# Appendix E Additional Tables of Results

Appendix E Table 1 Diagnostic Accuracy of Visual Acuity, Stereoacuity, Strabismus, and Combination Tests, by Test Type (KQ 2)

Appendix E Table 2 Characteristics of Studies That Report Diagnostic Accuracy of Visual Acuity, Stereoacuity, Strabismus, and Combination Tests (KQ 2)

Appendix E Table 3 Characteristics of Samples in Studies That Report Diagnostic Accuracy of Visual Acuity, Stereoacuity, Strabismus, and Combination Tests (KQ 2)

Appendix E Table 4 Diagnostic Accuracy of Autorefractors (KQ 2)

Appendix E Table 5 Diagnostic Accuracy of Photoscreeners (KQ 2)

Appendix E Table 6 Predictive Values of Screening Tests (KQ 2)

Appendix E Table 7 Diagnostic Accuracy of Screening Tests, Stratified by Age (KQ 2)

Appendix E Table 8 Additional Diagnostic Accuracy Study Results (KQ 2)

Appendix E Table 9 Diagnostic Accuracy Study Results (KQ 2)

Appendix E Table 10 Characteristics of Studies That Report Reliability (KQ 2)

Appendix E Table 11 Results of Studies That Report Reliability (KQ 2)

Appendix E Table 12 Characteristics of Randomized, Controlled Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQs 4 and 5)

Appendix E Table 13 Characteristics of Randomized, Controlled Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQ 4s and 5)

Appendix E Table 14 Results of Randomized, Controlled Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQ 4)

Appendix E Table 15 Adverse Events Reported in Randomized, Controlled Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQ 5)