# Appendix D Quality Assessments

Appendix D Table 1 Quality Assessment for Randomized, Controlled Trial (KQ 1)

Study, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Were outcome measurements equal, valid, and reliable? | Were outcome assessors masked? | Did the study have cross-overs or contamination raising concern for bias? | Differential loss to followup or overall high loss to followup raising concern for bias? | Did the study use acceptable statistical methods? | Quality Rating | Comments
Williams et al, 2001^74^ and 2002^75^ | No | Yes | Yes | Yes | Yes | NR | No | Yes | Modified ITT, no handling of missing data | Fair | Participants were invited to intervention or control according to the last digit of the mother's day of birth (not random); high overall attrition; of 3,490 children invited, 1,914 attended the final exam at 7.5 years and were included in analyses (55% of those randomized); differential attrition was low (1%); modified ITT (children remained in groups they were invited in to, regardless of whether they attended intervention clinics); no handling of missing data.

Abbreviations: ITT=intention to treat; KQ=Key Question.

Appendix D Table 2 Quality Assessment for Prospective Cohort Study (KQ 1)

First Author, Year | Did the study have differential attrition or overall high attrition raising concern for bias? | Were outcome measurements equal, valid, and reliable? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | Did the analysis control for baseline differences between groups? | Did the analysis control for potential confounders? | Did the analysis account for differences in treatment received by the groups? | Were the statistical methods used to assess the outcomes appropriate? | Quality Rating | Comments
Williams et al, 2003^76^ | Yes; see footnote^a^ | Yes | Yes | Yes | Yes | Yes | NA | Yes | Fair | See footnote^a^

a High overall attrition. Approximately 14,000 were recruited/enrolled in ALSPAC cohort study; 8,042 attended the final exam at 7.5 years. Of these, 1,917 were in the RCT and excluded and 44 had developmental delays and were excluded, leaving 6,081 analyzed (of those, 1,516 had been offered preschool vision screening and 1,019 had received it).

Abbreviations: ALSPAC=Avon Longitudinal Study of Parents and Children; KQ=Key Question; RCT=randomized controlled trial.

Appendix D Table 3 Quality Assessments: Studies of Test Accuracy and Reliability (KQ 2)

Author, Year | Representative Spectrum^a^ | Random or Consecutive Sample | Screening Test Adequately Described | Screening Cutoffs Predefined | Credible Reference Standard | Reference Standard Applied to All Screened or Random Samples^b^ | Time Between Test and Reference Short Enough^c^ | Reference Standard and Screening Exam Interpreted Independently | High Rate of Uninterpretable Results or Noncompliance with Screening Test | Analysis Includes Patients with Uninterpretable Results or Noncompliance | Quality Score
Adler et al, 2012^151^ | Unclear | Yes | Yes | NA | Yes (test-retest) | Yes | Yes | Partially (for less than half of retests) | No | NA | Poor
Afsari et al, 2013^77^ | Yes | NR | Yes | No | Yes | Yes | Yes | NR | Yes (35%) | No | Fair
Arthur et al, 2009^78^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | NA | Fair
Barry et al, 2001^79^ | Yes | Yes | Yes | Yes | NR | No | Yes | NR | NR | NR | Fair
Barry et al, 2003^80^ | Yes | Yes | Yes | Yes | NR | No | Yes | Yes | Yes | No | Fair
Bertuzzi et al, 2006^81^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | No | No | Fair
Chui et al, 2004^82^ | Yes | NR | Yes | Yes | Yes | No | Yes | Yes | NR | Yes | Fair
Cogen et al, 1992^83^ | Yes | NR | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Fair
Cooper et al, 1999^152^ | No | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Poor
Dahlmann-Noor et al, 2009^84^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Fair
Dahlmann-Noor et al, 2009^85^ | Yes | NR | Yes | Yes | NR | Yes | Yes | NR | No | NA | Fair
Ehrt et al, 2007^153^ | No | NR | Yes | Yes | NR | NR | Yes | NR | Yes | Yes | Poor
Harvey et al, 2009^86^ | No | NR | Yes | NA | NA (testability) | NA | NA | NA | No | Yes | Fair
Hope et al, 1990^87^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | No | No | Fair
Huang et al, 2013^88^ | No | Yes (random for those who passed; all those who failed screen) | Yes | No | Yes | Yes | Yes | Yes | No | No | Fair
Jost, 2015 ^89^ | Yes | Yes | Yes | Yes | Yes | No (but attempted to) | NR | Yes | Yes | Yes (former) No (latter) | Fair
Kemper et al, 2005^90^ | No | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | NR | Fair
Kennedy et al, 1989^91^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | NA | Fair
Kennedy et al, 1995^92^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | No | NA | Fair
Kennedy et al, 2000^93^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Kulp et al, 2014^94^ | No | Yes (random for those who passed; all those who failed screen) | Yes | No | Yes | Yes | Yes | Yes | No | NR | Fair
Leone et al, 2012^95^ | Yes | NR | Yes | NA | NA (testability) | NA | NA | NA | Yes, for age 24 to <36 months | Yes | Fair
Matta et al, 2008^96^ | No | NR | Yes | Yes | Yes | Yes | Yes | NR | NR | NR | Fair
Miller et al, 1999^97^ | No (High-prevalence population) | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Miller et al, 2001^98^ | No (High-prevalence population) | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Molteno et al, 1993^154^ | No | NR | Yes | Yes | No | Yes | Yes | NR | NR | NR | Poor
Morgan et al, 1987^99^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Ottar et al, 2002^101^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | Fair
Rogers et al, 2008^102^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Schmidt (VIP) et al, 2004^65^; Freedman, 2006^104^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | No | No | Fair
Shallo-Hoffmann et al, 2004^103^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Singman et al, 2013^155^ | No | Yes | Yes | Yes | Yes | NR | Unclear | NR | Unclear | NR | Poor
Tong et al, 2000^105^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
VIP, 2011^106^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | No | Yes | Fair
VIP, 2010^107^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | No | Yes | Fair
VIP, 2005^108^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | No | Yes | Fair
Weinand et al, 1998^109^ | No | NR | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Williams et al, 2000^110^ | Yes | NR | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Fair
Ying et al, 2011^111^ | No | NR | Yes | No | Yes | Yes | Yes | Yes | No | Yes | Fair

a Was the spectrum of patients representative of the patients who will receive the test in primary care?

b Did the whole or a random selection of the sample receive reference test? Did patients receive the same reference diagnostic test regardless of screening test results?

c Is the time period between the test and reference test short enough (to be reasonably sure that the condition did not change between the two tests) (no longer than 1 year)?

Abbreviations: VIP=Vision in Preschoolers.

Appendix D Table 4 Quality Assessments for Randomized, Controlled Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQs 4 and 5)

First Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Was intervention fidelity adequate? | What was reported adherence to the intervention? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias?
Awan et al, 2005^117^ | NR | Yes | Yes | Yes | 1 hour, 43 min per day for the 3-hour group; 2 hours, 33 min per day for 6-hour group | 13.3% | 5% | No
Clarke et al, 2003^115^ | Yes | Yes | Yes | Yes | 69% of those prescribed glasses wore them most or all the time; 6% would not wear them at all. 25/42 (60%) requiring patching wore it >two-thirds of the required time; 7% would not wear at all | 5.1% (at 52 weeks) | 0 | No
Wallace et al, 2006^116^ PEDIG | Yes | NR | Yes | Yes | Patching adherence was excellent (76–100%) for 68%, good (51–75%) for 22%, and fair-poor for 9% | 3.9% (at 5 weeks) | 3.1% | No

Abbreviations: KQ=Key Question; min=minutes; NR=not reported; PEDIG=Pediatric Eye Disease Investigator Group.

First Author, Year | Did the study have cross-overs or contamination raising concern for bias? | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptable statistical methods? | Quality Rating
Awan et al, 2005^117^ | No | Yes | No | No | No | Yes | NR | Yes | Fair
Clarke et al, 2003^115^ | No (very few) | Yes | No | No | Yes | Yes | None | Yes | Good
Wallace et al, 2006^116^ PEDIG | No | Yes | No | No | Yes | Yes | None | Yes | Good

Abbreviations: ITT=intention to treat; KQ=Key Question; NR=not reported; PEDIG=Pediatric Eye Disease Investigator Group.