# Appendix C Excluded Studies

Coding scheme:

X1 | Non-English
X2 | Not original research
X3 | Ineligible population
X4 | Ineligible screening or intervention
X5 | Ineligible comparator
X6 | Ineligible outcome
X7 | Ineligible setting
X8 | Ineligible study design
X9 | Ineligible country
X10 | Poor quality

1 Joint statement--Learning disabilities, dyslexia, and vision. Pediatrics. 2009 Aug;124(2):837-44. doi: 10.1542/peds.2009-1445. PMID: 19651597. Exclusion Code: X2.19651597
2 Prevalence and causes of visual impairment in African-American and Hispanic preschool children: the multi-ethnic pediatric eye disease study. Ophthalmology. 2009 Oct;116(10):1990-2000.e1. doi: 10.1016/j.ophtha.2009.03.027. PMID: 19592106. Exclusion Code: X6.19592106
3 Interobserver reliability of the prism and alternate cover test in children with esotropia. Arch Ophthalmol. 2009 Jan;127(1):59-65. doi: 10.1001/archophthalmol.2008.548. PMID: 19139339. Exclusion Code: X3.19139339
4 Impact of confidence number on accuracy of the SureSight Vision Screener. Optom Vis Sci. 2010 Feb;87(2):96-103. doi: 10.1097/OPX.0b013e3181cc8fb9. PMID: 20061987. Exclusion Code: X6.20061987
5 Abrams MS, Duncan CL, McMurtrey R. Development of motor fusion in patients with a history of strabismic amblyopia who are treated part-time with Bangerter foils. J AAPOS. 2011 Apr;15(2):127-30. doi: 10.1016/j.jaapos.2010.12.012. PMID: 21470883. Exclusion Code: X5.21470883
6 Adhikari S, Shrestha U. Validation of performance of certified medical assistants in preschool vision screening examination. Nepal J Ophthalmol. 2011 Jul-Dec;3(2):128-33. doi: http://dx.doi.org/10.3126/nepjoph.v3i2.5264. PMID: 21876585. Exclusion Code: X9.21876585
7 Adler P, Scally AJ, Barrett BT. Test--retest variability of Randot stereoacuity measures gathered in an unselected sample of UK primary school children. Br J Ophthalmol. 2012 May;96(5):656-61. doi: 10.1136/bjophthalmol-2011-300729. PMID: 22317911. Exclusion Code: X10.22317911
8 Afsari S, Rose KA, Gole GA, . Prevalence of anisometropia and its association with refractive error and amblyopia in preschool children. Br J Ophthalmol. 2013 Sep;97(9):1095-9. doi: 10.1136/bjophthalmol-2012-302637. PMID: 23613508. Exclusion Code: X6.23613508
9 Agervi P, Kugelberg U, Kugelberg M, . Treatment of anisometropic amblyopia with spectacles or in combination with translucent Bangerter filters. Ophthalmology. 2009 Aug;116(8):1475-80. doi: 10.1016/j.ophtha.2009.02.023. PMID: 19500854. Exclusion Code: X5.19500854
10 Agervi P, Kugelberg U, Kugelberg M, . Randomized evaluation of spectacles plus alternate-day occlusion to treat amblyopia. Ophthalmology. 2010 Feb;117(2):381-7. doi: 10.1016/j.ophtha.2009.07.020. PMID: 20006908. Exclusion Code: X5.20006908
11 Agervi P, Kugelberg U, Kugelberg M, . Two-year follow-up of a randomized trial of spectacles plus alternate-day patching to treat strabismic amblyopia. Acta Ophthalmol. 2013 Nov;91(7):678-84. doi: 10.1111/j.1755-3768.2012.02536.x. PMID: 22998746. Exclusion Code: X5.22998746
12 Agervi P, Kugelberg U, Kugelberg M, . Two-year follow-up of a randomized trial of spectacles alone or combined with Bangerter filters for treating anisometropic amblyopia. Acta Ophthalmol. 2013 Feb;91(1):71-7. doi: 10.1111/j.1755-3768.2011.02227.x. PMID: 21883985. Exclusion Code: X5.21883985
13 Akinci A, Oner O, Guven A, . Refractive errors and strabismus in children with tuberous sclerosis: a controlled study. J Pediatr Ophthalmol Strabismus. 2009 Nov-Dec;46(6):345-8. doi: 10.3928/01913913-20091104-06. PMID: 19928739. Exclusion Code: X3.19928739
14 Al Wadaani FA, Amin TT, Ali A, . Prevalence and pattern of refractive errors among primary school children in Al Hassa , Saudi Arabia. Glob J Health Sci. 2013 Jan;5(1):125-34. doi: 10.5539/gjhs.v5n1p125. PMID: 23283044. Exclusion Code: X3.23283044
15 AlHarkan DH, Khan AO. False amblyopia prediction in strabismic patients by fixation preference testing correlates with contralateral ocular dominance. J AAPOS. 2014 Oct;18(5):453-6. doi: 10.1016/j.jaapos.2014.06.010. PMID: 25266829. Exclusion Code: X3.25266829
16 Allen LE, Slater ME, Proffitt RV, . A new perimeter using the preferential looking response to assess peripheral visual fields in young and developmentally delayed children. J AAPOS. 2012 Jun;16(3):261-5. doi: 10.1016/j.jaapos.2012.01.006. PMID: 22681943. Exclusion Code: X3.22681943
17 Alotaibi AG, Fawazi SM, Alenazy BR, . Outcomes of 3 hours part-time occlusion treatment combined with near activities among children with unilateral amblyopia. Saudi Med J. 2012 Apr;33(4):395-8. PMID: 22485234. Exclusion Code: X5.22485234
18 Anderson HA, Stuebing KK. Subjective versus objective accommodative amplitude: preschool to presbyopia. Optom Vis Sci. 2014 Nov;91(11):1290-301. doi: 10.1097/opx.0000000000000402. PMID: 25602235. Exclusion Code: X5.25602235
19 Anstice N, Spink J, Abdul-Rahman A. Review of preschool vision screening referrals in South Auckland, New Zealand. Clin Exp Optom. 2012 Jul;95(4):442-8. doi: 10.1111/j.1444-0938.2012.00713.x. PMID: 22507224. Exclusion Code: X5.22507224
20 Arana Mendez M, Arguello L, Martinez J, . Evaluation of the Spot Vision Screener in young children in Costa Rica. J AAPOS. 2015 Oct;19(5):441-4. doi: 10.1016/j.jaapos.2015.08.002. PMID: 26486026. Exclusion Code: X9.26486026
21 Arnold RW, Armitage MD. Performance of four new photoscreeners on pediatric patients with high risk amblyopia. J Pediatr Ophthalmol Strabismus. 2014 Jan-Feb;51(1):46-52. doi: 10.3928/01913913-20131223-02. PMID: 24369683. Exclusion Code: X3.24369683
22 Arnold RW, Arnold AW, Armitage MD, . Pediatric photoscreeners in high risk patients 2012: a comparison study of Plusoptix, Iscreen and SPOT. Binocul Vis Strabolog Q Simms Romano. 2013;28(1):20-8. PMID: 23521032. Exclusion Code: X3.23521032
23 Arnold RW, Davis B, Arnold LE, . Calibration and validation of nine objective vision screeners with contact lens-induced anisometropia. J Pediatr Ophthalmol Strabismus. 2013 May-Jun;50(3):184-90. doi: 10.3928/01913913-20130402-02. PMID: 23565714. Exclusion Code: X8.23565714
24 Arnold RW, Lichtenstein SJ. Treatment options for dense amblyopia in uncooperative children. J Pediatr Ophthalmol Strabismus. 2010 May-Jun;47(3):134-8. doi: 10.3928/01913913-20100505-01. PMID: 20506995. Exclusion Code: X2.20506995
25 Arnold RW, Tulip D, McArthur E, . Predictive value from pediatrician plusoptix screening: impact of refraction and binocular alignment. Binocul Vis Strabolog Q Simms Romano. 2012;27(4):227-32. PMID: 23234483. Exclusion Code: X8.23234483
26 Athaide HV, Campos M, Costa C. Study of ocular aberrations with age. Arq Bras Oftalmol. 2009 Sep-Oct;72(5):617-21. PMID: 20027396. Exclusion Code: X3.20027396
27 Avram E, Stanila A. [Treating anisometric amblyopia with HTS Amblyopia iNet Software--preliminary results]. Oftalmologia. 2013;57(2):32-7. PMID: 24386790. Exclusion Code: X1.24386790
28 Ayanniyi A, Mahmoud AO, Olatunji FO. Causes and prevalence of ocular morbidity among primary school children in Ilorin, Nigeria. Niger J Clin Pract. 2010 Sep;13(3):248-53. PMID: 20857778. Exclusion Code: X5.20857778
29 Ayse YK, Onder U, Suheyla K. Accuracy of Plusoptix S04 in children and teens. Can J Ophthalmol. 2011 Apr;46(2):153-7. PMID: 21708083. Exclusion Code: X3.21708083
30 Bani SA, Amitava AK, Sharma R, . Beyond photography: evaluation of the consumer digital camera to identify strabismus and anisometropia by analyzing the Bruckner's reflex. Indian J Ophthalmol. 2013 Oct;61(10):608-11. doi: 10.4103/0301-4738.121092. PMID: 24212318. Exclusion Code: X5.24212318
31 Bau V, Rose K, Pollack K, . [Effectivity of an occlusion-supporting PC-based visual training programme by horizontal drifting sinus gratings in children with amblyopia]. Klin Monbl Augenheilkd. 2012 Oct;229(10):979-86. doi: 10.1055/s-0032-1315308. PMID: 23096142. Exclusion Code: X1.23096142
32 Beneish RG, Polomeno RC, Flanders ME, . Optimal compliance for amblyopia therapy: occlusion with a translucent tape on the lens. Can J Ophthalmol. 2009 Oct;44(5):523-8. doi: 10.3129/i09-122. PMID: 19789586. Exclusion Code: X5.19789586
33 Berntsen DA, Mutti DO, Zadnik K. The effect of bifocal add on accommodative lag in myopic children with high accommodative lag. Invest Ophthalmol Vis Sci. 2010 Dec;51(12):6104-10. doi: 10.1167/iovs.09-4417. PMID: 20688729. Exclusion Code: X5.20688729
34 Berry BE, Simons BD, Siatkowski RM, . Preschool vision screening using the MTI-Photoscreener. Pediatr Nurs. 2001 Jan-Feb;27(1):27-34. PMID: 12025144. Exclusion Code: X3.12025144
35 Birch EE. Amblyopia and binocular vision. Prog Retin Eye Res. 2013 Mar;33:67-84. doi: 10.1016/j.preteyeres.2012.11.001. PMID: 23201436. Exclusion Code: X2.23201436
36 Bloomberg JD, Suh DW. The accuracy of the plusoptiX A08 photoscreener in detecting risk factors for amblyopia in central Iowa. J AAPOS. 2013 Jun;17(3):301-4. doi: 10.1016/j.jaapos.2013.03.014. PMID: 23791414. Exclusion Code: X3.23791414
37 Blows SJ, Murphy EP, Martin FJ, . Vision screening in preschoolers: the New South Wales Statewide Eyesight Preschooler Screening program. Med J Aust. 2014 Mar 3;200(4):222-5. PMID: 24580526. Exclusion Code: X6.24580526
38 Bogdanici T, Tone S, Miron M, . [Use of Plusoptix as a screening method for refractive ambliopia]. Oftalmologia. 2012;56(2):49-55. PMID: 23424764. Exclusion Code: X1.23424764
39 Borchert MS, Varma R, Cotter SA, . Risk factors for hyperopia and myopia in preschool children the multi-ethnic pediatric eye disease and Baltimore pediatric eye disease studies. Ophthalmology. 2011 Oct;118(10):1966-73. doi: 10.1016/j.ophtha.2011.06.030. PMID: 21856013. Exclusion Code: X5.21856013
40 Bottin D, Waldhauser K, Bertelli E. The pediatric vision screening program performed in Bolzano in 2010: significance of the orthoptic re-examination. Strabismus. 2013 Jun;21(2):81-4. doi: 10.3109/09273972.2013.786738. PMID: 23713926. Exclusion Code: X6.23713926
41 Bregman J, Donahue SP. Validation of photoscreening technology in the general pediatrics office: a prospective study. J AAPOS. 2016 Apr;20(2):153-8. doi: 10.1016/j.jaapos.2016.01.004. PMID: 27079598. Exclusion Code: X10.27079598
42 Buck D, Powell CJ, Rahi J, . The improving outcomes in intermittent exotropia study: outcomes at 2 years after diagnosis in an observational cohort. BMC Ophthalmol. 2012;12:1. doi: 10.1186/1471-2415-12-1. PMID: 22257496. Exclusion Code: X8.22257496
43 Casati R. Shadow-related concavity-convexity inversions reveal a very basic tolerance for impossible shadows. Perception. 2014;43(4):351-2. PMID: 25109023. Exclusion Code: X2.25109023
44 Chandrakumar M, Colpa L, Reginald YA, . Measuring contrast sensitivity using the M&S Smart System II versus the Pelli-Robson chart. Ophthalmology. 2013 Oct;120(10):2160-1.e1. doi: 10.1016/j.ophtha.2013.07.022. PMID: 24090954. Exclusion Code: X3.24090954
45 Chang CH, Tsai RK, Sheu MM. Screening amblyopia of preschool children with uncorrected vision and stereopsis tests in Eastern Taiwan. Eye (Lond). 2007 Dec;21(12):1482-8. doi: 10.1038/sj.eye.6702568. PMID: 16946752. Exclusion Code: X9.16946752
46 Charm J, Cho P. High myopia-partial reduction orthokeratology (HM-PRO): study design. Cont Lens Anterior Eye. 2013 Aug;36(4):164-70. doi: 10.1016/j.clae.2013.02.012. PMID: 23518209. Exclusion Code: X3.23518209
47 Chen S, Wang B, Dong N, . Macular measurements using spectral-domain optical coherence tomography in Chinese myopic children. Invest Ophthalmol Vis Sci. 2014 Nov;55(11):7410-6. doi: 10.1167/iovs.14-13894. PMID: 25316719. Exclusion Code: X3.25316719
48 Chen W, Chen J, Zhang F, . Visual outcome in isoametropic amblyopic children with high hyperopia and the effect of therapy on retinal thickness. Am J Ophthalmol. 2013 Mar;155(3):536-43.e1. doi: 10.1016/j.ajo.2012.09.028. PMID: 23219065. Exclusion Code: X5.23219065
49 Cheng HC, Hsieh YT. Short-term refractive change and ocular parameter changes after cycloplegia. Optom Vis Sci. 2014 Sep;91(9):1113-7. doi: 10.1097/opx.0000000000000339. PMID: 25036542. Exclusion Code: X6.25036542
50 Chia A, Chua WH, Wen L, . Atropine for the treatment of childhood myopia: changes after stopping atropine 0.01%, 0.1% and 0.5%. Am J Ophthalmol. 2014 Feb;157(2):451-7.e1. doi: 10.1016/j.ajo.2013.09.020. PMID: 24315293. Exclusion Code: X3.24315293
51 Chia A, Lin X, Dirani M, . Risk factors for strabismus and amblyopia in young Singapore Chinese children. Ophthalmic Epidemiol. 2013 Jun;20(3):138-47. doi: 10.3109/09286586.2013.767354. PMID: 23713916. Exclusion Code: X5.23713916
52 Cho YA, Ryu WY. Changes in refractive error in patients with accommodative esotropia after being weaned from hyperopic correction. Br J Ophthalmol. 2015 May;99(5):680-4. doi: 10.1136/bjophthalmol-2014-305991. PMID: 25416183. Exclusion Code: X4.25416183
53 Chou YS, Tai MC, Chen PL, . Impact of cylinder axis on the treatment for astigmatic amblyopia. Am J Ophthalmol. 2014 Apr;157(4):908-14.e1. doi: 10.1016/j.ajo.2013.12.020. PMID: 24384526. Exclusion Code: X8.24384526
54 Colburn JD, Morrison DG, Estes RL, . Longitudinal follow-up of hypermetropic children identified during preschool vision screening. J AAPOS. 2010 Jun;14(3):211-5. doi: 10.1016/j.jaapos.2010.02.006. PMID: 20603055. Exclusion Code: X8.20603055
55 Cole SR, Beck RW, Moke PS, . The Amblyopia Treatment Index. J AAPOS; 2001. p. 250-4. Exclusion Code: X8.11507585
56 Cooper CD, Gole GA, Hall JE, . Evaluating photoscreeners II: MTI and fortune videorefractor. Aust N Z J Ophthalmol. 1999 Dec;27(6):387-98. PMID: 10641896. Exclusion Code: X10.10641896
57 Cooper EL, Leyman IA. The management of intermittent exotropia: a comparison of the results of surgical and nonsurgical treatment. Am Orthopt J. 1977;27:61-7. PMID: 900622. Exclusion Code: X5.900622
58 Cotter SA, Foster NC, Holmes JM, . Optical treatment of strabismic and combined strabismic-anisometropic amblyopia. Ophthalmology. 2012 Jan;119(1):150-8. doi: 10.1016/j.ophtha.2011.06.043. PMID: 21959371. Exclusion Code: X5.21959371
59 Cotter SA, Mohney BG, Chandler DL, . A randomized trial comparing part-time patching with observation for children 3 to 10 years of age with intermittent exotropia. Ophthalmology. 2014 Dec;121(12):2299-310. doi: 10.1016/j.ophtha.2014.07.021. PMID: 25234012. Exclusion Code: X6.25234012
60 Cotter SA, Varma R, Tarczy-Hornoch K, . Risk factors associated with childhood strabismus: the Multi-Ethnic Pediatric Eye Disease and Baltimore Pediatric Eye Disease Studies. Ophthalmology. 2011 Nov;118(11):2251-61. doi: 10.1016/j.ophtha.2011.06.032. PMID: 21856012. Exclusion Code: X5.21856012
61 de Koning HJ, Groenewoud JH, Lantau VK, . Effectiveness of screening for amblyopia and other eye disorders in a prospective birth cohort study. J Med Screen. 2013 Jun;20(2):66-72. doi: 10.1177/0969141313497355. PMID: 24009090. Exclusion Code: X5.24009090
62 Demirci G, Arslan B, Ozsutcu M, . Comparison of photorefraction, autorefractometry and retinoscopy in children. Int Ophthalmol. 2014 Aug;34(4):739-46. doi: 10.1007/s10792-013-9864-x. PMID: 24114503. Exclusion Code: X6.24114503
63 Dobson V, Clifford-Donaldson CE, Green TK, . Optical treatment reduces amblyopia in astigmatic children who receive spectacles before kindergarten. Ophthalmology. 2009 May;116(5):1002-8. doi: 10.1016/j.ophtha.2008.11.013. PMID: 19232733. Exclusion Code: X8.19232733
64 Donahue SP. How often are spectacles prescribed to “normal” preschool children? J AAPOS. 2004 Jun;8(3):224-9. doi: 10.1016/S1091853104000965. PMID: 15226721. Exclusion Code: X5.15226721
65 Drover JR, Morale SE, Wang YZ, . Vernier acuity cards: examination of development and screening validity. Optom Vis Sci. 2010 Nov;87(11):E806-12. doi: 10.1097/OPX.0b013e3181f6fb5e. PMID: 20871472. Exclusion Code: X6.20871472
66 Drover JR, Wyatt LM, Stager DR, . The teller acuity cards are effective in detecting amblyopia. Optom Vis Sci. 2009 Jun;86(6):755-9. doi: 10.1097/OPX.0b013e3181a523a3. PMID: 19390474. Exclusion Code: X3.19390474
67 Ehrt O, Weber A, Boergen KP. Screening for refractive errors in preschool children with the vision screener. Strabismus. 2007 Jan-Mar;15(1):13-9. doi: 10.1080/09273970601174969. PMID: 17523041. Exclusion Code: X10.17523041
68 Eibschitz-Tsimhoni M, Friedman T, Naor J, . Early screening for amblyogenic risk factors lowers the prevalence and severity of amblyopia. J AAPOS. 2000 Aug;4(4):194-9. doi: 10.1067/mpa.2000.105274. PMID: 10951293. Exclusion Code: X8.10951293
69 Elliott MC, Firth AY. The logMAR Kay picture test and the logMAR acuity test: a comparative study. Eye (Lond). 2009 Jan;23(1):85-8. doi: 10.1038/sj.eye.6702990. PMID: 17901881. Exclusion Code: X3.17901881
70 Engin O, Despriet DD, van der Meulen-Schot HM, . Comparison of optotypes of Amsterdam Picture Chart with those of Tumbling-E, LEA symbols, ETDRS, and Landolt-C in non-amblyopic and amblyopic patients. Graefes Arch Clin Exp Ophthalmol. 2014 Dec;252(12):2013-20. doi: 10.1007/s00417-014-2763-7. PMID: 25228066. Exclusion Code: X3.25228066
71 Erasmus Medical C, Icare Health Care DYHCM, Public Health Service of A. Disinvestment Study of Population-Based Vision Screening in Children. 2016. Exclusion Code: X6.
72 Fabian ID, Kinori M, Ancri O, . The possible association of attention deficit hyperactivity disorder with undiagnosed refractive errors. J AAPOS. 2013 Oct;17(5):507-11. doi: 10.1016/j.jaapos.2013.06.005. PMID: 24160972. Exclusion Code: X6.24160972
73 Feldman W, Milner RA, Sackett B, . Effects of preschool screening for vision and hearing on prevalence of vision and hearing problems 6-12 months later. Lancet. 1980 Nov 8;2(8202):1014-6. PMID: 6107638. Exclusion Code: X8.6107638
74 Felius J, Beauchamp CL, Stager DR, Sr. Visual acuity deficits in children with nystagmus and Down syndrome. Am J Ophthalmol. 2014 Feb;157(2):458-63. doi: 10.1016/j.ajo.2013.09.023. PMID: 24315291. Exclusion Code: X3.24315291
75 Figueira EC, Hing S. Intermittent exotropia: comparison of treatments. Clin Experiment Ophthalmol. 2006 Apr;34(3):245-51. doi: 10.1111/j.1442-9071.2006.01199.x. PMID: 16671905. Exclusion Code: X5.16671905
76 Fledelius HC, Bangsgaard R, Slidsborg C, . The usefulness of the Retinomax autorefractor for childhood screening validated against a Danish preterm cohort examined at the age of 4 years. Eye (Lond). 2015 Jun;29(6):742-7. doi: 10.1038/eye.2015.14. PMID: 25853445. Exclusion Code: X3.25853445
77 Fledelius HC, Bangsgaard R, Slidsborg C, . Refraction and visual acuity in a national Danish cohort of 4-year-old children of extremely preterm delivery. Acta Ophthalmol. 2015 Jun;93(4):330-8. doi: 10.1111/aos.12643. PMID: 25832810. Exclusion Code: X3.25832810
78 Foo VH, Verkicharla PK, Ikram MK, . Axial Length/Corneal Radius of Curvature Ratio and Myopia in 3-Year-Old Children. Transl Vis Sci Technol. 2016 Feb;5(1):5. doi: 10.1167/tvst.5.1.5. PMID: 26929885. Exclusion Code: X4.26929885
79 Foss AJ, Gregson RM, MacKeith D, . Evaluation and development of a novel binocular treatment (I-BiT) system using video clips and interactive games to improve vision in children with amblyopia (‘lazy eye’): study protocol for a randomised controlled trial. Trials. 2013;14:145. doi: 10.1186/1745-6215-14-145. PMID: 23688108. Exclusion Code: X2.23688108
80 Fotouhi A, KhabazKhoob M, Hashemi H, . Importance of including refractive error tests in school children's vision screening. Arch Iran Med. 2011 Jul;14(4):250-3. PMID: 21726100. Exclusion Code: X6.21726100
81 Franco AM, Lopes YC, Souza PH, . [Biometry in the growth of the high myopic eye in childhood]. Arq Bras Oftalmol. 2013 Oct;76(5):265-9. PMID: 24232937. Exclusion Code: X1.24232937
82 Fresina M, Schiavi C, Campos EC. Do bifocals reduce accommodative amplitude in convergence excess esotropia? Graefes Arch Clin Exp Ophthalmol. 2010 Oct;248(10):1501-5. doi: 10.1007/s00417-010-1418-6. PMID: 20524131. Exclusion Code: X3.20524131
83 Friedman DS, Repka MX, Katz J, . Prevalence of amblyopia and strabismus in white and African American children aged 6 through 71 months the Baltimore Pediatric Eye Disease Study. Ophthalmology. 2009 Nov;116(11):2128-34.e1-2. doi: 10.1016/j.ophtha.2009.04.034. PMID: 19762084. Exclusion Code: X6.19762084
84 Funarunart P, Tengtrisorn S, Sangsupawanich P, . Accuracy of noncycloplegic refraction in primary school children in southern Thailand. J Med Assoc Thai. 2009 Jun;92(6):806-11. PMID: 19530586. Exclusion Code: X3.19530586
85 Gabriel GM, Mutti DO. Evaluation of infant accommodation using retinoscopy and photoretinoscopy. Optom Vis Sci. 2009 Mar;86(3):208-15. doi: 10.1097/OPX.0b013e3181960652. PMID: 19165126. Exclusion Code: X5.19165126
86 Ganekal S, Jhanji V, Liang Y, . Prevalence and etiology of amblyopia in Southern India: results from screening of school children aged 5-15 years. Ophthalmic Epidemiol. 2013 Aug;20(4):228-31. doi: 10.3109/09286586.2013.809772. PMID: 23865603. Exclusion Code: X6.23865603
87 Garretty T. Development of manifest strabismus and reduced visual acuity following initial normal orthoptic examination/pseudo-strabismus under the age of 30 months. Strabismus. 2014 Mar;22(1):26-31. doi: 10.3109/09273972.2013.877944. PMID: 24512635. Exclusion Code: X5.24512635
88 Garry GA, Donahue SP. Validation of Spot screening device for amblyopia risk factors. J AAPOS. 2014 Oct;18(5):476-80. doi: 10.1016/j.jaapos.2014.07.156. PMID: 25266832. Exclusion Code: X3.25266832
89 Giaschi D, Chapman C, Meier K, . The effect of occlusion therapy on motion perception deficits in amblyopia. Vision Res. 2015 Sep;114:122-34. doi: 10.1016/j.visres.2015.05.015. PMID: 26049038. Exclusion Code: X5.26049038
90 Gong RL. [Observation on therapeutic effect of child amblyopia treated with auricular point sticking therapy]. Zhongguo Zhen Jiu. 2011 Dec;31(12):1081-3. PMID: 22256639. Exclusion Code: X1.22256639
91 Gopinath B, Wang JJ, Kifley A, . The association between ocular biometry and retinal vascular caliber is comparable from early childhood to adolescence. Invest Ophthalmol Vis Sci. 2013 Feb;54(2):1501-8. doi: 10.1167/iovs.12-11036. PMID: 23329666. Exclusion Code: X6.23329666
92 Gorzny F. Children with problems at school. Dtsch Arztebl Int. 2011 Jan;108(3):39; author reply 40. doi: 10.3238/arztebl.2011.0039a. PMID: 21286001. Exclusion Code: X2.21286001
93 Granet DB, Khayali S. Amblyopia and strabismus. Pediatr Ann. 2011 Feb;40(2):89-94. doi: 10.3928/00904481-20110117-08. PMID: 21323205. Exclusion Code: X2.21323205
94 Grisham JD, Bowman MC, Owyang LA, . Vergence orthoptics: validity and persistence of the training effect. Optom Vis Sci. 1991 Jun;68(6):441-51. PMID: 1891195. Exclusion Code: X4.1891195
95 Groenewoud JH, Tjiam AM, Lantau VK, . Rotterdam AMblyopia screening effectiveness study: detection and causes of amblyopia in a large birth cohort. Invest Ophthalmol Vis Sci. 2010 Jul;51(7):3476-84. doi: 10.1167/iovs.08-3352. PMID: 20089868. Exclusion Code: X5.20089868
96 Guliaev V, Fedorov AA, Lobanova LS. [Electrodiagnostics and electrostimulation for the combined treatment of concomitant squint in children]. Vopr Kurortol Fizioter Lech Fiz Kult. 2010 Sep-Oct(5):44-6. PMID: 21328906. Exclusion Code: X1.21328906
97 Guo X, Fu M, Lu J, . Normative distribution of visual acuity in 3- to 6-year-old Chinese preschoolers: the Shenzhen kindergarten eye study. Invest Ophthalmol Vis Sci. 2015 Mar;56(3):1985-92. doi: 10.1167/iovs.14-15422. PMID: 25711637. Exclusion Code: X9.25711637
98 Guo X, Jia X, Guo L, . Comparison of computer-photoscreening with non-cycloplegic retinoscopy for amblyopiogenic risk factors in children. Chin Med J (Engl). 2000 Nov;113(11):1007-10. PMID: 11776113. Exclusion Code: X9.11776113
99 Guo Y, Liu LJ, Xu L, . Optic Disc Ovality in Primary School Children in Beijing. Invest Ophthalmol Vis Sci. 2015 Jul;56(8):4547-53. doi: 10.1167/iovs.15-16590. PMID: 26200494. Exclusion Code: X5.26200494
100 Guo Y, Liu LJ, Xu L, . Myopic shift and outdoor activity among primary school children: one-year follow-up study in Beijing. PLoS One. 2013;8(9):e75260. doi: 10.1371/journal.pone.0075260. PMID: 24086484. Exclusion Code: X3.24086484
101 Gusek-Schneider GC. [Results of late onset amblyopia therapy for excentric fixation in different forms of amblyopia]. Klin Monbl Augenheilkd. 2010 Oct;227(10):765-73. doi: 10.1055/s-0029-1245743. PMID: 20963678. Exclusion Code: X1.20963678
102 Haase W, Bock H, Petzold G. Early start of screening. Dtsch Arztebl Int. 2011 Jan;108(3):39; author reply 40. doi: 10.3238/arztebl.2011.0039b. PMID: 21286002. Exclusion Code: X2.21286002
103 Halegoua J, Schwartz RH. Vision photoscreening of infants and young children in a primary care pediatric office: can it identify asymptomatic treatable amblyopic risk factors? Clin Pediatr (Phila). 2015 Jan;54(1):33-9. doi: 10.1177/0009922814541805. PMID: 25009113. Exclusion Code: X8.25009113
104 Han ZH, Qiu M. [Randomized Controlled Clinical Trials for Treatment of Child Amblyopia with Otopoint Pellet-pressure Combined with Chinese Medical Herbs]. Zhen Ci Yan Jiu. 2015 Jun;40(3):247-50. PMID: 26237980. Exclusion Code: X1.26237980
105 Handa T, Ishikawa H, Nishimoto H, . Effect of motion stimulation without changing binocular disparity on stereopsis in strabismus patients. Am Orthopt J. 2010;60:87-94. PMID: 21061889. Exclusion Code: X5.21061889
106 Hardgrave N, Hatley J, Lewerenz D. Comparing LEA numbers low vision book and Feinbloom visual acuity charts. Optom Vis Sci. 2012 Nov;89(11):1611-8. doi: 10.1097/OPX.0b013e31826ab10a. PMID: 23026789. Exclusion Code: X3.23026789
107 Harvey EM. Development and treatment of astigmatism-related amblyopia. Optom Vis Sci. 2009 Jun;86(6):634-9. doi: 10.1097/OPX.0b013e3181a6165f. PMID: 19430327. Exclusion Code: X2.19430327
108 Harvey EM, Miller JM, Schwiegerling J. Utility of an open field Shack-Hartmann aberrometer for measurement of refractive error in infants and young children. J AAPOS. 2013 Oct;17(5):494-500. doi: 10.1016/j.jaapos.2013.05.015. PMID: 24160970. Exclusion Code: X5.24160970
109 Hashemi H, Khabazkhoob M, Asharlous A, . Cycloplegic autorefraction versus subjective refraction: the Tehran Eye Study. Br J Ophthalmol. 2015 Nov 5doi: 10.1136/bjophthalmol-2015-307871. PMID: 26541436. Exclusion Code: X3.26541436
110 Hatt SR, Leske DA, Liebermann L, . Variability of angle of deviation measurements in children with intermittent exotropia. J AAPOS. 2012 Apr;16(2):120-4. doi: 10.1016/j.jaapos.2011.11.008. PMID: 22525165. Exclusion Code: X3.22525165
111 Hatt SR, Liebermann L, Leske DA, . Improved assessment of control in intermittent exotropia using multiple measures. Am J Ophthalmol. 2011 Nov;152(5):872-6. doi: 10.1016/j.ajo.2011.05.007. PMID: 21843874. Exclusion Code: X3.21843874
112 Holmes JM, Beck RW, Kraker RT, . Impact of patching and atropine treatment on the child and family in the amblyopia treatment study. Archives of ophthalmology (Chicago, Ill. : 1960); 2003. p. 1625-32. Exclusion Code: X5.
113 Horwood AM, Riddell PM. Receding and disparity cues aid relaxation of accommodation. Optom Vis Sci. 2009 Nov;86(11):1276-86. doi: 10.1097/OPX.0b013e3181bb41de. PMID: 19770814. Exclusion Code: X5.19770814
114 Hu VH, Starling A, Baynham SN, . Accuracy of referrals from an orthoptic vision screening program for 3- to 4-year-old preschool children. J AAPOS. 2012 Feb;16(1):49-52. doi: 10.1016/j.jaapos.2011.06.013. PMID: 22237670. Exclusion Code: X8.22237670
115 Huurneman B, Boonstra FN, Cox RF, . Perceptual learning in children with visual impairment improves near visual acuity. Invest Ophthalmol Vis Sci. 2013;54(9):6208-16. doi: 10.1167/iovs.13-12220. PMID: 23950157. Exclusion Code: X8.23950157
116 Ilhan N, Dogan H, Ilhan O, . Compatibility of spectacles with their prescriptions in central Anatolia. Semin Ophthalmol. 2015 Jan;30(1):29-35. doi: 10.3109/08820538.2013.810287. PMID: 23952133. Exclusion Code: X5.23952133
117 Ingram RM, Lambert TW, Gill LE. Visual outcome in 879 children treated for strabismus: insufficient accommodation and vision deprivation, deficient emmetropisation and anisometropia. Strabismus. 2009 Oct-Dec;17(4):148-57. doi: 10.3109/09273970903376010. PMID: 20001509. Exclusion Code: X8.20001509
118 Iyer V, van Samkar A, Saeed P. The Bruckner test variant (BTV): a promising instrument in detecting vision disorders. Am Orthopt J. 2013;63:97-102. doi: 10.3368/aoj.63.1.97. PMID: 24141759. Exclusion Code: X5.24141759
119 Jaeb Center for Health R, National Eye I. A Pilot Clinical Trial of Overminus Spectacle Therapy for Intermittent Exotropia. 2015. Exclusion Code: X6.
120 Jaeb Center for Health R, National Eye I. Observation Versus Occlusion Therapy for Intermittent Exotropia. 2015. Exclusion Code: X6.
121 Jaeb Center for Health R, National Eye I. Hyperopia Treatment Study 1 (HTS1) - Glasses vs Observation. 2018. Exclusion Code: X6.
122 Jefferis JM, Connor AJ, Clarke MP. Amblyopia. BMJ. 2015;351:h5811. doi: 10.1136/bmj.h5811. PMID: 26563241. Exclusion Code: X2.26563241
123 Jethani J, Seethapathy G, Purohit J, . Measuring normal ocular torsion and its variation by fundus photography in children between 5-15 years of age. Indian J Ophthalmol. 2010 Sep-Oct;58(5):417-9. doi: 10.4103/0301-4738.67060. PMID: 20689198. Exclusion Code: X3.20689198
124 Jones D, Luensmann D. The prevalence and impact of high myopia. Eye Contact Lens. 2012 May;38(3):188-96. doi: 10.1097/ICL.0b013e31824ccbc3. PMID: 22495679. Exclusion Code: X2.22495679
125 Jones PR, Kalwarowsky S, Atkinson J, . Automated measurement of resolution acuity in infants using remote eye-tracking. Invest Ophthalmol Vis Sci. 2014 Dec;55(12):8102-10. doi: 10.1167/iovs.14-15108. PMID: 25352118. Exclusion Code: X3.25352118
126 Jost RM, Yanni SE, Beauchamp CL, . Beyond screening for risk factors: objective detection of strabismus and amblyopia. JAMA Ophthalmol. 2014 Jul;132(7):814-20. doi: 10.1001/jamaophthalmol.2014.424. PMID: 24875453. Exclusion Code: X3.24875453
127 Kelly SA, Pang Y, Klemencic S. Reliability of the CSV-1000 in adults and children. Optom Vis Sci. 2012 Aug;89(8):1172-81. doi: 10.1097/OPX.0b013e318264097b. PMID: 22797510. Exclusion Code: X3.22797510
128 Kemper AR, Helfrich A, Talbot J, . Outcomes of an elementary school-based vision screening program in North Carolina. J Sch Nurs. 2012 Feb;28(1):24-30. doi: 10.1177/1059840511424413. PMID: 21970861. Exclusion Code: X3.21970861
129 Kerr NC, Somes G, Enzenauer RW. The effect of developmentally-at-risk status on the reliability of the iScreen(R) photorefractive device in young children. Am Orthopt J. 2011;61:117-23. doi: 10.3368/aoj.61.1.117. PMID: 21856879. Exclusion Code: X3.21856879
130 Khan T. Is there a critical period for amblyopia therapy? Results of a study on older anisometropic amblyopes. Journal of Clinical and Diagnostic Research; 2015. p. Nc01-nc4. Exclusion Code: X3.
131 Kirk S, Armitage MD, Dunn S, . Calibration and validation of the 2WIN photoscreener compared to the PlusoptiX S12 and the SPOT. J Pediatr Ophthalmol Strabismus. 2014 Sep-Oct;51(5):289-92. doi: 10.3928/01913913-20140701-01. PMID: 25000209. Exclusion Code: X3.25000209
132 Kirk VG, Clausen MM, Armitage MD, . Preverbal photoscreening for amblyogenic factors and outcomes in amblyopia treatment: early objective screening and visual acuities. Arch Ophthalmol. 2008 Apr;126(4):489-92. doi: 10.1001/archopht.126.4.489. PMID: 18413517. Exclusion Code: X8.18413517
133 Kirschen D, Isenberg SJ. The effectiveness of an autorefractor with eye-tracking capability in pediatric patients. J AAPOS. 2014 Jun;18(3):217-21. doi: 10.1016/j.jaapos.2013.12.019. PMID: 24924271. Exclusion Code: X3.24924271
134 Koenraads Y, Braun KP, van der Linden DC, . Perimetry in young and neurologically impaired children: the Behavioral Visual Field (BEFIE) Screening Test revisited. JAMA Ophthalmol. 2015 Mar;133(3):319-25. doi: 10.1001/jamaophthalmol.2014.5257. PMID: 25541916. Exclusion Code: X4.25541916
135 Kohler L, Stigmar G. Visual disorders in 7-year-old children with and without previous vision screening. Acta Paediatr Scand. 1978 May;67(3):373-7. PMID: 654915. Exclusion Code: X8.654915
136 Koklanis K, Abel LA, Aroni R. Psychosocial impact of amblyopia and its treatment: a multidisciplinary study. Clin Experiment Ophthalmol. 2006 Nov;34(8):743-50. doi: 10.1111/j.1442-9071.2006.01317.x. PMID: 17073896. Exclusion Code: X5.17073896
137 Koklanis K, Le T, Georgievski Z. The base-to-base induced-tropia prism test for detection of amblyopia: a pilot study. J AAPOS. 2010 Dec;14(6):484-7. doi: 10.1016/j.jaapos.2010.08.015. PMID: 21168071. Exclusion Code: X3.21168071
138 Kortum K, Kernt M, Reznicek L. [Significance of ophthalmological imaging in common hereditary retinal diseases]. Klin Monbl Augenheilkd. 2013 Mar;230(3):223-31. doi: 10.1055/s-0032-1327906. PMID: 23229225. Exclusion Code: X1.23229225
139 Koslowe KC, Spierer A, Rosner M, . Evaluation of accommotrac biofeedback training for myopia control. Optom Vis Sci. 1991 May;68(5):338-43. PMID: 1852394. Exclusion Code: X3.1852394
140 Kothari M, Bhaskare A, Mete D, . Evaluation of central, steady, maintained fixation grading for predicting inter-eye visual acuity difference to diagnose and treat amblyopia in strabismic patients. Indian J Ophthalmol. 2009 Jul-Aug;57(4):281-4. doi: 10.4103/0301-4738.53052. PMID: 19574695. Exclusion Code: X3.19574695
141 Kothari M, Kosumbkar S. Ultra-rapid school vision screening in developing nations using the Bruckner test. Am Orthopt J. 2010;60:82-6. PMID: 21061888. Exclusion Code: X3.21061888
142 Krishnacharya PS. Study on accommodation by autorefraction and dynamic refraction in children. J Optom. 2014 Oct-Dec;7(4):193-202. doi: 10.1016/j.optom.2014.07.001. PMID: 25130066. Exclusion Code: X6.25130066
143 Kulp M, Mitchell GL, Borsting E, . Effectiveness of placebo therapy for maintaining masking in a clinical trial of vergence/accommodative therapy. Invest Ophthalmol Vis Sci; 2009. p. 2560-6. Exclusion Code: X3.19151384
144 Kulp MT. Findings from the Vision In Preschoolers (VIP) Study. Optom Vis Sci. 2009 Jun;86(6):619-23. doi: 10.1097/OPX.0b013e3181a59bf5. PMID: 19417714. Exclusion Code: X2.19417714
145 Kulp MT, Foster NC, Holmes JM, . Effect of ocular alignment on emmetropization in children <10 years with amblyopia. Am J Ophthalmol. 2012 Aug;154(2):297-302.e1. doi: 10.1016/j.ajo.2012.02.035. PMID: 22633344. Exclusion Code: X5.22633344
146 Kumaran A, Htoon HM, Tan D, . Analysis of Changes in Refraction and Biometry of Atropine- and Placebo-Treated Eyes. Invest Ophthalmol Vis Sci. 2015 Aug;56(9):5650-5. doi: 10.1167/iovs.14-14716. PMID: 26313301. Exclusion Code: X3.26313301
147 Kwon M, Lu ZL, Miller A, . Assessing binocular interaction in amblyopia and its clinical feasibility. PLoS One. 2014;9(6):e100156. doi: 10.1371/journal.pone.0100156. PMID: 24959842. Exclusion Code: X3.24959842
148 Lai XJ, Alexander J, Ho A, . Design and validation of a method for evaluation of interocular interaction. Optom Vis Sci. 2012 Feb;89(2):183-96. doi: 10.1097/OPX.0b013e31823ee04a. PMID: 22157978. Exclusion Code: X3.22157978
149 Lai YH, Tseng HY, Hsu HT, . Uncorrected visual acuity and noncycloplegic autorefraction predict significant refractive errors in Taiwanese preschool children. Ophthalmology. 2013 Feb;120(2):271-6. doi: 10.1016/j.ophtha.2012.08.009. PMID: 23182455. Exclusion Code: X9.23182455
150 Lan W, Zhao F, Li Z, . Validation and cost-effectiveness of a home-based screening system for amblyopia. Ophthalmology. 2012 Jun;119(6):1265-71. doi: 10.1016/j.ophtha.2011.12.027. PMID: 22365057. Exclusion Code: X9.22365057
151 Latorre-Arteaga S, Gil-Gonzalez D, Enciso O, . Reducing visual deficits caused by refractive errors in school and preschool children: results of a pilot school program in the Andean region of Apurimac, Peru. Glob Health Action. 2014;7:22656. doi: 10.3402/gha.v7.22656. PMID: 24560253. Exclusion Code: X5.24560253
152 Lavezzo MM, Sousa RL, Kanamura MS, . [PhotoScreener for preschool children visual screening]. Arq Bras Oftalmol. 2010 Jan-Feb;73(1):52-6. PMID: 20464114. Exclusion Code: X1.20464114
153 Leat SJ. To prescribe or not to prescribe? Guidelines for spectacle prescribing in infants and children. Clin Exp Optom. 2011 Nov;94(6):514-27. doi: 10.1111/j.1444-0938.2011.00600.x. PMID: 21722183. Exclusion Code: X2.21722183
154 Lee SH, Chang JW. The relationship between higher-order aberrations and amblyopia treatment in hyperopic anisometropic amblyopia. Korean J Ophthalmol. 2014 Feb;28(1):66-75. doi: 10.3341/kjo.2014.28.1.66. PMID: 24505201. Exclusion Code: X8.24505201
155 Leon A, Donahue SP, Morrison DG, . The age-dependent effect of anisometropia magnitude on anisometropic amblyopia severity. J AAPOS. 2008 Apr;12(2):150-6. doi: 10.1016/j.jaapos.2007.10.003. PMID: 18155938. Exclusion Code: X8.18155938
156 Leske DA, Holmes JM, Melia BM, . Evaluation of the Intermittent Exotropia Questionnaire using Rasch analysis. JAMA Ophthalmol. 2015 Apr;133(4):461-5. doi: 10.1001/jamaophthalmol.2014.5622. PMID: 25634146. Exclusion Code: X3.25634146
157 Li SL, Reynaud A, Hess RF, . Dichoptic movie viewing treats childhood amblyopia. J AAPOS. 2015 Oct;19(5):401-5. doi: 10.1016/j.jaapos.2015.08.003. PMID: 26486019. Exclusion Code: X5.26486019
158 Lim HT, Chun BY. Comparison of OCT measurements between high myopic and low myopic children. Optom Vis Sci. 2013 Dec;90(12):1473-8. doi: 10.1097/opx.0000000000000086. PMID: 24121408. Exclusion Code: X3.24121408
159 Lira RP, Santo IF, Astur GL, . Refractive error in school children in Campinas, Brazil. Arq Bras Oftalmol. 2014 May-Jun;77(3):203-4. PMID: 25295913. Exclusion Code: X3.25295913
160 Liu XT, Zhang F, Lu F. Evaluation of cycloplegic effectiveness of cyclopentolate and atropine. [Chinese]. Zhonghua Shiyan Yanke Zazhi/Chinese Journal of Experimental Ophthalmology; 2012. p. 353-7. Exclusion Code: X1.
161 Lobanova IV, Leshchenko IA, Markova E, . [Impact of the method choice and the extent of correction on the development of visual evoked potentials in children and adolescents with refractive anomalies]. Vestn Oftalmol. 2013 Jul-Aug;129(4):44-50, 2-3. PMID: 24137982. Exclusion Code: X1.24137982
162 Longmuir S, Pfeifer W, Coussens T, . Usefulness of iris reactivity to light to determine the peak cycloplegia in hyperopic children. Insight. 2012 Winter;37(1):12-4, 30. PMID: 22439352. Exclusion Code: X3.22439352
163 Longmuir SQ, Boese EA, Pfeifer W, . Practical community photoscreening in very young children. Pediatrics. 2013 Mar;131(3):e764-9. doi: 10.1542/peds.2012-1638. PMID: 23400603. Exclusion Code: X8.23400603
164 Longmuir SQ, Pfeifer W, Leon A, . Nine-year results of a volunteer lay network photoscreening program of 147 809 children using a photoscreener in Iowa. Ophthalmology. 2010 Oct;117(10):1869-75. doi: 10.1016/j.ophtha.2010.03.036. PMID: 20656350. Exclusion Code: X5.20656350
165 Longmuir SQ, Pfeifer W, Shah SS, . Validity of a layperson-administered Web-based vision screening test. J AAPOS. 2015 Feb;19(1):29-32. doi: 10.1016/j.jaapos.2014.10.021. PMID: 25727583. Exclusion Code: X4.25727583
166 Loudon SE, Rook CA, Nassif DS, . Rapid, high-accuracy detection of strabismus and amblyopia using the pediatric vision scanner. Invest Ophthalmol Vis Sci. 2011 Jul;52(8):5043-8. doi: 10.1167/iovs.11-7503. PMID: 21642624. Exclusion Code: X3.21642624
167 Lowry EA, Lui R, Enanoria W, . Repeat Retinomax screening changes positive predictive value. J AAPOS. 2014 Feb;18(1):45-9. doi: 10.1016/j.jaapos.2013.11.004. PMID: 24568982. Exclusion Code: X3.24568982
168 Lowry EA, Wang W, Nyong'o O. Objective vision screening in 3-year-old children at a multispecialty practice. J AAPOS. 2015 Feb;19(1):16-20. doi: 10.1016/j.jaapos.2014.09.008. PMID: 25727580. Exclusion Code: X5.25727580
169 Ma DJ, Yang HK, Hwang JM. Reliability and validity of an automated computerized visual acuity and stereoacuity test in children using an interactive video game. Am J Ophthalmol. 2013 Jul;156(1):195-201.e1. doi: 10.1016/j.ajo.2013.02.018. PMID: 23582763. Exclusion Code: X3.23582763
170 Ma X, Congdon N, Yi H, . Safety of Spectacles for Children's Vision: A Cluster-Randomized Controlled Trial. Am J Ophthalmol. 2015 Nov;160(5):897-904. doi: 10.1016/j.ajo.2015.08.013. PMID: 26284747. Exclusion Code: X3.26284747
171 Ma X, Zhou Z, Yi H, . Effect of providing free glasses on children's educational outcomes in China: cluster randomized controlled trial. BMJ. 2014;349:g5740. doi: 10.1136/bmj.g5740. PMID: 25249453. Exclusion Code: X3.25249453
172 Mansouri B, Singh P, Globa A, . Binocular training reduces amblyopic visual acuity impairment. Strabismus. 2014 Mar;22(1):1-6. doi: 10.3109/09273972.2013.877945. PMID: 24564723. Exclusion Code: X3.24564723
173 Mathew JA, Shah SA, Simon JW. Varying difficulty of Snellen letters and common errors in amblyopic and fellow eyes. Arch Ophthalmol. 2011 Feb;129(2):184-7. doi: 10.1001/archophthalmol.2010.369. PMID: 21320964. Exclusion Code: X3.21320964
174 Matta NS, Arnold RW, Singman EL, . Comparison between the plusoptiX and MTI Photoscreeners. Arch Ophthalmol. 2009 Dec;127(12):1591-5. doi: 10.1001/archophthalmol.2009.294. PMID: 20008713. Exclusion Code: X3.20008713
175 Matta NS, Arnold RW, Singman EL, . Can a photoscreener help us remotely evaluate and manage amblyopia? Am Orthopt J. 2011;61:124-7. doi: 10.3368/aoj.61.1.124. PMID: 21856880. Exclusion Code: X3.21856880
176 Matta NS, Singman EL, McCarus C, . Screening for amblyogenic risk factors using the PlusoptiX S04 photoscreener on the indigent population of Honduras. Ophthalmology. 2010 Sep;117(9):1848-50. doi: 10.1016/j.ophtha.2010.01.038. PMID: 20472292. Exclusion Code: X9.20472292
177 Matta NS, Singman EL, Silbert DI. Performance of the plusoptiX S04 photoscreener for the detection of amblyopia risk factors in children aged 3 to 5. J AAPOS. 2010 Apr;14(2):147-9. doi: 10.1016/j.jaapos.2010.01.006. PMID: 20451857. Exclusion Code: X3.20451857
178 McCullough SJ, Little JA, Breslin KM, . Comparison of refractive error measures by the IRX3 aberrometer and autorefraction. Optom Vis Sci. 2014 Oct;91(10):1183-90. doi: 10.1097/opx.0000000000000379. PMID: 25192432. Exclusion Code: X3.25192432
179 McCurry TC, Lawrence LM, Wilson ME, . The plusoptiX S08 photoscreener as a vision screening tool for children with autism. J AAPOS. 2013 Aug;17(4):374-7. doi: 10.1016/j.jaapos.2013.05.006. PMID: 23928004. Exclusion Code: X3.23928004
180 McGlone L, Hamilton R, McCulloch DL, . Visual outcome in infants born to drug-misusing mothers prescribed methadone in pregnancy. Br J Ophthalmol. 2014 Feb;98(2):238-45. doi: 10.1136/bjophthalmol-2013-303967. PMID: 24246372. Exclusion Code: X3.24246372
181 Melia BM, Holmes JM, Chandler DL, . Classifying stability of misalignment in children with esotropia using simulations. Arch Ophthalmol. 2010 Dec;128(12):1555-60. doi: 10.1001/archophthalmol.2010.293. PMID: 21149779. Exclusion Code: X8.21149779
182 Meyer-Rusenberg B, Thill M, Vujancevic S, . Conservative management of bilateral persistent pupillary membranes with 18 years of follow-up. Graefes Arch Clin Exp Ophthalmol. 2010 Jul;248(7):1053-4. doi: 10.1007/s00417-010-1318-9. PMID: 20182884. Exclusion Code: X8.20182884
183 Mirzajani A, Heirani M, Jafarzadehpur E, . A comparison of the Plusoptix S08 photorefractor to retinoscopy and cycloretinoscopy. Clin Exp Optom. 2013 Jul;96(4):394-9. doi: 10.1111/cxo.12063. PMID: 23679982. Exclusion Code: X6.23679982
184 Moghaddam AA, Kargozar A, Zarei-Ghanavati M, . Screening for amblyopia risk factors in pre-verbal children using the Plusoptix photoscreener: a cross-sectional population-based study. Br J Ophthalmol. 2012 Jan;96(1):83-6. doi: 10.1136/bjo.2010.190405. PMID: 21515564. Exclusion Code: X8.21515564
185 Moguel-Ancheita S, Ramirez-Sibaja S, Reyes-Pantoja SA, . Visuomotor functions and intelligence subsequent to strabismus treatment. Second phase. Cir Cir. 2010 Nov-Dec;78(6):468-72. PMID: 21214981. Exclusion Code: X1.21214981
186 Mohan K, Sharma A. Long-term treatment results of accommodative esotropia. J AAPOS. 2014 Jun;18(3):261-5. doi: 10.1016/j.jaapos.2014.01.018. PMID: 24924281. Exclusion Code: X8.24924281
187 Mohney BG, Cotter SA, Chandler DL, . A Randomized Trial Comparing Part-time Patching with Observation for Intermittent Exotropia in Children 12 to 35 Months of Age. Ophthalmology. 2015 Aug;122(8):1718-25. doi: 10.1016/j.ophtha.2015.04.025. PMID: 26072346. Exclusion Code: X6.26072346
188 Moll AM, Rao RC, Rotberg LB, . The role of the random dot Stereo Butterfly test as an adjunct test for the detection of constant strabismus in vision screening. J AAPOS. 2009 Aug;13(4):354-6. doi: 10.1016/j.jaapos.2009.03.008. PMID: 19482495. Exclusion Code: X3.19482495
189 Molteno AC, Hoare-Nairne J, Sanderson GF, . Reliability of the Otago photoscreener. A study of a thousand cases. Aust N Z J Ophthalmol. 1993 Nov;21(4):257-65. PMID: 8148143. Exclusion Code: X10.8148143
190 Moseley MJ, Wallace MP, Stephens DA, . Personalized versus standardized dosing strategies for the treatment of childhood amblyopia: study protocol for a randomized controlled trial. Trials. 2015;16:189. doi: 10.1186/s13063-015-0711-4. PMID: 25906974. Exclusion Code: X5.25906974
191 Mu Y, Bi H, Ekure E, . Performance of Spot Photoscreener in Detecting Amblyopia Risk Factors in Chinese Pre-school and School Age Children Attending an Eye Clinic. PLoS One. 2016;11(2):e0149561. doi: 10.1371/journal.pone.0149561. PMID: 26882106. Exclusion Code: X3.26882106
192 Nathan NR, Donahue SP. Modification of Plusoptix referral criteria to enhance sensitivity and specificity during pediatric vision screening. J AAPOS. 2011 Dec;15(6):551-5. doi: 10.1016/j.jaapos.2011.08.008. PMID: 22153399. Exclusion Code: X3.22153399
193 Newman DK, East MM. Preschool vision screening: negative predictive value for amblyopia. Br J Ophthalmol. 1999 Jun;83(6):676-9. PMID: 10340974. Exclusion Code: X5.10340974
194 Norgett Y, Siderov J. Crowding in children's visual acuity tests--effect of test design and age. Optom Vis Sci. 2011 Aug;88(8):920-7. doi: 10.1097/OPX.0b013e31821bd2d3. PMID: 21532515. Exclusion Code: X5.21532515
195 Nottingham University Hospitals NHST, Wellcome T. I-BiT - Evaluation of a Novel Binocular Treatment System (I-BiTTM) in Children With Amblyopia. 2013. Exclusion Code: X6.
196 Omar R, Hussin DA, Knight VF. Comparison of LEA Symbols chart and Sheridan Gardiner chart in assessing vision screening among pre-school children: a Malaysia perspective. J Med Assoc Thai. 2012 Mar;95(3):412-7. PMID: 22550841. Exclusion Code: X5.22550841
197 Oral Y, Gunaydin N, Ozgur O, . A comparison of different autorefractors with retinoscopy in children. J Pediatr Ophthalmol Strabismus. 2012 Nov-Dec;49(6):370-7. doi: 10.3928/01913913-20120821-04. PMID: 22938517. Exclusion Code: X3.22938517
198 Ore L, Garozli HJ, Schwartz N, . Factors influencing prevalence of vision and ocular abnormalities among Jewish and Arab Israeli schoolchildren. Isr Med Assoc J. 2014 Sep;16(9):553-8. PMID: 25351012. Exclusion Code: X3.25351012
199 Orssaud C. [Amblyopia]. J Fr Ophtalmol. 2014 Jun;37(6):486-96. doi: 10.1016/j.jfo.2014.01.004. PMID: 24703193. Exclusion Code: X1.24703193
200 Ospina LH. Cortical visual impairment. Pediatr Rev. 2009 Nov;30(11):e81-90. doi: 10.1542/pir.30-11-e81. PMID: 19884281. Exclusion Code: X2.19884281
201 OstadiMoghaddam H, Fotouhi A, Hashemi H, . Validity of vision screening tests by teachers among school children in Mashhad, Iran. Ophthalmic Epidemiol. 2012 Jun;19(3):166-71. doi: 10.3109/09286586.2011.602503. PMID: 22568430. Exclusion Code: X3.22568430
202 Ostadimoghaddam H, Fotouhi A, Hashemi H, . The prevalence of anisometropia in population base study. Strabismus. 2012 Dec;20(4):152-7. doi: 10.3109/09273972.2012.680229. PMID: 23211139. Exclusion Code: X3.23211139
203 Ostendorf GM. [Vision screening of children: rational and cost effective]. Versicherungsmedizin. 2013 Dec 1;65(4):207. PMID: 24404617. Exclusion Code: X1.24404617
204 Ostrow G, Friedlaender D. Amblyopia: current evidence-based therapeutic options. Int Ophthalmol Clin. 2014 Summer;54(3):33-40. doi: 10.1097/iio.0000000000000032. PMID: 24879102. Exclusion Code: X2.24879102
205 Paff T, Oudesluys-Murphy AM, Wolterbeek R, . Screening for refractive errors in children: the plusoptiX S08 and the Retinomax K-plus2 performed by a lay screener compared to cycloplegic retinoscopy. J AAPOS. 2010 Dec;14(6):478-83. doi: 10.1016/j.jaapos.2010.09.015. PMID: 21168070. Exclusion Code: X3.21168070
206 Pai A, Samarawickrama C, Burlutsky G, . Refractive error in preschool children. Ophthalmology. 2010 Jun;117(6):1278-9. doi: 10.1016/j.ophtha.2010.01.014. PMID: 20522341. Exclusion Code: X2.20522341
207 Pang Y, Allison C, Frantz KA, . A prospective pilot study of treatment outcomes for amblyopia associated with myopic anisometropia. Arch Ophthalmol. 2012 May;130(5):579-84. doi: 10.1001/archopthalmol.2011.1203. PMID: 22232365. Exclusion Code: X8.22232365
208 Pant M, Shrestha GS, Joshi ND. Ocular morbidity among street children in Kathmandu Valley. Ophthalmic Epidemiol. 2014 Dec;21(6):356-61. doi: 10.3109/09286586.2014.964035. PMID: 25228043. Exclusion Code: X3.25228043
209 Park KA, Oh SY. The effect of reducing hyperopic correction in patients with accommodative esotropia. J AAPOS. 2013 Aug;17(4):363-6. doi: 10.1016/j.jaapos.2013.03.027. PMID: 23993716. Exclusion Code: X5.23993716
210 Pärssinen O, Kauppinen M, Viljanen A. Astigmatism among myopics and its changes from childhood to adult age: a 23-year follow-up study. Acta Ophthalmol (Copenh); 2015. p. 276-83. Exclusion Code: X3.
211 Pascual M, Huang J, Maguire MG, . Risk factors for amblyopia in the Vision In Preschoolers study. Ophthalmology. 2014 Mar;121(3):622-9.e1. doi: 10.1016/j.ophtha.2013.08.040. PMID: 24140117. Exclusion Code: X5.24140117
212 Pawar PV, Mumbare SS, Patil MS, . Effectiveness of the addition of citicoline to patching in the treatment of amblyopia around visual maturity: a randomized controlled trial. Indian J Ophthalmol. 2014 Feb;62(2):124-9. doi: 10.4103/0301-4738.128586. PMID: 24618483. Exclusion Code: X4.24618483
213 Payerols A, Eliaou C, Trezeguet V, . Accuracy of PlusOptix A09 distance refraction in pediatric myopia and hyperopia. BMC Ophthalmol. 2016;16:72. doi: 10.1186/s12886-016-0247-8. PMID: 27246869. Exclusion Code: X3.27246869
214 Pechereau A, Paire V, Raffin L, . [Amblyopia treatment of unilateral and bilateral cataract with visual acuity result]. J Fr Ophtalmol. 2011 Mar;34(3):208-12. doi: 10.1016/j.jfo.2011.01.009. PMID: 21377759. Exclusion Code: X1.21377759
215 Pediatric Eye Disease Investigator Group. A randomized trial of atropine vs. patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2002 Mar;120(3):268-78. PMID: 11879129. Exclusion Code: X5.11879129
216 Pediatric Eye Disease Investigator Group. Pharmacological plus optical penalization treatment for amblyopia: results of a randomized trial. Arch Ophthalmol. 2009 Jan;127(1):22-30. doi: 10.1001/archophthalmol.2008.520. PMID: 19139333. Exclusion Code: X5.19139333
217 Pediatric Eye Disease Investigator Group, Mohney BG, Cotter SA, . A randomized trial comparing part-time patching with observation for intermittent exotropia in children 12 to 35 months of age. Ophthalmology. 2015 Aug;122(8):1718-25. doi: 10.1016/j.ophtha.2015.04.025. PMID: 26072346. Exclusion Code: X6.26072346
218 Peng MY, Matta N, Silbert D, . Accuracy of the Retinomax K-plus3 in measuring refractive error in a pediatric population. J AAPOS. 2014 Aug;18(4):327-31. doi: 10.1016/j.jaapos.2014.02.017. PMID: 25173893. Exclusion Code: X6.25173893
219 Pescosolido N, Stefanucci A, Buomprisco G, . Amblyopia treatment strategies and new drug therapies. J Pediatr Ophthalmol Strabismus. 2014 Mar-Apr;51(2):78-86. doi: 10.3928/01913913-20130107-01. PMID: 24410693. Exclusion Code: X2.24410693
220 Peterseim MM, Papa CE, Parades C, . Combining automated vision screening with on-site examinations in 23 schools: ReFocus on Children Program 2012 to 2013. J Pediatr Ophthalmol Strabismus. 2015 Jan-Feb;52(1):20-4. doi: 10.3928/01913913-20141124-01. PMID: 25427341. Exclusion Code: X5.25427341
221 Peterseim MM, Papa CE, Wilson ME, . Photoscreeners in the pediatric eye office: compared testability and refractions on high-risk children. Am J Ophthalmol. 2014 Nov;158(5):932-8. doi: 10.1016/j.ajo.2014.07.041. PMID: 25089352. Exclusion Code: X3.25089352
222 Peterseim MM, Papa CE, Wilson ME, . The effectiveness of the Spot Vision Screener in detecting amblyopia risk factors. J AAPOS. 2014 Dec;18(6):539-42. doi: 10.1016/j.jaapos.2014.07.176. PMID: 25498463. Exclusion Code: X3.25498463
223 Polat U, Ma-Naim T, Spierer A. Treatment of children with amblyopia by perceptual learning. Vision Res. 2009 Oct;49(21):2599-603. doi: 10.1016/j.visres.2009.07.008. PMID: 19622368. Exclusion Code: X3.19622368
224 Polling JR, Loudon SE, Klaver CC. Prevalence of amblyopia and refractive errors in an unscreened population of children. Optom Vis Sci. 2012 Nov;89(11):e44-9. doi: 10.1097/OPX.0b013e31826ae047. PMID: 23069721. Exclusion Code: X5.23069721
225 Prabakaran S, Dirani M, Chia A, . Cycloplegic refraction in preschool children: comparisons between the hand-held autorefractor, table-mounted autorefractor and retinoscopy. Ophthalmic Physiol Opt. 2009 Jul;29(4):422-6. doi: 10.1111/j.1475-1313.2008.00616.x. PMID: 19523087. Exclusion Code: X6.19523087
226 Premsenthil M, Manju R, Thanaraj A, . The screening of visual impairment among preschool children in an urban population in Malaysia; the Kuching pediatric eye study: a cross sectional study. BMC Ophthalmol. 2013;13:16. doi: 10.1186/1471-2415-13-16. PMID: 23601160. Exclusion Code: X5.23601160
227 Pritchard C, Ellis GS, Jr. Efficacy of modified cover testing for detection of incipient true strabismus with pseudostrabismus diagnosis. Am Orthopt J. 2013;63:73-9. doi: 10.3368/aoj.63.1.73. PMID: 24141755. Exclusion Code: X3.24141755
228 Rah MJ, Walline JJ, Jones-Jordan LA, . Vision specific quality of life of pediatric contact lens wearers. Optom Vis Sci. 2010 Aug;87(8):560-6. doi: 10.1097/OPX.0b013e3181e6a1c8. PMID: 20562669. Exclusion Code: X3.20562669
229 Rahi JS, Cumberland PM, Peckham CS. Improving detection of blindness in childhood: the British Childhood Vision Impairment study. Pediatrics. 2010 Oct;126(4):e895-903. doi: 10.1542/peds.2010-0498. PMID: 20855395. Exclusion Code: X4.20855395
230 Rajavi Z, Parsafar H, Ramezani A, . Is noncycloplegic photorefraction applicable for screening refractive amblyopia risk factors? J Ophthalmic Vis Res. 2012 Jan;7(1):3-9. PMID: 22737380. Exclusion Code: X9.22737380
231 Ransbarger KM, Dunbar JA, Choi SE, . Results of a community vision-screening program using the Spot photoscreener. J AAPOS. 2013 Oct;17(5):516-20. doi: 10.1016/j.jaapos.2013.06.013. PMID: 24160974. Exclusion Code: X5.24160974
232 Rebiscan I, Retina Foundation of the S. Amblyopia and Strabismus Detection Using a Pediatric Vision Scanner. 2012. Exclusion Code: X6.
233 Rebiscan I, University of Southern C. Amblyopia and Strabismus Detection Using a Pediatric Vision Scanner. 2011. Exclusion Code: X6.
234 Rebiscan I, Vanderbilt U. Amblyopia and Strabismus Detection Using a Pediatric Vision Scanner. 2012. Exclusion Code: X6.
235 Repka MX, Beck RW, Holmes JM, . A randomized trial of patching regimens for treatment of moderate amblyopia in children. Arch Ophthalmol. 2003;121(5):603-11. doi: 10.1001/archopht.121.5.603. PMID: CN-00437330. Exclusion Code: X5.12742836
236 Repka MX, Cotter SA, Beck RW, . A randomized trial of atropine regimens for treatment of moderate amblyopia in children. Ophthalmology; 2004. p. 2076-85. Exclusion Code: X5.15522375
237 Repka MX, Holmes JM. Lessons from the amblyopia treatment studies. Ophthalmology. 2012 Apr;119(4):657-8. doi: 10.1016/j.ophtha.2011.12.003. PMID: 22472249. Exclusion Code: X2.22472249
238 Repka MX, Kraker RT, Beck RW, . Treatment of severe amblyopia with weekend atropine: results from 2 randomized clinical trials. J AAPOS. 2009 Jun;13(3):258-63. doi: 10.1016/j.jaapos.2009.03.002. PMID: 19541265. Exclusion Code: X5.19541265
239 Repka MX, Kraker RT, Beck RW, . Contrast sensitivity following amblyopia treatment in children. Arch Ophthalmol. 2009 Sep;127(9):1225-7. doi: 10.1001/archophthalmol.2009.219. PMID: 19752439. Exclusion Code: X5.19752439
240 Repka MX, Kraker RT, Holmes JM, . Atropine vs patching for treatment of moderate amblyopia: follow-up at 15 years of age of a randomized clinical trial. JAMA Ophthalmol. 2014 Jul;132(7):799-805. doi: 10.1001/jamaophthalmol.2014.392. PMID: 24789375. Exclusion Code: X5.24789375
241 Repka MX, Wallace DK, Beck RW, . Two-year follow-up of a 6-month randomized trial of atropine vs patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2005;123(2):149-57. doi: 10.1001/archopht.123.2.149. PMID: CN-00504898. Exclusion Code: X5.15710809
242 Rogers GL, Jordan CO. Pediatric vision screening. Pediatr Rev. 2013 Mar;34(3):126-32; quiz 33. doi: 10.1542/pir.34-3-126. PMID: 23457199. Exclusion Code: X2.23457199
243 Rohrschneider K, Brill B, Bayer Y, . [Dice test--a simple method for assessment of visual acuity in infants with visual deficits]. Ophthalmologe. 2010 Jul;107(7):641-6. doi: 10.1007/s00347-009-2095-x. PMID: 20354703. Exclusion Code: X1.20354703
244 Rosen RC, Schiffman HR, Meyers H. Behavioral treatment of myopia: refractive error and acuity changes in relation to axial length and intraocular pressure. Am J Optom Physiol Opt. 1984 Feb;61(2):100-5. PMID: 6703003. Exclusion Code: X3.6703003
245 Rossi LD, Vasconcelos GC, Saliba GR, . [Functional vision assessment in children with low vision from two to six years of age - a comparative study]. Arq Bras Oftalmol. 2011 Jul-Aug;74(4):262-6. PMID: 22068853. Exclusion Code: X1.22068853
246 Rossi LD, Vasconcelos GC, Saliba GR, . [Reliability of functional vision assessment in children with low vision from 2 to 6 years old--searching for evidences]. Arq Bras Oftalmol. 2012 Jul-Aug;75(4):259-63. PMID: 23258657. Exclusion Code: X1.23258657
247 Rupolo G, Angi M, Sabbadin E, . Treating myopia with acoustic biofeedback: a prospective study on the evolution of visual acuity and psychological distress. Psychosom Med. 1997 May-Jun;59(3):313-7. PMID: 9178342. Exclusion Code: X4.9178342
248 Rustagi N, Uppal Y, Taneja DK. Screening for visual impairment: outcome among schoolchildren in a rural area of Delhi. Indian J Ophthalmol. 2012 May-Jun;60(3):203-6. doi: 10.4103/0301-4738.95872. PMID: 22569381. Exclusion Code: X3.22569381
249 Rutstein RP, Quinn GE, Lazar EL, . A randomized trial comparing Bangerter filters and patching for the treatment of moderate amblyopia in children. Ophthalmology. 2010 May;117(5):998-1004.e6. doi: 10.1016/j.ophtha.2009.10.014. PMID: 20163869. Exclusion Code: X5.20163869
250 Saber Moghadam A, Alizadeh R, Zarei-Ghanavati M. Plusoptix S08 sensitivity in detecting strabismus as amblyogenic risk factor. Strabismus. 2013 Dec;21(4):230-4. doi: 10.3109/09273972.2013.851259. PMID: 24299331. Exclusion Code: X3.24299331
251 Saffra NA, Desai RU, Har-Zvi N. Preschool amblyopia screening. Ophthalmology. 2011 Jun;118(6):1222-3. doi: 10.1016/j.ophtha.2011.01.048. PMID: 21640269. Exclusion Code: X5.21640269
252 Salcido AA, Bradley J, Donahue SP. Predictive value of photoscreening and traditional screening of preschool children. J AAPOS. 2005 Apr;9(2):114-20. doi: 10.1016/j.jaapos.2003.10.011. PMID: 15838437. Exclusion Code: X5.15838437
253 Satiani NG, Mutti DO. Screening for hyperopia in infants using the PowerRefractor. Optom Vis Sci. 2011 Aug;88(8):905-11. doi: 10.1097/OPX.0b013e3182206df2. PMID: 21602730. Exclusion Code: X3.21602730
254 Schlenker MB, Christakis TJ, Braga-Mele RM. Comparing a traditional single optotype visual acuity test with a computer-based visual acuity test for childhood amblyopia vision screening: a pilot study. Can J Ophthalmol. 2010 Aug;45(4):368-74. doi: 10.3129/i10-034. PMID: 20648081. Exclusion Code: X5.20648081
255 Schmid GF. Association between retinal steepness and central myopic shift in children. Optom Vis Sci. 2011 Jun;88(6):684-90. doi: 10.1097/OPX.0b013e3182152646. PMID: 21423064. Exclusion Code: X3.21423064
256 Schmidt-Bacher AE, Kahlert C, Kolling G. [Accuracy of two autorefractors--Pediatric Autorefractor plusoptiX and Retinomax--in cycloplegic children in comparison to retinoscopy]. Klin Monbl Augenheilkd. 2010 Oct;227(10):792-7. doi: 10.1055/s-0029-1245734. PMID: 20963682. Exclusion Code: X1.20963682
257 Sethi HS, Saxena R, Sharma P, . Home exercises for convergence insufficiency in children. Arch Ophthalmol. 2006 Feb;124(2):287. doi: 10.1001/archopht.124.2.287-a. PMID: 16476908. Exclusion Code: X8.16476908
258 Shah N, Laidlaw DA, Rashid S, . Validation of printed and computerised crowded Kay picture logMAR tests against gold standard ETDRS acuity test chart measurements in adult and amblyopic paediatric subjects. Eye (Lond). 2012 Apr;26(4):593-600. doi: 10.1038/eye.2011.333. PMID: 22193878. Exclusion Code: X3.22193878
259 Shahid Beheshti Medical U. Is Non-cycloplegic Photorefraction Applicable for Screening Refractive Risk Factors of Amblyopia? Exclusion Code: X6.
260 Shin YJ, Lee IB, Wee WR, . A novel computerized visual acuity test for children. Korean J Ophthalmol. 2013 Jun;27(3):194-8. doi: 10.3341/kjo.2013.27.3.194. PMID: 23730112. Exclusion Code: X5.23730112
261 Silbert D, Matta N, Tian J, . Comparing the SureSight autorefractor and the plusoptiX photoscreener for pediatric vision screening. Strabismus. 2014 Jun;22(2):64-7. doi: 10.3109/09273972.2014.904896. PMID: 24738949. Exclusion Code: X3.24738949
262 Silbert DI, Arnold RW, Matta NS. Comparison of the iScreen and the MTI photoscreeners for the detection of amblyopia risk factors in children. J AAPOS. 2013 Feb;17(1):34-7. doi: 10.1016/j.jaapos.2012.09.015. PMID: 23415034. Exclusion Code: X3.23415034
263 Silbert DI, Matta NS. Performance of the Spot vision screener for the detection of amblyopia risk factors in children. J AAPOS. 2014 Apr;18(2):169-72. doi: 10.1016/j.jaapos.2013.11.019. PMID: 24698615. Exclusion Code: X3.24698615
264 Silbert DI, Matta NS, Andersen K. Plusoptix photoscreening may replace cycloplegic examination in select pediatric ophthalmology patients. J AAPOS. 2013 Apr;17(2):163-5. doi: 10.1016/j.jaapos.2012.11.008. PMID: 23522941. Exclusion Code: X6.23522941
265 Silbert DI, Matta NS, Brubaker A. Flip chart Visual Acuity Screening for Amblyopia Risk Factors Compared to the PlusoptiX A09 Photoscreener,Tests Performed by a Lay Screener. Binocul Vis Strabolog Q Simms Romano. 2013;28(4):222-8. PMID: 24372416. Exclusion Code: X3.24372416
266 Silbert DI, Matta NS, Burkholder D, . Clinical accuracy of the AAPOS pediatric vision screening referral criteria. J AAPOS. 2012 Aug;16(4):361-4. doi: 10.1016/j.jaapos.2012.02.016. PMID: 22824492. Exclusion Code: X4.22824492
267 Silbert DI, Matta NS, Ely AL. Comparison of SureSight autorefractor and plusoptiX A09 photoscreener for vision screening in rural Honduras. J AAPOS. 2014 Feb;18(1):42-4. doi: 10.1016/j.jaapos.2013.09.006. PMID: 24568981. Exclusion Code: X3.24568981
268 Silva AM, Matos MH, Lima Hde C. [Low vision service at the Instituto Brasileiro de Oftalmologia e Prevencao da Cegueira (IBOPC): analysis of the patients examined on the first year of the department (2004)]. Arq Bras Oftalmol. 2010 May-Jun;73(3):266-70. PMID: 20730285. Exclusion Code: X1.20730285
269 Silverstein E, Lorenz S, Emmons K, . Limits on improving the positive predictive value of the Welch Allyn SureSight for preschool vision screening. J AAPOS. 2009 Feb;13(1):45-50. doi: 10.1016/j.jaapos.2008.08.011. PMID: 18976944. Exclusion Code: X8.18976944
270 Simon JW, Baxi H. Atropine penalization for “rescuing” patching failures. Arch Ophthalmol. 2009 Feb;127(2):220-1. doi: 10.1001/archophthalmol.2008.560. PMID: 19204246. Exclusion Code: X8.19204246
271 Singman E, Matta N, Tian J, . A comparison of the PlusoptiX S04 and A09 photoscreeners. Strabismus. 2013 Jun;21(2):85-7. doi: 10.3109/09273972.2013.786735. PMID: 23713927. Exclusion Code: X10.23713927
272 Singman E, Matta N, Tian J, . A comparison of referral criteria used by the plusoptiX photoscreener. Strabismus. 2013 Sep;21(3):190-4. doi: 10.3109/09273972.2013.811606. PMID: 23978147. Exclusion Code: X3.23978147
273 Singman E, Matta N, Tian J, . The accuracy of the plusoptiX for measuring pupillary distance. Strabismus. 2014 Mar;22(1):21-5. doi: 10.3109/09273972.2013.877941. PMID: 24564725. Exclusion Code: X4.24564725
274 Sloot F, Sami A, Karaman H, . Effect of omission of population-based eye screening at age 6-9 months in the Netherlands. Acta Ophthalmol. 2015 Jun;93(4):318-21. doi: 10.1111/aos.12556. PMID: 25270899. Exclusion Code: X6.25270899
275 Solebo AL, Cumberland PM, Rahi JS. Whole-population vision screening in children aged 4-5 years to detect amblyopia. Lancet. 2015 Jun 6;385(9984):2308-19. doi: 10.1016/s0140-6736(14)60522-5. PMID: 25499167. Exclusion Code: X8.25499167
276 Somer D, Karabulut E, Cinar FG, . Emmetropization, visual acuity, and strabismus outcomes among hyperopic infants followed with partial hyperopic corrections given in accordance with dynamic retinoscopy. Eye (Lond). 2014 Oct;28(10):1165-73. doi: 10.1038/eye.2014.161. PMID: 25033902. Exclusion Code: X8.25033902
277 Steffen H. [Nonparetic strabismus. 1]. Klin Monbl Augenheilkd. 2012 Nov;229(11):1145-53; quiz 54-5. doi: 10.1055/s-0032-1324858. PMID: 23172623. Exclusion Code: X1.23172623
278 Stewart CE, Stephens DA, Fielder AR, . Objectively monitored patching regimens for treatment of amblyopia: randomised trial. BMJ (Clinical research ed.). 2007;335(7622):707. doi: 10.1136/bmj.39301.460150.55. PMID: CN-00612053. Exclusion Code: X5.
279 Stewart CE, Wallace MP, Stephens DA, . The effect of amblyopia treatment on stereoacuity. J AAPOS. 2013 Apr;17(2):166-73. doi: 10.1016/j.jaapos.2012.10.021. PMID: 23622448. Exclusion Code: X5.23622448
280 Strauss RW, Ehrt O. [Detection of amlyogenic risk factors with the vision screener S 04]. Klin Monbl Augenheilkd. 2010 Oct;227(10):798-803. doi: 10.1055/s-0029-1245784. PMID: 20963683. Exclusion Code: X1.20963683
281 Sturm V. [The lazy eye - contemporary strategies of amblyopia treatment]. Praxis (Bern 1994). 2011 Feb 16;100(4):229-35. doi: 10.1024/1661-8157/a00442. PMID: 21328237. Exclusion Code: X1.21328237
282 Subramanian V, Morale SE, Wang YZ, . Abnormal radial deformation hyperacuity in children with strabismic amblyopia. Invest Ophthalmol Vis Sci. 2012 Jun;53(7):3303-8. doi: 10.1167/iovs.11-8774. PMID: 22531696. Exclusion Code: X4.22531696
283 Sudhan A, Pandey A, Pandey S, . Effectiveness of using teachers to screen eyes of school-going children in Satna district of Madhya Pradesh, India. Indian J Ophthalmol. 2009 Nov-Dec;57(6):455-8. doi: 10.4103/0301-4738.57157. PMID: 19861748. Exclusion Code: X3.19861748
284 Sujuan JL, Handa S, Perera C, . The psychological impact of eyedrops administration in children. J AAPOS. 2015 Aug;19(4):338-43. doi: 10.1016/j.jaapos.2015.05.010. PMID: 26296784. Exclusion Code: X4.26296784
285 Tailor V, Balduzzi S, Hull S, . Tests for detecting strabismus in children age 1 to 6 years in the community. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X2.
286 Tang WC, Tang YY, Lam CS. How representative is the ‘Representative Value’ of refraction provided by the Shin-Nippon NVision-K 5001 autorefractor? Ophthalmic Physiol Opt. 2014 Jan;34(1):89-93. doi: 10.1111/opo.12098. PMID: 24325438. Exclusion Code: X3.24325438
287 Tarczy-Hornoch K, Cotter SA, Borchert M, . Prevalence and causes of visual impairment in Asian and non-Hispanic white preschool children: multi-ethnic pediatric eye disease study. Ophthalmology. 2013 Jun;120(6):1220-6. doi: 10.1016/j.ophtha.2012.12.029. PMID: 23561327. Exclusion Code: X6.23561327
288 The Hospital for Sick C. Vision Care for Children in Ontario. 2015. Exclusion Code: X6.
289 Tjiam AM, Holtslag G, Van Minderhout HM, . Randomised comparison of three tools for improving compliance with occlusion therapy: an educational cartoon story, a reward calendar, and an information leaflet for parents. Graefes Arch Clin Exp Ophthalmol. 2013 Jan;251(1):321-9. doi: 10.1007/s00417-012-2107-4. PMID: 22820813. Exclusion Code: X5.22820813
290 Toner KN, Lynn MJ, Candy TR, . The Handy Eye Check: a mobile medical application to test visual acuity in children. J AAPOS. 2014 Jun;18(3):258-60. doi: 10.1016/j.jaapos.2014.01.011. PMID: 24924280. Exclusion Code: X3.24924280
291 Tong DTY. Treatment of intermittent esotropia incorporating peripheral awareness training. J Behav Optom. 1999;10:128-31. Exclusion Code: X8.
292 Trivedi RH, Wilson ME, Peterseim MM, . A pilot study evaluating the use of EyeSpy video game software to perform vision screening in school-aged children. J AAPOS. 2010 Aug;14(4):311-6. doi: 10.1016/j.jaapos.2010.03.008. PMID: 20637666. Exclusion Code: X3.20637666
293 Tsai IL, Tsai CY, Kuo LL, . Transient changes of intraocular pressure and anterior segment configuration after diagnostic mydriasis with 1% tropicamide in children. Clin Exp Optom. 2012 Mar;95(2):166-72. doi: 10.1111/j.1444-0938.2011.00677.x. PMID: 22077324. Exclusion Code: X3.22077324
294 Tsybul'ska T. [Possible functional treatment of myopia in children]. Wiad Lek. 2014;67(2 Pt 2):384-6. PMID: 25796878. Exclusion Code: X1.25796878
295 Ugurbas SC, Alpay A, Tutar H, . Validation of plusoptiX S04 photoscreener as a vision screening tool in children with intellectual disability. J AAPOS. 2011 Oct;15(5):476-9. doi: 10.1016/j.jaapos.2011.05.023. PMID: 22108360. Exclusion Code: X3.22108360
296 University of B, Nijmegen Medical C. AMblyopia Treatment Through PErceptual Training in Children (AMPEL). 2018. Exclusion Code: X6.
297 Uphoff R. [U1, U2, U3… - the importance of routine]. Kinderkrankenschwester. 2014 Sep;33(9):356-8. PMID: 25291845. Exclusion Code: X1.25291845
298 Varma R, McKean-Cowdin R, Vitale S, . Vision assessment using the NIH Toolbox. Neurology. 2013 Mar 12;80(11 Suppl 3):S37-40. doi: 10.1212/WNL.0b013e3182876e0a. PMID: 23479542. Exclusion Code: X6.23479542
299 Wallace DK, Kraker RT, Beck RW, . Randomized trial to evaluate combined patching and atropine for residual amblyopia. Arch Ophthalmol. 2011 Jul;129(7):960-2. doi: 10.1001/archophthalmol.2011.174. PMID: 21746992. Exclusion Code: X5.21746992
300 Wallace DK, Lazar EL, Crouch ER, 3rd, . Time course and predictors of amblyopia improvement with 2 hours of daily patching. JAMA Ophthalmol. 2015 May;133(5):606-9. doi: 10.1001/jamaophthalmol.2015.6. PMID: 25695355. Exclusion Code: X5.25695355
301 Wallace DK, Lazar EL, Holmes JM, . A randomized trial of increasing patching for amblyopia. Ophthalmology. 2013 Nov;120(11):2270-7. doi: 10.1016/j.ophtha.2013.04.008. PMID: 23755872. Exclusion Code: X5.23755872
302 Wallace DK, Lazar EL, Melia M, . Stereoacuity in children with anisometropic amblyopia. J AAPOS. 2011 Oct;15(5):455-61. doi: 10.1016/j.jaapos.2011.06.007. PMID: 22108357. Exclusion Code: X6.22108357
303 Wallace DK, Lazar EL, Repka MX, . A randomized trial of adding a plano lens to atropine for amblyopia. J AAPOS. 2015 Feb;19(1):42-8. doi: 10.1016/j.jaapos.2014.10.022. PMID: 25727586. Exclusion Code: X4.25727586
304 Walsh LA, Hahn EK, LaRoche GR. The method of treatment cessation and recurrence rate of amblyopia. Strabismus. 2009 Sep;17(3):107-16. doi: 10.1080/09273970903126709. PMID: 20804358. Exclusion Code: X5.20804358
305 Wang J, Hatt SR, O'Connor AR, . Final version of the Distance Randot Stereotest: normative data, reliability, and validity. J AAPOS. 2010 Apr;14(2):142-6. doi: 10.1016/j.jaapos.2009.12.159. PMID: 20199880. Exclusion Code: X3.20199880
306 Wang XM, Ma LX, Wang LH. [Research of cyclopentolate 1% on the effect of cycloplegia for Chinese hyperopic children]. Zhonghua Yan Ke Za Zhi. 2011 Nov;47(11):989-94. PMID: 22336064. Exclusion Code: X1.22336064
307 Wu J, Nazemi F, Schofield J, . Effectiveness of telescopic magnification in the treatment of amblyopia: a pilot study. Arch Ophthalmol. 2010 Mar;128(3):297-302. doi: 10.1001/archophthalmol.2009.400. PMID: 20212198. Exclusion Code: X5.20212198
308 Wu L, Zhang GL, Yang YX. [Clinical study on electrical plum-blossom needle for treatment of amblyopia in children]. Zhongguo Zhong Xi Yi Jie He Za Zhi. 2011 Mar;31(3):342-5. PMID: 21485075. Exclusion Code: X1.21485075
309 Wu PC, Yang YH, Fang PC. The long-term results of using low-concentration atropine eye drops for controlling myopia progression in schoolchildren. J Ocul Pharmacol Ther. 2011 Oct;27(5):461-6. doi: 10.1089/jop.2011.0027. PMID: 21815829. Exclusion Code: X3.21815829
310 Xie JZ, Tarczy-Hornoch K, Lin J, . Color vision deficiency in preschool children: the multi-ethnic pediatric eye disease study. Ophthalmology. 2014 Jul;121(7):1469-74. doi: 10.1016/j.ophtha.2014.01.018. PMID: 24702753. Exclusion Code: X4.24702753
311 Yamada T, Hatt SR, Leske DA, . Spectacle wear in children reduces parental health-related quality of life. J AAPOS. 2011 Feb;15(1):24-8. doi: 10.1016/j.jaapos.2010.11.003. PMID: 21315631. Exclusion Code: X3.21315631
312 Yamada T, Hatt SR, Leske DA, . A new computer-based pediatric vision-screening test. J AAPOS. 2015 Apr;19(2):157-62. doi: 10.1016/j.jaapos.2015.01.011. PMID: 25892043. Exclusion Code: X3.25892043
313 Yan XR, Jiao WZ, Li ZW, . Performance of the Plusoptix A09 photoscreener in detecting amblyopia risk factors in Chinese children attending an eye clinic. PLoS One. 2015;10(6):e0126052. doi: 10.1371/journal.pone.0126052. PMID: 26030210. Exclusion Code: X3.26030210
314 Yang HK, Hwang JM. The effect of target size and accommodation on the distant angle of deviation in intermittent exotropia. Am J Ophthalmol. 2011 May;151(5):907-13.e1. doi: 10.1016/j.ajo.2010.11.021. PMID: 21333266. Exclusion Code: X3.21333266
315 Yeh ML, Chen HH, Chung YC. One year study on the integrative intervention of acupressure and interactive multimedia for visual health in school children. Complement Ther Med. 2012 Dec;20(6):385-92. doi: 10.1016/j.ctim.2012.09.001. PMID: 23131368. Exclusion Code: X3.23131368
316 Yilmaz I, Ozkaya A, Alkin Z, . Comparison of the Plusoptix A09 and Retinomax K-Plus 3 with retinoscopy in children. J Pediatr Ophthalmol Strabismus. 2015 Jan-Feb;52(1):37-42. doi: 10.3928/01913913-20141230-06. PMID: 25643369. Exclusion Code: X3.25643369
317 Ying GS, Huang J, Maguire MG, . Associations of anisometropia with unilateral amblyopia, interocular acuity difference, and stereoacuity in preschoolers. Ophthalmology. 2013 Mar;120(3):495-503. doi: 10.1016/j.ophtha.2012.08.014. PMID: 23174398. Exclusion Code: X5.23174398
318 Ying GS, Maguire MG, Cyert LA, . Prevalence of vision disorders by racial and ethnic group among children participating in head start. Ophthalmology. 2014 Mar;121(3):630-6. doi: 10.1016/j.ophtha.2013.09.036. PMID: 24183422. Exclusion Code: X6.24183422
319 Zhang Y, Huang S, Ye H, . [A design of refractometer based on blur circle]. Zhongguo Yi Liao Qi Xie Za Zhi. 2011 Mar;35(2):103-7. PMID: 21706792. Exclusion Code: X1.21706792
320 Zinkernagel SM, Mojon DS. Distance doubling visual acuity test: a reliable test for nonorganic visual loss. Graefes Arch Clin Exp Ophthalmol. 2009 Jun;247(6):855-8. doi: 10.1007/s00417-008-1019-9. PMID: 19089440. Exclusion Code: X3.19089440