# Appendix B Methods

## Search Strategies

### PubMed search, 10/12/2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] | 147438 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] Filters: Infant: 1-23 months | 9631 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] Filters: Infant: 1-23 months; Preschool Child: 2-5 years | 18242 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (child [tiab] OR children [tiab] OR preschool* [tiab] OR pediatri* [tiab]) | 1083423 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #4) | 14520 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5) | 24670 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5) Filters: Publication date from 2009/01/01 to 2015/10/12 | 5520 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Vision Tests”[Mesh] OR “Refraction, Ocular”[Mesh] OR “Vision Screening”[Mesh] OR photoscreen* OR autorefract* OR “Visual Acuity ”[Mesh] OR cycloplegic refract*) | 84019 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Amblyopia/drug therapy”[Mesh] OR “Amblyopia/prevention and control”[Mesh] OR “Amblyopia/therapy”[Mesh] OR “Refractive Errors/drug therapy”[Mesh] OR “Refractive Errors/prevention and control”[Mesh] OR “Refractive Errors/therapy”[Mesh] OR “eye exercises” [all fields] OR “vision therapy” [all fields] OR “eye therapy” [all fields] OR “vision exercises” [all fields] OR “fixation training” [all fields] OR “near vision tasks” [all fields] OR “binocular therapy” [all fields] OR Ocular motility disorders/therapy OR “near activities” [all fields] OR “accommodative therapy” [all fields] OR “visual training” [all fields] OR orthoptics [all fields] | 24915 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) | 1878 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) | 1069 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 615199 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “comparative study”[pt] OR “Epidemiologic Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “observational study” OR “observational studies” OR “cohort”[tw] OR “case control”[tw] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) OR “cross-sectional studies”[MeSH Terms] OR “cross-sectional study”[tw]) | 3378268 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR reproducib*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw]) | 1941693 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #12) | 115 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #13) | 1139 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #14) | 313 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 OR #16 OR #17) | 1295 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND #12) | 142 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND #13) | 589 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 OR #20) | 645 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Review | 99 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Review; Systematic Reviews | 123 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) Filters: Review | 100 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) Filters: Review; Systematic Reviews | 121 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

### Cochrane Library, 10/12/2015

ID | Search | Hits
#1 | [mh amblyopia] or amblyopia or [mh strabismus] or strabismus or [mh “Depth Perception”] or stereopsis or ptosis or [mh “Refractive Errors”] or “refractive error” or “refractive errors” or [mh “Vision Disorders”] | 4054
#2 | child or children or preschool* or pediatri* | 107944
#3 | #1 and #2 | 1301
#4 | [mh “Vision Tests”] or [mh “Refraction, Ocular”] or [mh “Vision Screening”] or photoscreen* or autorefract* or [mh “Visual Acuity”] or cycloplegic refract* | 4534
#5 | [mh Amblyopia/dt] or [mh Amblyopia/pc] or [mh Amblyopia/th] or [mh “Refractive Errors/dt”] or [mh “Refractive Errors/pc”] or [mh “Refractive Errors/th”] or “eye exercises” or “vision therapy” or “eye therapy” or “vision exercises” or “fixation training” or “near vision tasks” or “binocular therapy” or [mh “Ocular motility disorders”/th] or “near activities” or “accommodative therapy” or “visual training” or orthoptics | 338
#6 | #3 and #4 | 432
#7 | #3 and #5 | 172
#8 | (randomized and controlled and trial) or (controlled and trial) or “controlled clinical trial”:pt or “Randomized Controlled Trial”:pt or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”] | 625248
#9 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or “comparative study”:pt or [mh “Epidemiologic Studies”] or [mh “Cross-Over Studies”] or [mh “Follow-Up Studies”] or “observational study” or “observational studies” or “cohort” or “case control” or “prospective cohort” or [mh “prospective studies”] or (prospective and cohort and (study or studies)) or [mh “cross-sectional studies”] or “cross-sectional study” | 257795
#10 | [mh “Sensitivity and Specificity”] or [mh “Predictive Value of Tests”] or [mh “ROC Curve”] or [mh “Reproducibility of Results”] or [mh “False Negative Reactions”] or [mh “False Positive Reactions”] or “predictive value” or sensitivity or specificity or accuracy or ROC or reproducib* or “false positive” or “false negative” or “likelihood ratio” | 78943
#11 | #6 and #8 | 367
#12 | #6 and #9 | 250
#13 | #6 and #10 | 122
#14 | #11 or #12 or #13 Publication Year from 2009 to 2015 | 120
#15 | #7 and #8 | 157
#16 | #7 and #9 | 103
#17 | #15 or #16 | 159

### Cumulative Index to Nursing and Allied Health Literature (CINAHL), 10/13/2015

# | Query | Limiters/Expanders | Results
S15 | S13 or S14 | Limiters - Published Date: 20090101-20151031; Exclude MEDLINE records Search modes - Boolean/Phrase | 0
S14 | S5 and S7 | Search modes - Boolean/Phrase | 0
S13 | S5 and S6 | Search modes - Boolean/Phrase | 0
S12 | (S9 OR S10 OR S11) | Limiters - Published Date: 20090101-20151031; Exclude MEDLINE records Search modes - Boolean/Phrase | 1
S11 | S4 AND S8 | Search modes - Boolean/Phrase | 1
S10 | S4 AND S7 | Search modes - Boolean/Phrase | 0
S9 | S4 AND S6 | Search modes - Boolean/Phrase | 0
S8 | mh “Sensitivity and Specificity” or mh “Predictive Value of Tests” or mh “ROC Curve” or mh “Reproducibility of Results” or mh “False Negative Reactions” or mh “False Positive Reactions” or “predictive value” or sensitivity or specificity or accuracy or ROC or reproducib* or “false positive” or “false negative” or “likelihood ratio” | Search modes - Boolean/Phrase | 186,360
S7 | PT “comparative study” OR ( mh “Case-Control Studies” or mh “Cohort Studies” or mh “Epidemiologic Studies” or mh “Cross-Over Studies” or mh “Follow-Up Studies” or “observational study” or “observational studies” or “prospective cohort” or mh “prospective studies” or (prospective and cohort and (study or studies)) or mh “cross-sectional studies” or “cross-sectional study” ) | Search modes - Boolean/Phrase | 307,379
S6 | PT ( “controlled clinical trial” or “Randomized Controlled Trial” ) OR ( mh “Single-Blind Method” or mh “Double-Blind Method” or mh “Random Allocation” ) | Search modes - Boolean/Phrase | 53,998
S5 | S1 and S3 | Limiters - Published Date: 20090101-20151031; Exclude MEDLINE records; Publication Type: Systematic Review; Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1
S4 | S1 and S2 | Limiters - Published Date: 20090101-20151031; Exclude MEDLINE records; Publication Type: Systematic Review; Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1
S3 | (MH “Amblyopia/DT/PC/TH”) or (MH “Refractive Errors/DT/PC/TH”) or (MH “Ocular Motility Disorders/TH”) or “eye exercises” or “vision therapy” or “eye therapy” or “vision exercises” or “fixation training” or “near vision tasks” or “binocular therapy” or “near activities” or “accommodative therapy” or “visual training” or orthoptics | Search modes - Boolean/Phrase | 603
S2 | mh “Vision Tests” or mh “Refraction, Ocular” or mh “Vision Screening” or photoscreen* or autorefract* or mh “Visual Acuity” or cycloplegic refract* | Search modes - Boolean/Phrase | 7,947
S1 | mh amblyopia or mh strabismus or mh “Depth Perception” or stereopsis or ptosis or mh “Refractive Errors” or mh “Vision Disorders” | Limiters - Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1,016

## Additional Searches, October 20, 2015

### ClinicalTrials.gov

#### Screening, with date and child limits

(amblyopia OR strabismus OR “Depth Perception” OR stereopsis OR ptosis OR “Refractive Errors” OR “refractive error” OR “Vision Disorders”) AND (“Vision Tests” OR “Refraction, Ocular” OR “ocular refraction” OR “Vision Screening” OR photoscreen* OR autorefract* OR “Visual Acuity” OR cycloplegic refract*) | Child | received from 01/01/2009 to 10/20/2015

#### Treatment, with date and child limits

(amblyopia OR strabismus OR “Depth Perception” OR stereopsis OR ptosis OR “Refractive Errors” OR “refractive error” OR “Vision Disorders”) AND (“eye exercises” OR “vision therapy” OR “eye therapy” OR “vision exercises” OR “fixation training” OR “near vision tasks” OR “binocular therapy” OR Ocular motility disorders OR “near activities” OR “accommodative therapy” OR “visual training” OR orthoptics) AND INFLECT EXACT “Child” [AGE-GROUP] AND (“01/01/2009” : “10/20/2015” [FIRST-RECEIVED-DATE]

### World Health Organization International Clinical Trials Registry Platform (WHO ICTRP) strategy

#### Screening

Vision Tests OR ocular refraction OR Vision Screening OR photoscreen* OR autorefract* OR Visual Acuity OR cycloplegic refract* (in TITLE)

AND

amblyopia OR strabismus OR Depth Perception OR stereopsis OR ptosis OR Refractive Errors OR refractive error OR Vision Disorders (in CONDITION)

LIMITED TO CHILDREN; RECRUITMENT STATUS-ALL

#### Treatment

amblyopia OR strabismus OR Depth Perception OR stereopsis OR ptosis OR Refractive Errors OR refractive error OR Vision Disorders (in CONDITION)

AND

(eye exercises OR vision therapy OR eye therapy OR vision exercises OR fixation training OR near vision tasks OR binocular therapy OR Ocular motility disorders OR near activities OR accommodative therapy OR visual training OR orthoptics) (in INTERVENTION)

LIMITED TO CHILDREN; RECRUITMENT STATUS-ALL

## Update Search Strategies

### PubMed search, 06/07/2016

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] | 153313 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] Filters: Infant: 1-23 months | 9910 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search amblyopia [Mesh] OR amblyopia OR strabismus [Mesh] OR strabismus OR “Depth Perception”[Mesh] OR stereopsis OR ptosis OR “Refractive Errors ”[Mesh] OR “refractive error” OR “refractive errors” OR “Vision Disorders”[Mesh] Filters: Infant: 1-23 months; Preschool Child: 2-5 years | 18707 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (child [tiab] OR children [tiab] OR preschool* [tiab] OR pediatri* [tiab]) | 1122706 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #4) | 15037 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5) | 25390 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5) Filters: Publication date from 2015/04/01 | 763 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Vision Tests”[Mesh] OR “Refraction, Ocular”[Mesh] OR “Vision Screening”[Mesh] OR photoscreen* OR autorefract* OR “Visual Acuity ”[Mesh] OR cycloplegic refract*) | 87344 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Amblyopia/drug therapy”[Mesh] OR “Amblyopia/prevention and control”[Mesh] OR “Amblyopia/therapy”[Mesh] OR “Refractive Errors/drug therapy”[Mesh] OR “Refractive Errors/prevention and control”[Mesh] OR “Refractive Errors/therapy”[Mesh] OR “eye exercises” [all fields] OR “vision therapy” [all fields] OR “eye therapy” [all fields] OR “vision exercises” [all fields] OR “fixation training” [all fields] OR “near vision tasks” [all fields] OR “binocular therapy” [all fields] OR Ocular motility disorders/therapy OR “near activities” [all fields] OR “accommodative therapy” [all fields] OR “visual training” [all fields] OR orthoptics [all fields] | 25531 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) | 213 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) | 115 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 638598 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “comparative study”[pt] OR “Epidemiologic Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “observational study” OR “observational studies” OR “cohort”[tw] OR “case control”[tw] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) OR “cross-sectional studies”[MeSH Terms] OR “cross-sectional study”[tw]) | 3503813 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR reproducib*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw]) | 2020506 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #12) | 14 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #13) | 119 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #14) | 32 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 OR #16 OR #17) | 144 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND #12) | 20 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND #13) | 60 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 OR #20) | 69 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Review | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Review; Systematic Reviews | 12 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) Filters: Review | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #9) Filters: Review; Systematic Reviews | 15 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

### Cochrane Library, 06/07/2016

ID | Search | Hits
#1 | [mh amblyopia] or amblyopia or [mh strabismus] or strabismus or [mh “Depth Perception”] or stereopsis or ptosis or [mh “Refractive Errors”] or “refractive error” or “refractive errors” or [mh “Vision Disorders”] | 4375
#2 | child or children or preschool* or pediatri* | 114634
#3 | #1 and #2 | 1412
#4 | [mh “Vision Tests”] or [mh “Refraction, Ocular”] or [mh “Vision Screening”] or photoscreen* or autorefract* or [mh “Visual Acuity”] or cycloplegic refract* | 5016
#5 | [mh Amblyopia/dt] or [mh Amblyopia/pc] or [mh Amblyopia/th] or [mh “Refractive Errors/dt”] or [mh “Refractive Errors/pc”] or [mh “Refractive Errors/th”] or “eye exercises” or “vision therapy” or “eye therapy” or “vision exercises” or “fixation training” or “near vision tasks” or “binocular therapy” or [mh “Ocular motility disorders”/th] or “near activities” or “accommodative therapy” or “visual training” or orthoptics | 369
#6 | #3 and #4 | 471
#7 | #3 and #5 | 186
#8 | (randomized and controlled and trial) or (controlled and trial) or “controlled clinical trial”:pt or “Randomized Controlled Trial”:pt or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”] | 673266
#9 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or “comparative study”:pt or [mh “Epidemiologic Studies”] or [mh “Cross-Over Studies”] or [mh “Follow-Up Studies”] or “observational study” or “observational studies” or “cohort” or “case control” or “prospective cohort” or [mh “prospective studies”] or (prospective and cohort and (study or studies)) or [mh “cross-sectional studies”] or “cross-sectional study” | 279243
#10 | [mh “Sensitivity and Specificity”] or [mh “Predictive Value of Tests”] or [mh “ROC Curve”] or [mh “Reproducibility of Results”] or [mh “False Negative Reactions”] or [mh “False Positive Reactions”] or “predictive value” or sensitivity or specificity or accuracy or ROC or reproducib* or “false positive” or “false negative” or “likelihood ratio” | 84491
#11 | #6 and #8 | 408
#12 | #6 and #9 | 280
#13 | #6 and #10 | 130
#14 | #11 or #12 or #13 Publication Year from 2015 to 2016 | 17
#15 | #7 and #8 | 170
#16 | #7 and #9 | 113
#17 | #15 or #16 Publication Year from 2015 to 2016 | 8

### Cumulative Index to Nursing and Allied Health Literature (CINAHL), 06/07/2016

| Query | Limiters/Expanders | Results
S20 | S16 or S17 or S18 | Limiters - Published Date: 20150401-; Exclude MEDLINE records Search modes - Boolean/Phrase | 1
S19 | S16 or S17 or S18 | Search modes - Boolean/Phrase | 26
S18 | S15 and S9 | Search modes - Boolean/Phrase | 7
S17 | S15 and S8 | Search modes - Boolean/Phrase | 19
S16 | S15 and S7 | Search modes - Boolean/Phrase | 3
S15 | S1 and S3 | Search modes - Boolean/Phrase | 123
S14 | S10 or S11 or S12 | Limiters - Published Date: 20150401-; Exclude MEDLINE records Search modes - Boolean/Phrase | 1
S13 | S10 or S11 or S12 | Search modes - Boolean/Phrase | 129
S12 | S6 and S9 | Search modes - Boolean/Phrase | 58
S11 | S6 and S8 | Search modes - Boolean/Phrase | 81
S10 | S6 and S7 | Search modes - Boolean/Phrase | 6
S9 | mh “Sensitivity and Specificity” or mh “Predictive Value of Tests” or mh “ROC Curve” or mh “Reproducibility of Results” or mh “False Negative Reactions” or mh “False Positive Reactions” or “predictive value” or sensitivity or specificity or accuracy or ROC or reproducib* or “false positive” or “false negative” or “likelihood ratio” | Search modes - Boolean/Phrase | 199,643
S8 | PT “comparative study” OR ( mh “Case-Control Studies” or mh “Cohort Studies” or mh “Epidemiologic Studies” or mh “Cross-Over Studies” or mh “Follow-Up Studies” or “observational study” or “observational studies” or “prospective cohort” or mh “prospective studies” or (prospective and cohort and (study or studies)) or mh “cross-sectional studies” or “cross-sectional study” ) | Search modes - Boolean/Phrase | 322,154
S7 | PT ( “controlled clinical trial” or “Randomized Controlled Trial” ) OR ( mh “Single-Blind Method” or mh “Double-Blind Method” or mh “Random Allocation” ) | Search modes - Boolean/Phrase | 56,553
S6 | S1 and S2 | Search modes - Boolean/Phrase | 345
S5 | S1 and S3 | Limiters - Published Date: 20150401-20161231; Exclude MEDLINE records; Publication Type: Systematic Review; Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1
S4 | S1 and S2 | Limiters - Published Date: 20150401-20161231; Exclude MEDLINE records; Publication Type: Systematic Review; Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1
S3 | (MH “Amblyopia/DT/PC/TH”) or (MH “Refractive Errors/DT/PC/TH”) or (MH “Ocular Motility Disorders/TH”) or “eye exercises” or “vision therapy” or “eye therapy” or “vision exercises” or “fixation training” or “near vision tasks” or “binocular therapy” or “near activities” or “accommodative therapy” or “visual training” or orthoptics | Search modes - Boolean/Phrase | 636
S2 | mh “Vision Tests” or mh “Refraction, Ocular” or mh “Vision Screening” or photoscreen* or autorefract* or mh “Visual Acuity” or cycloplegic refract* | Search modes - Boolean/Phrase | 8,237
S1 | mh amblyopia or mh strabismus or mh “Depth Perception” or stereopsis or ptosis or mh “Refractive Errors” or mh “Vision Disorders” | Limiters - Age Groups: Infant: 1-23 months, Child, Preschool: 2-5 years Search modes - Boolean/Phrase | 1,040

Appendix B Table 1 Study Eligibility Criteria

| Include | Exclude
Populations | All KQs: Children age 6 months to 5 years KQs 1–3: Children without known impaired visual acuity or obvious symptoms of impaired visual acuity KQs 4, 5: Children with amblyopia, amblyopia risk factors, and/or refractive error | Newborns, children younger than age 6 months, and children age 6 years or older; children with severe congenital conditions or developmental delays, retinopathy of prematurity, glaucoma, congenital cataract, neurodevelopmental disorders, systemic conditions associated with ocular abnormalities, or pathologic myopia
Setting | All KQs: Studies performed in primary care, community-based, and school settings; studies conducted in countries categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme KQs 2–5: Specialty settings (e.g., ophthalmology or optometry practices)
Screening tests and interventions | KQs 1–3: Studies of screening tests used or available in primary care settings, including visual acuity tests (e.g., autorefraction; picture identification tests, such as Allen test cards or LEA symbols; HOTV chart; Snellen chart; tumbling E chart), stereoacuity tests (e.g., contour stereotests, such as the Frisby, Random Dot E, Stereo Smile, and Titmus Fly tests; Moving Dynamic Random Dot Stereosize test), and ocular alignment tests (e.g., photoscreening, corneal light reflex test, cover-uncover test, cross cover test, red reflex test) KQs 4, 5: Correction of refractive error (eyeglasses), penalization of the nonamblyopic eye (eye patch, atropine), and vision therapy (eye exercises) | KQs 1–3: Studies of screening tests not used or available in primary care settings (e.g., contrast sensitivity test, fundoscopic examination, visual acuity test with cycloplegia) or not intended to detect amblyopia, amblyopia risk factors, or refractive error (e.g., white reflex test) KQs 4, 5: Surgical interventions for strabismus or other indications
Comparisons | KQs 1, 3: Screened vs. nonscreened groups or earlier (at a younger age) vs. later screening (at an older age) KQ 2: Evaluations that include cycloplegic refraction and/or a comprehensive eye examination; for evaluations of reliability (test-retest), the comparison may be the same test administered at different time points or by a different person. KQs 4, 5: No treatment or sham or inactive control | No comparison, nonconcordant historical controls, comparative studies of various interventions (i.e., head-to-head studies without an additional eligible comparison group)
Outcomes | KQs 1, 4: Reduced long-term amblyopia and improved visual acuity, school performance, functioning, and quality of life KQ 2: Sensitivity, specificity, positive and negative predictive values, likelihood ratios, and diagnostic odds ratios (or ability to calculate such outcomes from data provided); measures of reliability, including reproducibility, interrater reliability, and testability (ability of children to cooperate with the test) KQs 3, 5: Harms, including psychological distress, labeling, anxiety, other psychological effects, false-positive results, and adverse effects on vision in the nonimpaired eye | Cost-effectiveness or cost-related outcomes KQ 2: Studies providing only associations, correlations, or other outcomes
Study designs | KQ 1: Randomized, controlled trials and prospective cohort studies with an eligible comparator KQ 2: Cross-sectional studies, cohort studies, or trials focused on assessment of diagnostic accuracy KQs 3, 5: Randomized, controlled trials; controlled cohort studies; case-control studies KQ 4: Randomized, controlled trials | Case reports, case series, systematic reviews, and all other study designs not listed as eligible KQ 2: Studies that do not attempt to perform the reference standard in all participants or a random sample of participants
Language and publication status | English-language, full-text journal articles | Languages other than English, publications available only as a conference abstract

Abbreviation: KQ=Key Question.

Appendix B Table 2 U.S. Preventive Services Task Force Quality Rating Criteria

Criteria for Randomized, Controlled Trials
- Initial assembly of comparable groups: Randomized controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: Equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of interventions; - Important outcomes considered; - Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria
Good | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in the analysis.
Fair | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor | Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VII , Harris et al, 2001^71^

Criteria for Studies of Screening Tests
- Screening test relevant, available for primary care, adequately described.; - Study uses a credible reference standard, performed regardless of test results.; - Reference standard interpreted independently of screening test.; - Handles indeterminate results in a reasonable manner.; - Spectrum of patients included in study.; - Sample size: Although this is one of the criteria listed in the current procedures manual, we did not consider sample size when assessing study quality, because sample size affects precision of the estimate.; - Administration of reliable screening test.

In addition to the criteria listed in the USPSTF procedures manual, we also considered the criteria described in Appendix D (which details quality assessments of individual studies).

Definition of Ratings Based on Above Criteria
Good | Relevant and adequately described study populations for the outcome of interest (i.e., sensitivity, specificity), screening test well described in terms of test procedures followed and threshold used for a “positive” or “negative” test, credible reference standard used for outcome of interest (i.e., sensitivity or specificity), generally interprets reference standard independently of screening test, outcomes clearly reported and valid, handles indeterminate results in a reasonable manner.
Fair | Mostly includes a relevant and adequately described study population for the outcome of interest (i.e., sensitivity, specificity), screening test described although may include some ambiguity about test procedures followed or threshold for a “positive” or “negative” test, credible reference standard mostly used for outcome of interest (i.e., sensitivity or specificity), interpretation of reference standard may or may not be independent of screening test, outcomes mostly clearly reported although may have some ambiguity regarding how indeterminate results were handled.
Poor | Has fatal flaw such as study population not appropriate for outcome of interest (i.e., sensitivity, specificity), screening test improperly administered or not at all described, use of noncredible reference standard, reference and screening test not independently assessed, outcomes not clearly or accurately reported with no information about how indeterminate tests were handled.

Criteria Adapted from: U.S. Preventive Services Task Force, Procedure Manual Appendix VII, Harris et al, 2001.^71^