# Appendix A Glossary of Terms and Summary of Recommendations From Other Groups

Glossary of Terms
Amblyopia: A neurodevelopmental disorder that arises from abnormal processing of visual images during a critical period of vision development, resulting in a functional reduction of visual acuity.
Ametropia: An abnormal refractive condition (such as myopia, hyperopia, or astigmatism) of the eye in which images fail to focus on the retina; also referred to as refractive error.
Anisometropia: A difference in refractive power between the eyes in which one foveal image is more blurred than the other.
Astigmatism: Blurred vision caused by a failure to focus light evenly onto the retina because of deviation from normal spherical curvature.
Cataract: A clouding or loss of transparency of the lens in the eye as a result of tissue breakdown and protein clumping.
Emmetropia: A state in which the eye is relaxed and focused on an object more than 6 meters or 20 feet away. The light rays coming from that object are essentially parallel, and the rays are focused on the retina without effort.
Hyperopia: A condition in which visual images come to a focus behind the retina of the eye and vision is better for distant than near objects.
Isoametropia: Refractive error that is similar in both eyes.
Myopia: A condition in which visual images come to a focus in front of the retina of the eye because of defects in the refractive media or abnormal length of the eyeball, resulting especially in defective vision for distant objects.
Ptosis: Drooping of the upper eyelid due to paralysis, disease, or a congenital condition.
Stereopsis: The perception of depth produced by the reception in the brain of visual stimuli from both eyes in combination; also known as binocular vision.
Strabismus: Ocular misalignment in which each eye does not have the same image on the fovea.
Visual acuity: Sharpness of vision, measured by the ability to discern letters or numbers at a given distance according to a fixed standard.

Appendix A Table 1 Summary of Recommendations From Other Groups

Group, Year | Recommendation(s)
American Academy of Family Physicians (AAFP), 2011^147^ | The AAFP recommends vision screening for all children at least once between the ages of 3 and 5 years to detect the presence of amblyopia or its risk factors. The AAFP concludes that the current evidence is insufficient to assess the balance of benefits and harms of vision screening for children <3 years of age.
American Academy of Pediatrics (AAP), American Association for Pediatric Ophthalmology and Strabismus (AAPOS), American Academy of Ophthalmology (AAO), and American Academy of Certified Orthoptists, 2016^148^ (joint statement) | Vision screening should be performed at an early age and at regular intervals with age-appropriate, valid methods, ideally within the medical home. Recommended screening components by age are: Newborn to 6 months: Fixation and follow response, red reflex (for ocular media clarity), and external inspection via direct observation. 6 months to 1 year of age: The above (for newborn to 6 months) plus pupil examination using a flashlight. 1 to 3 years: The above (for 6 months to 1 year) plus instrument-based vision screening (photoscreening, autorefraction) when available. Visual acuity screening may be attempted at age 3 years using HOTV or LEA Symbols. 4 to 5 years of age: Visual acuity screening using HOTV or LEA Symbols, cross cover test, and red reflex.
American Optometric Association (AOA), 2002^149^ | All children should receive regular comprehensive eye examinations (by an eye care specialist) beginning at 6 months of age after an initial eye screening at birth, typically performed by the pediatrician. Eye examinations are then recommended at age 3 years, before entering first grade, and then periodically at 2-year intervals (or more frequently in children who have visual complaints or risk factors for vision impairment).
Canadian Task Force on Preventive Health Care (CTFPHC), 1989^150^ | There is fair evidence to include testing of visual acuity in the periodic health examination of preschool children.