# References

1 Moyer VA. Behavioral counseling interventions to promote a healthful diet and physical activity for cardiovascular disease prevention in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(5):367–71. PMID: 22733153. http://dx.doi.org/10.7326/0003-4819-157-5-201209040-00486 22733153
2 U.S. Department of Health and Human Services, U.S. Department of Agriculture. 2015–2020 Dietary Guidelines for Americans. Washington DC: U.S. Department of Health and Human Services; 2015. PMID: None.
3 U.S. Department of Health and Human Services, U.S. Department of Agriculture. Scientific Report of the 2015 Dietary Guidelines Advisory Committee. Washington DC: U.S. Department of Health and Human Services; 2015. PMID: None.
4 American Heart Association. American Heart Association Recommendations for Physical Activity in Adults. http://www.heart.org/HEARTORG/GettingHealthy/PhysicalActivity/FitnessBasics/American-Heart-Association-Recommendations-for-Physical-Activity-in-Adults_UCM_307976_Article.jsp. Accessed May 2, 2016.
5 World Health Organization. Global Recommendations on Physical Activity for Health. Geneva Switzerland: World Health Organization; 2010. PMID: None.
6 U. S. Department of Health and Human Services. 2008 Physical Activity Guidelines for Americans. Washington DC: US Department of Health and Human Services; 2008. PMID: None.
7 Owen N, Healy GN, Matthews CE, . Too much sitting: the population health science of sedentary behavior. Exerc Sport Sci Rev. 2010;38(3):105–13. PMID: 20577058. http://dx.doi.org/10.1097/JES.0b013e3181e373a2 20577058
8 Australian Government Department of Health. Australia’s Physical Activity and Sedentary Behaviour Guidelines. http://www.health.gov.au/internet/main/publishing.nsf/content/health-pubhlth-strateg-phys-act-guidelines. Accessed Apr 4, 2016. PMID: None.
9 Davies D, Burns H, Jewell T, . Start Active, Stay Active: A report on physical activity from the four home countries’ Chief Medical Officers. London, UK: Department of Health; 2011. PMID: None.
10 Mokdad AH, Marks JS, Stroup DF, . Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238–45. PMID: 15010446. https://dx.doi.org/10.1001/jama.291.10.1238 15010446
11 Johnson NB, Hayes LD, Brown K, . CDC National Health Report: Leading Causes of Morbidity and Mortality and Associated Behavioral Risk and Protective Factors-United States, 2005–2013. MMWR Surveill Summ. 2014;63:3–27. PMID: 25356673.25356673
12 Mozaffarian D, Benjamin EJ, Go AS, . Heart Disease and Stroke Statistics-2016 Update: A Report From the American Heart Association. Circulation. 2016;133(4):e38–e360. PMID: 26673558. http://dx.doi.org/10.1161/CIR.0000000000000350 26673558
13 Heidenreich PA, Trogdon JG, Khavjou OA, . Forecasting the future of cardiovascular disease in the United States: a policy statement from the American Heart Association. Circulation. 2011;123(8):933–44. PMID: 21262990. http://dx.doi.org/10.1161/CIR.0b013e31820a55f5 21262990
14 Ford ES, Caspersen CJ. Sedentary behaviour and cardiovascular disease: a review of prospective studies. Int J Epidemiol. 2012;41(5):1338–53. PMID: 22634869. http://dx.doi.org/10.1093/ije/dys078 22634869
15 Chomistek AK, Manson JE, Stefanick ML, . Relationship of sedentary behavior and physical activity to incident cardiovascular disease: results from the Women’s Health Initiative. J Am Coll Cardiol. 2013;61(23):2346–54. PMID: 23583242. http://dx.doi.org/10.1016/j.jacc.2013.03.031 23583242
16 Matthews CE, George SM, Moore SC, . Amount of time spent in sedentary behaviors and cause-specific mortality in US adults. Am J Clin Nutr. 2012;95(2):437–45. PMID: 22218159. http://dx.doi.org/10.3945/ajcn.111.019620 22218159
17 Matthews CE, Chen KY, Freedson PS, . Amount of time spent in sedentary behaviors in the United States, 2003–2004. Am J Epidemiol. 2008;167(7):875–81. PMID: 18303006. http://dx.doi.org/10.1093/aje/kwm390 18303006
18 Bogers R, Bemelmans W, Hoogenveen R, . Association of overweight with increased risk of coronary heart disease partly independent of blood pressure and cholesterol levels: a meta-analysis of 21 cohort studies including more than 300 000 persons. Arch Intern Med. 2007;167(16):1720–8. PMID: 17846390. https://dx.doi.org/10.1001/archinte.167.16.1720 17846390
19 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006. http://dx.doi.org/10.1016/S0140-6736(09)60318-4 19299006
20 Ogden CL, Carroll MD, Kit BK, . Prevalence of childhood and adult obesity in the United States, 2011–2012. JAMA. 2014;311(8):806–14. PMID: 24570244. http://dx.doi.org/10.1001/jama.2014.732 24570244
21 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837–47. PMID: 9603539. http://dx.doi.org/10.1161/01.CIR.97.18.1837 9603539
22 National Cholesterol Education Program. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143–421. PMID: 12485966.12485966
23 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743–53. PMID: 18212285. http://dx.doi.org/10.1161/CIRCULATIONAHA.107.699579 18212285
24 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2935–59. PMID: 24239921. http://dx.doi.org/10.1016/j.jacc.2013.11.005 24239921
25 National Heart Lung and Blood Institute. 2013 Report on the Assessment of Cardiovascular Risk: Full Work Group Report Supplement. National Heart, Lung, and Blood Institute; 2013. PMID: None.
26 Carroll MD, Kit BK, Lacher DA, . Total and high-density lipoprotein cholesterol in adults: National Health and Nutrition Examination Survey, 2011–2012. NCHS Data Brief. 2013(132):1–8. PMID: 24165064.24165064
27 Cowie CC, Rust KF, Ford ES, . Full accounting of diabetes and pre-diabetes in the U.S. population in 1988–1994 and 2005–2006. Diabetes Care. 2009;32(2):287–94. PMID: 19017771. http://dx.doi.org/10.2337/dc08-1296 19017771
28 Nwankwo T, Yoon S, Burt V, . Hypertension among adults in the United States: National Health and Nutrition Examination Survey, 2011–2012. NCHS data brief. 2013(133):1–8. PMID: 24171916.24171916
29 Kirkpatrick SI, Dodd KW, Reedy J, . Income and race/ethnicity are associated with adherence to food-based dietary guidance among US adults and children. J Acad Nutr Diet. 2012;112(5):624–35. PMID: 22709767. https://dx.doi.org/10.1016/j.jand.2011.11.012 22709767
30 National Center for Health Statistics. Health, United States, 2014: with special feature on adults aged 55–64. Report No.:2015-1232. Hyattsville, MD: National Center for Health Statistics (US); 2015. PMID: 2608606426086064.
31 de Mestral C, Stringhini S, Marques-Vidal P. Barriers to healthy eating in Switzerland: a nationwide study. Clin Nutr. 2016;[Epub ahead of print]. PMID: 27091772. http://dx.doi.org/10.1016/j.clnu.2016.04.004 27091772
32 Kelly S, Martin S, Kuhn I, . Barriers and facilitators to the uptake and maintenance of healthy behaviours by people at mid-life: a rapid systematic review. PLoS One. 2016;11(1):e0145074. PMID: 26815199. http://dx.doi.org/10.1371/journal.pone.0145074 26815199
33 Suplee PD, Jerome-D’Emilia B, Burrell S. Exploring the challenges of healthy eating in an urban community of hispanic women. Hisp Health Care Int. 2015;13(3):161–70. PMID: 26400394. http://dx.doi.org/10.1891/1540-4153.13.3.161 26400394
34 Griffith DM, Cornish EK, McKissic SA, . Differences in perceptions of the food environment between African American men who did and did not consume recommended levels of fruits and vegetables. Health Educ Behav. 2016;[Epub ahead of print]. PMID: 26932874. http://dx.doi.org/10.1177/1090198115626923 26932874
35 Allender S, Cowburn G, Foster C. Understanding participation in sport and physical activity among children and adults: a review of qualitative studies. Health Educ Res. 2006;21(6):826–35. PMID: 16857780. http://dx.doi.org/10.1093/her/cyl063 16857780
36 Mailey EL, Phillips SM, Dlugonski D, . Overcoming barriers to exercise among parents: a social cognitive theory perspective. J Behav Med. 2016;[Epub ahead of print]. PMID: 27108160. http://dx.doi.org/10.1007/s10865-016-9744-8 27108160
37 Centers for Disease Control and Prevention. Strategies to prevent obesity and other chronic diseases: the CDC guide to strategies to increase physical activity in the community. Atlanta, GA: U.S. Department of Health and Human Services; 2011. PMID: None.
38 Hirsch JA, Moore KA, Clarke PJ, . Changes in the built environment and changes in the amount of walking over time: longitudinal results from the multi-ethnic study of atherosclerosis. Am J Epidemiol. 2014;180(8):799–809. PMID: 25234431. http://dx.doi.org/10.1093/aje/kwu218 25234431
39 Sallis JF, Glanz K. Physical activity and food environments: solutions to the obesity epidemic. Milbank Q. 2009;87(1):123–54. PMID: 19298418. http://dx.doi.org/10.1111/j.1468-0009.2009.00550.x 19298418
40 Lin JS, O’Connor E, Whitlock EP, . Behavioral counseling to promote physical activity and a healthful diet to prevent cardiovascular disease in adults: update of the evidence for the U.S. Preventive Services Task Force. Evidence Synthesis No. 79. AHRQ Publication No. 11-05149-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2010. PMID: 2159510021595100.
41 Patnode CD, Henderson JT, Thompson JH, . Behavioral counseling and pharmacotherapy interventions for tobacco cessation in adults, including pregnant women: a review of reviews for the U.S. Preventive Services Task Force. Ann Intern Med. 2015;163(8):608–21. PMID: 26389650. http://dx.doi.org/10.7326/M15-0171 26389650
42 LeBlanc E, O’Connor E, Whitlock EP, . Screening for and management of obesity and overweight in adults. Evidence Report No. 89. AHRQ Publication No. 11-05159-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2011. PMID: 2204956922049569.
43 Guirguis-Blake JM, Evans CV, Senger CA, . Aspirin for the primary prevention of cardiovascular events: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2016;[Epub ahead of print]. PMID: 27064410. http://dx.doi.org/10.7326/M15-2113 27064410
44 Piper MA, Evans CV, Burda BU, . Diagnostic and predictive accuracy of blood pressure screening methods with consideration of rescreening intervals: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015;162(3):192–204. PMID: 25531400. http://dx.doi.org/10.7326/M14-1539 25531400
45 Chou R, Dana T, Blazina I, . Statins for prevention of cardiovascular disease in adults: systematic review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 132. AHRQ Publication No. 13-05193-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2015. PMID: 2649175626491756.
46 Selph S, Dana T, Blazina I, . Screening for type 2 diabetes mellitus: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015;162(11):765–76. PMID: 25867111. http://dx.doi.org/10.7326/M14-2221 25867111
47 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. April 2016. http://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf. Accessed May 25, 2016, 2016.
48 Eckel RH, Jakicic JM, Ard JD, . 2013 AHA/ACC guideline on lifestyle management to reduce cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2960–84. PMID: 24239922. http://dx.doi.org/10.1016/j.jacc.2013.11.003 24239922
49 Jacobson DM, Strohecker L, Compton MT, . Physical activity counseling in the adult primary care setting: position statement of the American College of Preventive Medicine. Am J Prev Med. 2005;29(2):158–62. PMID: 16005814. http://dx.doi.org/10.1016/j.amepre.2005.04.009 16005814
50 Medicine ACoS. Exercise is Medicine. http://exerciseismedicine.org/. Accessed May 13, 2016.
51 Kraus WE, Bittner V, Appel L, . The National Physical Activity Plan: a call to action from the American Heart Association: a science advisory from the American Heart Association. Circulation. 2015;131(21):1932–40. PMID: 25918126. http://dx.doi.org/10.1161/CIR.0000000000000203 25918126
52 Task Force on Community Preventive Services. Recommendations to increase physical activity in communities. Am J Prev Med. 2002;22(4 Suppl):67–72. PMID: 11985935.11985935
53 U.S. Department of Health and Human Services. Healthy People 2020. https://www.healthypeople.gov/2020/topics-objectives. Accessed May 2, 2016.
54 Hing E, Albert M. State variation in preventive care visits, by patient characteristics, 2012. NCHS data brief, no 234. Hyattsville, MD: National Center for Health Statistics; 2016. PMID: None.
55 Hesse BW, Nelson DE, Kreps GL, . Trust and sources of health information: the impact of the Internet and its implications for health care providers: findings from the first Health Information National Trends Survey. Arch Intern Med. 2005;165(22):2618–24. PMID: 16344419. http://dx.doi.org/10.1001/archinte.165.22.2618 16344419
56 Hiddink GJ, Hautvast JG, van Woerkum CM, . Consumers’ expectations about nutrition guidance: the importance of primary care physicians. Am J Clin Nutr. 1997;65(6 Suppl):1974S–9S. PMID: 9174506.9174506
57 Honda K. Factors underlying variation in receipt of physician advice on diet and exercise: applications of the behavioral model of health care utilization. Am J Health Promot. 2004;18(5):370–7. PMID: 15163138. http://dx/doi.org/10.4278/0890-1171-18.5.370 15163138
58 Barnes PM, Schoenborn CA. Trends in adults receiving a recommendation for exercise or other physical activity from a physician or other health professional. NCHS Data Brief. 2012:(86)1–8. PMID: 22617014.22617014
59 Hebert ET, Caughy MO, Shuval K. Primary care providers’ perceptions of physical activity counselling in a clinical setting: a systematic review. Br J Sports Med. 2012;46(9):625–31. PMID: 22711796. https://dx.doi.org/10.1136/bjsports-2011-090734 22711796
60 LeFevre ML, Force USPST. Behavioral counseling to promote a healthful diet and physical activity for cardiovascular disease prevention in adults with cardiovascular risk factors: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(8):587–93. PMID: 25155419. http://dx.doi.org/10.7326/M14-1796 25155419
61 Siu AL, Force USPST. Screening for Abnormal Blood Glucose and Type 2 Diabetes Mellitus: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015;163(11):861–8. PMID: 26501513. http://dx.doi.org/10.7326/M15-2345 26501513
62 Moyer VA, U. S. Preventive Services Task Force. Screening for and management of obesity in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(5):373–8. PMID: 22733087. http://dx.doi.org/10.7326/0003-4819-157-5-201209040-00475 22733087
63 Lin JS, O’Connor E, Whitlock EP, . Behavioral counseling to promote physical activity and a healthful diet to prevent cardiovascular disease in adults: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(11):736–50. PMID: 21135297. http://dx.doi.org/10.7326/0003-4819-153-11-201012070-00007 21135297
64 Lin JS, O’Connor E, Evans CV, . Behavioral counseling to promote a healthy lifestyle in persons With cardiovascular risk ractors: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;161(8):568–78. PMID: 25155549. http://dx.doi.org/10.7326/m14-0130 25155549
65 Lin JS, O’Connor EA, Evans CV, . Behavioral counseling to promote a healthy lifestyle for cardiovascular disease prevention in persons with cardiovascular risk factors: an updated systematic evidence review for the U.S. Preventive Services Task. Force Evidence Report No. 113. AHRQ Publication No. 13-05179-EF-1. Rockville MD: Agency for Healthcare Research and Quality; 2014. PMID: 2523263325232633.
66 Prince SA, Saunders TJ, Gresty K, . A comparison of the effectiveness of physical activity and sedentary behaviour interventions in reducing sedentary time in adults: a systematic review and meta-analysis of controlled trials. Obes Rev. 2014;15(11):905–19. PMID: 25112481. http://dx.doi.org/10.1111/obr.12215 25112481
67 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
68 United Nations Development Programme. Human Development Report 2014: Sustaining Human Progress: Reducing Vulnerabilties and Building Resilience. New York, New York: United Nations Development Programme; 2014. PMID: None.
69 Prochaska JO, Velicer WF, Redding C, . Stage-based expert systems to guide a population of primary care patients to quit smoking, eat healthier, prevent skin cancer, and receive regular mammograms. Prev Med. 2005;41(2):406–16. PMID: 15896835. https://dx.doi.org/10.1016/j.ypmed.2004.09.050 15896835
70 Michie S, Richardson M, Johnston M, . The behavior change technique taxonomy (v1) of 93 hierarchically clustered techniques: building an international consensus for the reporting of behavior change interventions. Ann Behav Med. 2013;46(1):81–95. PMID: 23512568. http://dx.doi.org/10.1007/s12160-013-9486-6 23512568
71 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–88. PMID: 3802833. http://dx.doi.org/10.1016/0197-2456(86)90046-2 3802833
72 Hivert MF, Langlois MF, Bérard P, . Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes (Lond). 2007;31(8):1262–9. PMID: 17356531. https://dx.doi.org/10.1038/sj.ijo.0803572 17356531
73 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919. http://dx.doi.org/10.1002/sim.1186 12111919
74 The Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. Higgins J, Green S, editors: The Cochrane Collaboration; 2011. PMID: None.
75 Hartung J, Knapp G. A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med. 2001;20(24):3875–89. PMID: 11782040.11782040
76 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. JAMA. 2006;295(6):676–80. PMID: 16467236. http://dx.doi.org/10.1001/jama.295.6.676 16467236
77 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563. http://dx.doi.org/10.1136/bmj.315.7109.629 9310563
78 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
79 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. http://dx.doi.org/10.1186/1472-6963-4-38 15615589
80 Aadahl M, Linneberg A, Moller TC, . Motivational counseling to reduce sitting time: a community-based randomized controlled trial in adults. Am J Prev Med. 2014;47(5):576–86. PMID: 25113139. http://dx.doi.org/10.1016/j.amepre.2014.06.020 25113139
81 Aittasalo M, Miilunpalo S, Kukkonen-Harjula K, . A randomized intervention of physical activity promotion and patient self-monitoring in primary health care. Prev Med. 2006;42(1):40–6. PMID: 16297442. https://dx.doi.org/10.1016/j.ypmed.2005.10.003 16297442
82 Albright CL, Steffen AD, Novotny R, . Baseline results from Hawaii’s Na Mikimiki Project: a physical activity intervention tailored to multiethnic postpartum women. Women Health. 2012;52(3):265–91. PMID: 22533900. https://dx.doi.org/10.1080/03630242.2012.662935 22533900
83 Albright CL, Steffen AD, Wilkens LR, . Effectiveness of a 12-month randomized clinical trial to increase physical activity in multiethnic postpartum women: Results from Hawaii’s N Mikimiki Project. Prev Med. 2014;69:214–23. PMID: 25285751. http://dx.doi.org/10.1016/j.ypmed.2014.09.019 25285751
84 Aldana SG, Greenlaw RL, Diehl HA, . Effects of an intensive diet and physical activity modification program on the health risks of adults. J Am Diet Assoc. 2005;105(3):371–81. PMID: 15746824. https://dx.doi.org/10.1016/j.jada.2004.12.007 15746824
85 Aldana SG, Greenlaw RL, Diehl HA, . The behavioral and clinical effects of therapeutic lifestyle change on middle-aged adults. Prev Chronic Dis. 2006;3(1):A05. PMID: 16356358.16356358
86 Alexander GL, McClure JB, Calvi JH, . A randomized clinical trial evaluating online interventions to improve fruit and vegetable consumption. Am J Public Health. 2010;100(2):319–26. PMID: 20019315. https://dx.doi.org/10.2105/AJPH.2008.154468 20019315
87 Allen P, Thompson JL, Herman CJ, . Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Prev Chronic Dis. 2008;5(3):A76. PMID: 18558026.18558026
88 Allison MA, Aragaki AK, Ray RM, . A Randomized Trial of a Low-Fat Diet Intervention on Blood Pressure and Hypertension: Tertiary Analysis of the WHI Dietary Modification Trial. Am J Hypertens. 2015. PMID: 26708006. http://dx.doi.org/10.1093/ajh/hpv196 26708006
89 Assaf AR, Beresford SA, Risica PM, . Low-Fat Dietary Pattern Intervention and Health-Related Quality of Life: The Women’s Health Initiative Randomized Controlled Dietary Modification Trial. J Acad Nutr Diet. 2016;116(2):259–71. PMID: 26384466. http://dx.doi.org/10.1016/j.jand.2015.07.016 26384466
90 Baron JA, Gleason R, Crowe B, . Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Pract. 1990;40(333):137–41. PMID: 2115348.2115348
91 Bennett GG, Foley P, Levine E, . Behavioral treatment for weight gain prevention among black women in primary care practice: A randomized clinical trial. JAMA Intern Med. 2013;173(19):1770–7. PMID: 23979005. http://dx.doi.org/10.1001/jamainternmed.2013.9263 23979005
92 Beresford SA, Curry SJ, Kristal AR, . A dietary intervention in primary care practice: the Eating Patterns Study. Am J Public Health. 1997;87(4):610–6. PMID: 9146440.9146440
93 Bernstein A, Nelson ME, Tucker KL, . A home-based nutrition intervention to increase consumption of fruits, vegetables, and calcium-rich foods in community dwelling elders. J Am Diet Assoc. 2002;102(10):1421–7. PMID: 12396159.12396159
94 Bickmore TW, Silliman RA, Nelson K, . A Randomized Controlled Trial of an Automated Exercise Coach for Older Adults. J Am Geriatr Soc. 2013;61(10):1676–83. PMID: 24001030. https://dx.doi.org/10.1111/jgs.12449 24001030
95 Blumenthal JA, Babyak MA, Hinderliter A, . Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. 2010;170(2):126–35. PMID: 20101007. https://dx.doi.org/10.1001/archinternmed.2009.470 20101007
96 Bowen D, Clifford CK, Coates R, . The Women’s Health Trial Feasibility Study in Minority Populations: design and baseline descriptions. Ann Epidemiol. 1996;6(6):507–19. PMID: 8978881. http://dx.doi.org/10.1016/S1047-2797(96)00072-5 8978881
97 Brekke HK, Jansson PA, Lenner RA. Long-term (1- and 2-year) effects of lifestyle intervention in type 2 diabetes relatives. Diabetes Res Clin Pract. 2005;70(3):225–34. PMID: 15885845. https://dx.doi.org/10.1016/j.diabres.2005.03.027 15885845
98 Bryan AD, Magnan RE, Hooper AE, . Colorado stride (COSTRIDE): testing genetic and physiological moderators of response to an intervention to increase physical activity. Int J Behav Nutr Phys Act. 2013;10:139. PMID: 24359456. http://dx.doi.org/10.1186/1479-5868-10-139 24359456
99 Burke L, Jancey J, Howat P, . Physical activity and nutrition program for seniors (PANS): protocol of a randomized controlled trial. BMC Public Health. 2010;10:751. PMID: 21129226. https://dx.doi.org/10.1186/1471-2458-10-751 21129226
100 Burke L, Lee AH, Jancey J, . Physical activity and nutrition behavioural outcomes of a home-based intervention program for seniors: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:14. PMID: 23363616. https://dx.doi.org/10.1186/1479-5868-10-14 23363616
101 Carpenter RA, Finley C, Barlow CE. Pilot test of a behavioral skill building intervention to improve overall diet quality. J Nutr Educ Behav. 2004;36(1):20–4. PMID: 14756978.14756978
102 Carroll JK, Lewis BA, Marcus BH, . Computerized tailored physical activity reports. A randomized controlled trial. Am J Prev Med. 2010;39(2):148–56. PMID: 20621262. https://dx.doi.org/10.1016/j.amepre.2010.04.005 20621262
103 Castro CM, Pruitt LA, Buman MP, . Physical activity program delivery by professionals versus volunteers: the TEAM randomized trial. Health Psychol. 2011;30(3):285–94. PMID: 21553972. https://dx.doi.org/10.1037/a0021980 21553972
104 Clark PG, Nigg CR, Greene G, . The Study of Exercise and Nutrition in Older Rhode Islanders (SENIOR): translating theory into research. Health Educ Res. 2002;17(5):552–61. PMID: 12408200. http://dx.doi.org/10.1093/her/17.5.552 12408200
105 Clark PG, Rossi JS, Greaney ML, . Intervening on exercise and nutrition in older adults: the Rhode Island SENIOR Project. J Aging Health. 2005;17(6):753–78. PMID: 16377771. http://dx.doi.org/10.1177/0898264305281105 16377771
106 Coates RJ, Bowen DJ, Kristal AR, . The Women’s Health Trial Feasibility Study in Minority Populations: changes in dietary intakes. Am J Epidemiol. 1999;149(12):1104–12. PMID: 10369504.10369504
107 Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506. https://dx.doi.org/10.1136/bmj.39147.604896.55 17449506
108 De Vet E, Oenema A, Sheeran P, . Should implementation intentions interventions be implemented in obesity prevention: the impact of if-then plans on daily physical activity in Dutch adults. Int J Behav Nutr Phys Act. 2009;6:11. PMID: 19267889. https://dx.doi.org/10.1186/1479-5868-6-11 19267889
109 Delichatsios HK, Friedman RH, Glanz K, . Randomized trial of a “talking computer” to improve adults’ eating habits. Am J Health Promot. 2001;15(4):215–24. PMID: 11349340. http://dx.doi.org/10.4278/0890-1171-15.4.215 11349340
110 Dutton GR, Napolitano MA, Whiteley JA, . Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Prev Med. 2008;46(3):216–21. PMID: 18234327. https://dx.doi.org/10.1016/j.ypmed.2007.12.012 18234327
111 Elley CR, Kerse N, Arroll B, . Effectiveness of counselling patients on physical activity in general practice: cluster randomised controlled trial. BMJ. 2003;326(7393):793. PMID: 12689976. https://dx.doi.org/10.1136/bmj.326.7393.793 12689976
112 Estabrooks PA, Smith-Ray RL, Almeida FA, . Move More: Translating an efficacious group dynamics physical activity intervention into effective clinical practice. Int J Sport Exerc Psychology. 2011;9(1):4–18. PMID: None. http://dx.doi.org/10.1080/1612197X.2011.563123
113 Fjeldsoe BS, Miller YD, Graves N, . Randomized Controlled Trial of an Improved Version of MobileMums, an Intervention for Increasing Physical Activity in Women with Young Children. Ann Behav Med. 2015;49(4):487–99. PMID: 25582987. http://dx.doi.org/10.1007/s12160-014-9675-y 25582987
114 Foley P, Levine E, Askew S, . Weight gain prevention among black women in the rural community health center setting: the Shape Program. BMC Public Health. 2012;12:305. PMID: 22537222. http://dx.doi.org/10.1186/1471-2458-12-305 22537222
115 Franko DL, Cousineau TM, Trant M, . Motivation, self-efficacy, physical activity and nutrition in college students: Randomized controlled trial of an internet-based education program. Prev Med. 2008;47(4):369–77. PMID: 18639581. https://dx.doi.org/10.1016/j.ypmed.2008.06.013 18639581
116 Fries E, Edinboro P, McClish D, . Randomized trial of a low-intensity dietary intervention in rural residents: the Rural Physician Cancer Prevention Project. Am J Prev Med. 2005;28(2):162–8. PMID: 15710271. https://dx.doi.org/10.1016/j.amepre.2004.10.017 15710271
117 Gao S, Stone RA, Hough LJ, . Physical activity counseling in overweight and obese primary care patients: Outcomes of the VA-STRIDE randomized controlled trial. Prev Med Rep. 2016;3:113–20. PMID: 26844197. http://dx.doi.org/10.1016/j.pmedr.2015.12.007 26844197
118 Garcia-Ortiz L, Grandes G, Sanchez-Perez A, . Effect on cardiovascular risk of an intervention by family physicians to promote physical exercise among sedentary individuals. Rev Esp Cardiol. 2010;63(11):1244–52. PMID: 21070720. http://dx.doi.org/10.1016/S1885-5857(10)70249-8 21070720
119 Gell NM, Wadsworth DD. The use of text messaging to promote physical activity in working women: A randomized controlled trial. J Phys Act Health. 2015;12(6):756–63. PMID: 25110303. http://dx.doi.org/10.1123/jpah.2013-0144 25110303
120 Goldstein MG, Pinto BM, Marcus BH, . Physician-based physical activity counseling for middle-aged and older adults: a randomized trial. Ann Behav Med. 1999;21(1):40–7. PMID: 18425653. https://dx.doi.org/10.1007/BF02895032 18425653
121 Grandes G, Sanchez A, Montoya I, . Two-year longitudinal analysis of a cluster randomized trial of physical activity promotion by general practitioners. PLoS One. 2011;6(3):e18363. PMID: 21479243. https://dx.doi.org/10.1371/journal.pone.0018363 21479243
122 Grandes G, Sanchez A, Sanchez-Pinilla RO, . Effectiveness of physical activity advice and prescription by physicians in routine primary care: a cluster randomized trial. Arch Intern Med. 2009;169(7):694–701. PMID: 19364999. https://dx.doi.org/10.1001/archinternmed.2009.23 19364999
123 Green BB, McAfee T, Hindmarsh M, . Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177–83. PMID: 11897462. http://dx.doi.org/10.1016/S0749-3797(01)00428-7 11897462
124 Greenberger HM. Modifiers of the effectiveness of a diet intervention in family members of cardiovascular disease patients [Dissertation Research]. UMI Dissertation Publishing: Columbia University; 2010.
125 Greene GW, Fey-Yensan N, Padula C, . Change in fruit and vegetable intake over 24 months in older adults: results of the SENIOR project intervention. Gerontologist. 2008;48(3):378–87. PMID: 18591363. http://dx.doi.org/10.1093/geront/48.3.378 18591363
126 Greenlee H, Gaffney AO, Aycinena AC, . Cocinar Para Su Salud!: Randomized Controlled Trial of a Culturally Based Dietary Intervention among Hispanic Breast Cancer Survivors.[Reprint in J Acad Nutr Diet. 2015 May;115(5 Suppl):S42–S56.e3; PMID: 25911520]. J Acad Nutr Diet. 2015;115(5):709–23.e3. PMID: 25578926. http://dx.doi.org/10.1016/j.jand.2014.11.002 25578926
127 Halbert JA, Silagy CA, Finucane P, . Recruitment of older adults for a randomized, controlled trial of exercise advice in a general practice setting. J Am Geriatr Soc. 1999;47(4):477–81. PMID: 10203125. http://dx/doi.org/10.1111/j.1532-5415.1999.tb07242.x 10203125
128 Halbert JA, Silagy CA, Finucane PM, . Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice. Med J Aust. 2000;173(2):84–7. PMID: 10937036.10937036
129 Hall WD, Feng Z, George VA, . Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13(3):337–43. PMID: 12894958.12894958
130 Hargreaves EA, Mutrie N, Fleming JD. A Web-Based Intervention to Encourage Walking (StepWise): Pilot Randomized Controlled Trial. JMIR Res Protoc. 2016;5(1):e14. PMID: 26810251. http://dx.doi.org/10.2196/resprot.4288 26810251
131 Harland J, White M, Drinkwater C, . The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. BMJ. 1999;319(7213):828–32. PMID: 10496829.10496829
132 Harris T, Kerry SM, Victor CR, . A primary care nurse-delivered walking intervention in older adults: PACE (pedometer accelerometer consultation evaluation)-Lift cluster randomised controlled trial. PLoS Med. 2015;12(2):e1001783. PMID: 25689364. http://dx.doi.org/10.1371/journal.pmed.1001783 25689364
133 Hebert PR, Bolt RJ, Borhani NO, . Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):130–9. PMID: 7795831. http://dx.doi.org/10.1016/1047-2797(94)00057-Z 7795831
134 Hellenius ML, Dahlof C, Aberg H, . Quality of life is not negatively affected by diet and exercise intervention in healthy men with cardiovascular risk factors. Qual Life Res. 1995;4(1):13–20. PMID: 7711685.7711685
135 Hellenius ML, de FU, Berglund B, . Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. 1993;103(1):81–91. PMID: 8280188. http://dx.doi.org/10.1016/0021-9150(93)90042-S 8280188
136 Herman C, Thompson J, Wolfe V, ., editors. Six-month results from a healthy lifestyles diabetes primary prevention program among urban Native American women. American Public Health Association 134th Annual Meeting & Exposition; 2006 Nov 4; Boston, MA (USA). PMID: None.
137 Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586. http://dx.doi.org/10.1093/ajh/hpt183 24084586
138 Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39–49. PMID: 16391215. https://dx.doi.org/10.1001/jama.295.1.39 16391215
139 Howard BV, Van HL, Hsia J, . Low-fat dietary pattern and risk of cardiovascular disease: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):655–66. PMID: 16467234. https://dx.doi.org/10.1001/jama.295.6.655 16467234
140 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477. http://dx.doi.org/10.1001/archinte.1990.00390130131021 2404477
141 Jacobs N, Clays E, De BD, . Effect of a tailored behavior change program on a composite lifestyle change score: a randomized controlled trial. Health Educ Res. 2011;26(5):886–95. PMID: 21712501. https://dx.doi.org/10.1093/her/cyr046 21712501
142 Jacobs N, De BI, Thijs H, . Effect of a cardiovascular prevention program on health behavior and BMI in highly educated adults: a randomized controlled trial. Patient Educ Couns. 2011;85(1):122–6. PMID: 20888728. https://dx.doi.org/10.1016/j.pec.2010.08.024 20888728
143 Jeffery RW, French SA. Preventing weight gain in adults: the pound of prevention study. Am J Public Health. 1999;89(5):747–51. PMID: 10224988.10224988
144 John JH, Ziebland S, Yudkin P, . Effects of fruit and vegetable consumption on plasma antioxidant concentrations and blood pressure: a randomised controlled trial. Lancet. 2002;359(9322):1969–74. PMID: 12076551. http://dx.doi.org/10.1016/S0140-6736(02)98858-6 12076551
145 Kallings LV. Physical activity on prescription: studies on physical activity level, adherence, and cardiovascular risk factors [Doctoral]. Stockholm, Sweden: Karolinska Institutet; 2008.
146 Kallings LV, Sierra JJ, Fisher RM, . Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2009;16(1):80–4. PMID: 19237997. https://dx.doi.org/10.1097/HJR.0b013e32831e953a 19237997
147 Kattelmann KK, Bredbenner CB, White AA, . The effects of Young Adults Eating and Active for Health (YEAH): A theory-based web-delivered intervention. Journal of Nutrition Education and Behavior. 2014;46(6):S27–S41. PMID: None. http://dx.doi.org/10.1016/j.jneb.2014.08.007
148 Katz DL, Shuval K, Comerford BP, . Impact of an educational intervention on internal medicine residents’ physical activity counselling: the Pressure System Model. J Eval Clin Pract. 2008;14(2):294–9. PMID: 18324934. https://dx.doi.org/10.1111/j.1365-2753.2007.00853.x 18324934
149 Kerr DA, Harray AJ, Pollard CM, . The connecting health and technology study: A 6-month randomized controlled trial to improve nutrition behaviours using a mobile food record and text messaging support in young adults. Int J Behav Nutr Phys Act. 2016;13(1):52. PMID: 27098449. https://dx.doi.org/10.1186/s12966-016-0376-8 27098449
150 Kerr DA, Pollard CM, Howat P, . Connecting Health and Technology (CHAT): protocol of a randomized controlled trial to improve nutrition behaviours using mobile devices and tailored text messaging in young adults. BMC Public Health. 2012;12:477. PMID: 22726532. http://dx.doi.org/10.1186/1471-2458-12-477 22726532
151 Kerse N, Elley CR, Robinson E, . Is physical activity counseling effective for older people? A cluster randomized, controlled trial in primary care. J Am Geriatr Soc. 2005;53(11):1951–6. PMID: 16274377. https://dx.doi.org/10.1111/j.1532-5415.2005.00466.x 16274377
152 King AC, Castro CM, Buman MP, . Behavioral Impacts of Sequentially versus Simultaneously Delivered Dietary Plus Physical Activity Interventions: the CALM Trial. Ann Behav Med. 2013;46(2):157–68. PMID: 23609341. https://dx.doi.org/10.1007/s12160-013-9501-y 23609341
153 King AC, Friedman R, Marcus B, . Ongoing physical activity advice by humans versus computers: the Community Health Advice by Telephone (CHAT) trial. Health Psychol. 2007;26(6):718–27. PMID: 18020844. https://dx.doi.org/10.1037/0278-6133.26.6.718 18020844
154 Kinmonth AL, Wareham NJ, Hardeman W, . Efficacy of a theory-based behavioural intervention to increase physical activity in an at-risk group in primary care (ProActive UK): a randomised trial. Lancet. 2008;371(9606):41–8. PMID: 18177774. https://dx.doi.org/10.1016/S0140-6736(08)60070-7 18177774
155 Kolt GS, Schofield GM, Kerse N, . Effect of telephone counseling on physical activity for low-active older people in primary care: a randomized, controlled trial. J Am Geriatr Soc. 2007;55(7):986–92. PMID: 17608869. https://dx.doi.org/10.1111/j.1532-5415.2007.01203.x 17608869
156 Kristal AR, Curry SJ, Shattuck AL, . A randomized trial of a tailored, self-help dietary intervention: the Puget Sound Eating Patterns study. Prev Med. 2000;31(4):380–9. PMID: 11006063. https://dx.doi.org/10.1006/pmed.2000.0711 11006063
157 Kuller LH, Simkin-Silverman LR, Wing RR, . Women’s Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32–7. PMID: 11136682. http://dx.doi.org/10.1161/01.CIR.103.1.32 11136682
158 Kumanyika SK, Cook NR, Cutler JA, . Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. J Hum Hypertens. 2005;19(1):33–45. PMID: 15372064. https://dx.doi.org/10.1038/sj.jhh.1001774 15372064
159 Kumanyika SK, Hebert PR, Cutler JA, . Feasibility and efficacy of sodium reduction in the Trials of Hypertension Prevention, phase I. Trials of Hypertension Prevention Collaborative Research Group. Hypertension. 1993;22(4):502–12. PMID: 8406655. http://dx.doi.org/10.1161/01.HYP.22.4.502 8406655
160 Lawton BA, Rose SB, Elley CR, . Exercise on prescription for women aged 40–74 recruited through primary care: two year randomised controlled trial. BMJ. 2008;337:a2509. PMID: 19074218. http://dx.doi.org/10.1136/bmj.a2509 19074218
161 Lewis BA, Williams DM, Martinson BC, . Healthy for life: A randomized trial examining physical activity outcomes and psychosocial mediators. Ann Behav Med. 2013;45(2):203–12. PMID: 23229158. https://dx.doi.org/10.1007/s12160-012-9439-5 23229158
162 Lutz SF, Ammerman AS, Atwood JR, . Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99(6):705–9. PMID: 10361533. https://dx.doi.org/10.1016/S0002-8223(99)00169-8 10361533
163 Magnan RE, Nilsson R, Marcus BH, . A transdisciplinary approach to the selection of moderators of an exercise promotion intervention: baseline data and rationale for Colorado STRIDE. J Behav Med. 2013;36(1):20–33. PMID: 22083142. https://dx.doi.org/10.1007/s10865-011-9385-x 22083142
164 Mailey EL, McAuley E. Impact of a brief intervention on physical activity and social cognitive determinants among working mothers: a randomized trial. J Behav Med. 2014;37(2):343–55. PMID: 23338616. http://dx.doi.org/10.1007/s10865-013-9492-y 23338616
165 Marcus BH, Dunsiger SI, Pekmezi D, . Twelve-month physical activity outcomes in Latinas in the Seamos Saludables trial. Am J Prev Med. 2015;48(2):179–82. PMID: 25442225. http://dx.doi.org/10.1016/j.amepre.2014.08.032 25442225
166 Marcus BH, Dunsiger SI, Pekmezi DW, . The Seamos Saludables study: A randomized controlled physical activity trial of Latinas. Am J Prev Med. 2013;45(5):598–605. PMID: 24139773. http://dx.doi.org/10.1016/j.amepre.2013.07.006 24139773
167 Marcus BH, Napolitano MA, King AC, . Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol. 2007;26(4):401–9. PMID: 17605559. https://dx.doi.org/10.1037/0278-6133.26.4.401 17605559
168 Marcus BH, Napolitano MA, King AC, . Examination of print and telephone channels for physical activity promotion: Rationale, design, and baseline data from Project STRIDE. Contemp Clin Trials. 2007;28(1):90–104. PMID: 16839823. http://dx.doi.org/10.1016/j.cct.2006.04.003 16839823
169 Marsaux CF, Celis-Morales C, Fallaize R, . Effects of a Web-Based Personalized Intervention on Physical Activity in European Adults: A Randomized Controlled Trial. J Med Internet Res. 2015;17(10):e231. PMID: 26467573. http://dx.doi.org/10.2196/jmir.4660 26467573
170 Marshall AL, Bauman AE, Owen N, . Population-based randomized controlled trial of a stage-targeted physical activity intervention. Ann Behav Med. 2003;25(3):194–202. PMID: 12763714.12763714
171 Marshall AL, Miller YD, Graves N, . Moving MobileMums forward: protocol for a larger randomized controlled trial of an improved physical activity program for women with young children. BMC Public Health. 2013;13(1):593. PMID: 23777245. https://dx.doi.org/10.1186/1471-2458-13-593 23777245
172 Martinson BC, Crain AL, Sherwood NE, . Maintaining physical activity among older adults: six-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev Med. 2008;46(2):111–9. PMID: 17904629. https://dx.doi.org/10.1016/j.ypmed.2007.08.007 17904629
173 Martinson BC, Sherwood NE, Crain AL, . Maintaining physical activity among older adults: 24-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev Med. 2010. PMID: 20382179. https://dx.doi.org/10.1016/j.ypmed.2010.04.002 20382179
174 Meinert CL, Borhani NO, Langford HG. Design, methods, and rationale in the Hypertension Prevention Trial. Hypertension Prevention Trial Research Group. Control Clin Trials. 1989;10(3 Suppl):1S–29S. PMID: 2680271.2680271
175 Mochari-Greenberger H, Terry MB, Mosca L. Sex, age, and race/ethnicity do not modify the effectiveness of a diet intervention among family members of hospitalized cardiovascular disease patients. J Nutr Educ Behav. 2011;43(5):366–73. PMID: 21906549. https://dx.doi.org/10.1016/j.jneb.2011.01.014 21906549
176 Mosca L, Mochari H, Liao M, . A novel family-based intervention trial to improve heart health: FIT Heart: results of a randomized controlled trial. Circ Cardiovasc Qual Outcomes. 2008;1(2):98–106. PMID: 20031796. https://dx.doi.org/10.1161/CIRCOUTCOMES.108.825786 20031796
177 Napolitano MA, Whiteley JA, Papandonatos G, . Outcomes from the women’s wellness project: a community-focused physical activity trial for women. Prev Med. 2006;43(6):447–53. PMID: 16919322. https://dx.doi.org/10.1016/j.ypmed.2006.06.011 16919322
178 Nishigaki M, Tokunaga-Nakawatase Y, Nishida J, . Randomized controlled trial of the effectiveness of genetic counseling and a distance, computer-based, lifestyle intervention program for adult offspring of patients with type 2 diabetes: background, study protocol, and baseline patient characteristics. J Nutr Metab. 2012;2012:831735. PMID: 22619705. http://dx.doi.org/10.1155/2012/831735 22619705
179 Norris SL, Grothaus LC, Buchner DM, . Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30(6):513–23. PMID: 10901494. https://dx.doi.org/10.1006/pmed.2000.0673 10901494
180 O’Neill SM, Rubinstein WS, Wang C, . Familial risk for common diseases in primary care: the Family Healthware Impact Trial. Am J Prev Med. 2009;36(6):506–14. PMID: 19460658. http://dx.doi.org/10.1016/j.amepre.2009.03.002 19460658
181 Parekh S, King D, Boyle FM, . Randomized controlled trial of a computer-tailored multiple health behaviour intervention in general practice: 12-month follow-up results. Int J Behav Nutr Phys Act. 2014;11(1):41. PMID: 24646165. http://dx.doi.org/10.1186/1479-5868-11-41 24646165
182 Parekh S, Vandelanotte C, King D, . Design and baseline characteristics of the 10 Small Steps Study: a randomised controlled trial of an intervention to promote healthy behaviour using a lifestyle score and personalised feedback. BMC Public Health. 2012;12:179. PMID: 22405027. https://dx.doi.org/10.1186/1471-2458-12-179 22405027
183 Pekmezi D, Dunsiger S, Gans K, . Rationale, design, and baseline findings from Seamos Saludables: a randomized controlled trial testing the efficacy of a culturally and linguistically adapted, computer- tailored physical activity intervention for Latinas. Contemp Clin Trials. 2012;33(6):1261–71. PMID: 22789455. https://dx.doi.org/10.1016/j.cct.2012.07.005 22789455
184 Pekmezi DW, Neighbors CJ, Lee CS, . A culturally adapted physical activity intervention for Latinas: a randomized controlled trial. Am J Prev Med. 2009;37(6):495–500. PMID: 19944914. https://dx.doi.org/10.1016/j.amepre.2009.08.023 19944914
185 Pinto BM, Friedman R, Marcus BH, . Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23(2):113–20. PMID: 12121799. http://dx.doi.org/10.1016/S0749-3797(02)00441-5 12121799
186 Pinto BM, Goldstein MG, Ashba J, . Randomized controlled trial of physical activity counseling for older primary care patients. Am J Prev Med. 2005;29(4):247–55. PMID: 16242586. https://dx.doi.org/10.1016/j.amepre.2005.06.016 16242586
187 Pinto BM, Goldstein MG, DePue JD, . Acceptability and feasibility of physician-based activity counseling. The PAL project. Am J Prev Med. 1998;15(2):95–102. PMID: 9713664. http://dx.doi.org/10.1016/S0749-3797(98)00043-9 9713664
188 Roderick P, Ruddock V, Hunt P, . A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47(414):7–12. PMID: 9115804.9115804
189 Ruffin MT, Nease DE, Jr., Sen A, . Effect of preventive messages tailored to family history on health behaviors: the Family Healthware Impact Trial. Ann Fam Med. 2011;9(1):3–11. PMID: 21242555. https://dx.doi.org/10.1370/afm.1197 21242555
190 Sacerdote C, Fiorini L, Rosato R, . Randomized controlled trial: effect of nutritional counselling in general practice. Int J Epidemiol. 2006;35(2):409–15. PMID: 16157616. https://dx.doi.org/10.1093/ije/dyi170 16157616
191 Satterfield S, Cutler JA, Langford HG, . Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1(5):455–71. PMID: 1669525.1669525
192 Shah M, Jeffery RW, Laing B, . Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69–76. PMID: 2404050.2404050
193 Sherwood NE, Martinson BC, Crain AL, . A new approach to physical activity maintenance: rationale, design, and baseline data from the Keep Active Minnesota Trial. BMC Geriatr. 2008;8:17. PMID: 18655709. https://dx.doi.org/10.1186/1471-2318-8-17 18655709
194 Simkin-Silverman L, Wing RR, Hansen DH, . Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24(5):509–17. PMID: 8524727. http://dx.doi.org/10.1006/pmed.1995.1081 8524727
195 Simkin-Silverman LR, Wing RR, Boraz MA, . Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26(3):212–20. PMID: 14644697.14644697
196 Simkin-Silverman LR, Wing RR, Boraz MA, . Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4(3):255–71. PMID: 9787651.9787651
197 Smith BJ, Cinnadaio N, Cheung NW, . Investigation of a lifestyle change strategy for high-risk women with a history of gestational diabetes. Diabetes Res Clin Pract. 2014;106(3):e60–3. PMID: 25451910. http://dx.doi.org/10.1016/j.diabres.2014.09.035 25451910
198 Springvloet L, Lechner L, de Vries H, . Short- and medium-term efficacy of a Web-based computer-tailored nutrition education intervention for adults including cognitive and environmental feedback: randomized controlled trial. J Med Internet Res. 2015;17(1):e23. PMID: 25599828. http://dx.doi.org/10.2196/jmir.3837 25599828
199 Springvloet L, Lechner L, de Vries H, . Long-term efficacy of a Web-based computer-tailored nutrition education intervention for adults including cognitive and environmental feedback: a randomized controlled trial. BMC Public Health. 2015;15:372. PMID: 25887891. http://dx.doi.org/10.1186/s12889-015-1707-4 25887891
200 Springvloet L, Lechner L, Oenema A. Planned development and evaluation protocol of two versions of a web-based computer-tailored nutrition education intervention aimed at adults, including cognitive and environmental feedback. BMC Public Health. 2014;14:47. PMID: 24438381. http://dx.doi.org/10.1186/1471-2458-14-47 24438381
201 Stewart AL, Verboncoeur CJ, McLellan BY, . Physical activity outcomes of CHAMPS II: a physical activity promotion program for older adults. J Gerontol A Biol Sci Med Sci. 2001;56(8):M465–M70. PMID: 11487597. http://dx.doi.org/10.1093/gerona/56.8.M465 11487597
202 Stopponi MA, Alexander GL, McClure JB, . Recruitment to a randomized web-based nutritional intervention trial: characteristics of participants compared to non-participants. J Med Internet Res. 2009;11(3):e38. PMID: 19709990. http://dx.doi.org/10.2196/jmir.1086 19709990
203 Taveras EM, Blackburn K, Gillman MW, . First steps for mommy and me: a pilot intervention to improve nutrition and physical activity behaviors of postpartum mothers and their infants. Matern Child Health J. 2011;15(8):1217–27. PMID: 20957514. https://dx.doi.org/10.1007/s10995-010-0696-2 20957514
204 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. http://dx.doi.org/10.1001/jama.1992.03480090061028 1586398
205 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920. http://dx.doi.org/10.1001/archinte.1997.00440270105009 9080920
206 The Women’s Health Initiative Study Group. Design of the Women’s Health Initiative clinical trial and observational study.. Control Clin Trials. 1998;19(1):61–109. PMID: 9492970. http://dx.doi.org/10.1016/S0197-2456(97)00078-0 9492970
207 Thompson JL, Allen P, Helitzer DL, . Reducing diabetes risk in American Indian women. Am J Prev Med. 2008;34(3):192–201. PMID: 18312806. https://dx.doi.org/10.1016/j.amepre.2007.11.014 18312806
208 Thompson WG, Kuhle CL, Koepp GA, . “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Arch Gerontol Geriatr. 2014;58(3):314–9. PMID: 24485546. http://dx.doi.org/10.1016/j.archger.2014.01.004 24485546
209 Tinker LF, Bonds DE, Margolis KL, . Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women’s Health Initiative randomized controlled dietary modification trial. Arch Intern Med. 2008;168(14):1500–11. PMID: 18663162. https://dx.doi.org/10.1001/archinte.168.14.1500 18663162
210 Tokunaga-Nakawatase Y, Nishigaki M, Taru C, . Computer-supported indirect-form lifestyle-modification support program using Lifestyle Intervention Support Software for Diabetes Prevention (LISS-DP) for people with a family history of type 2 diabetes in a medical checkup setting: A randomized controlled trial. Prim Care Diabetes. 2014;8(3):207–14. PMID: 24529485. http://dx.doi.org/10.1016/j.pcd.2014.01.007 24529485
211 Valve P, Lehtinen-Jacks S, Eriksson T, . LINDA - a solution-focused low-intensity intervention aimed at improving health behaviors of young females: a cluster-randomized controlled trial. BMC Public Health. 2013;13:1044. PMID: 24188719. http://dx.doi.org/10.1186/1471-2458-13-1044 24188719
212 Van Hoecke AS, Delecluse C, Bogaerts A, . The long-term effectiveness of need-supportive physical activity counseling compared with a standard referral in sedentary older adults. J Aging Phys Act. 2014;22(2):186–98. PMID: 23628840. http://dx.doi.org/10.1123/japa.2012-0261 23628840
213 Van Hoecke AS, Delecluse C, Bogaerts A, . Effects of need-supportive physical activity counseling on well-being: a 2-year follow-up among sedentary older adults. J Phys Act Health. 2014;11(8):1492–502. PMID: 24384675. http://dx.doi.org/10.1123/jpah.2012-0497 24384675
214 van Stralen MM, de VH, Bolman C, . Exploring the efficacy and moderators of two computer-tailored physical activity interventions for older adults: a randomized controlled trial. Ann Behav Med. 2010;39(2):139–50. PMID: 20182833. https://dx.doi.org/10.1007/s12160-010-9166-8 20182833
215 van Stralen MM, de VH, Mudde AN, . The long-term efficacy of two computer-tailored physical activity interventions for older adults: main effects and mediators. Health Psychol. 2011;30(4):442–52. PMID: 21639638. https://dx.doi.org/10.1037/a0023579 21639638
216 van Stralen MM, de Vries H, Mudde AN, . Efficacy of two tailored interventions promoting physical activity in older adults. Am J Prev Med. 2009;37(5):405–17. PMID: 19840695. http://dx.doi.org/10.1016/j.amepre.2009.07.009 19840695
217 Vandelanotte C, De B, I, Sallis JF, . Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med. 2005;29(2):138–46. PMID: 15823787. https://dx.doi.org/10.1207/s15324796abm2902_8 15823787
218 Vrdoljak D, Markovic BB, Puljak L, . Lifestyle intervention in general practice for physical activity, smoking, alcohol consumption and diet in elderly: a randomized controlled trial. Arch Gerontol Geriatr. 2014;58(1):160–9. PMID: 24012131. https://dx.doi.org/10.1016/j.archger.2013.08.007 24012131
219 Wadsworth DD, Hallam JS. Effect of a web site intervention on physical activity of college females. Am J Health Behav. 2010;34(1):60–9. PMID: 19663753. https://doi.org/10.5993/AJHB.34.1.8 19663753
220 Warner LM, Wolff JK, Ziegelmann JP, . Revisiting self-regulatory techniques to promote physical activity in older adults: null-findings from a randomised controlled trial. Psychol Health. 2016:1–21. PMID: 27145328. http://dx.doi.org/10.1080/08870446.2016.1185523 27145328
221 Williams K, Prevost AT, Griffin S, . The ProActive trial protocol - a randomised controlled trial of the efficacy of a family-based, domiciliary intervention programme to increase physical activity among individuals at high risk of diabetes [ISRCTN61323766]. BMC Public Health. 2004;4:48. PMID: 15491494. https://dx.doi.org/10.1186/1471-2458-4-48 15491494
222 Rees K, Dyakova M, Ward K, . Dietary advice for reducing cardiovascular risk. Cochrane Database Syst Rev. 2013;3:CD002128. PMID: 23543514. http://dx.doi.org/10.1002/14651858.CD002128.pub4 23543514
223 Hartley L, Igbinedion E, Holmes J, . Increased consumption of fruit and vegetables for the primary prevention of cardiovascular diseases. Cochrane Database Syst Rev. 2013(6):CD009874. PMID: 23736950. https://dx.doi.org/10.1002/14651858.CD009874.pub2 23736950
224 Hooper L, Summerbell CD, Thompson R, . Reduced or modified dietary fat for preventing cardiovascular disease. Cochrane Database Syst Rev. 2012;5:CD002137. PMID: 22592684. http://dx.doi.org/10.1002/14651858.CD002137.pub3 22592684
225 Hooper L, Martin N, Abdelhamid A, . Reduction in saturated fat intake for cardiovascular disease. Cochrane Database Syst Rev. 2015;6:CD011737. PMID: 26068959. http://dx.doi.org/10.1002/14651858.CD011737 26068959
226 Hartley L, May MD, Loveman E, . Dietary fibre for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2016;1:CD011472. PMID: 26758499. http://dx.doi.org/10.1002/14651858.CD011472.pub2 26758499
227 Rees K, Hartley L, Clarke A, . ‘Mediterranean’ dietary pattern for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2012;2012. (4)PMID: 25267918. http://dx.doi.org/10.1002/14651858.cd009825 25267918
228 Richards J, Hillsdon M, Thorogood M, . Face-to-face interventions for promoting physical activity. Cochrane Database Syst Rev. 2013;9:CD010392. PMID: 24085592. http://dx.doi.org/10.1002/14651858.CD010392.pub2 24085592
229 Richards J, Thorogood M, Hillsdon M, . Face-to-face versus remote and web 2.0 interventions for promoting physical activity. Cochrane Database Syst Rev. 2013(9):CD010393. PMID: 24085593. https://dx.doi.org/10.1002/14651858.CD010393.pub2 24085593
230 National Institute for Health and Care Excellence. Exercise referral schemes to promote physical activity. Public health guideline [PH54]. United Kingdom: NICE; 2014. PMID: None.
231 National Institute for Health and Care Excellence. Physical activity: brief advice for adults in primary care. Public health guideline [PH44]. United Kingdom: NICE; 2013. PMID: None.
232 Campbell F, Blank L, Messina J, . Physical Activity: Brief advice for adults in primary care (National Institute for Health and Clinical Excellence Public Health Intervention Guidance). United Kingdom: NICE Centre for Public Health Excellence; 2012. PMID: None.
233 Pavey TG, Anokye N, Taylor AH, . The clinical effectiveness and cost-effectiveness of exercise referral schemes: a systematic review and economic evaluation. Health Technol Assess. 2011;15(44):i–xii, 1–254. PMID: 22182828. https://dx.doi.org/10.3310/hta15440 22182828
234 Lewington S, Clarke R, Qizilbash N, . Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903–13. PMID: 12493255. http://dx.doi.org/10.1016/S0140-6736(02)11911-8 12493255
235 Prospective Studies Collaboration, Lewington S, Whitlock G, . Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet. 2007;370(9602):1829–39. PMID: 18061058. http://dx.doi.org/10.1016/S0140-6736(07)61778-4 18061058
236 Blood Pressure Lowering Treatment Trialists C, Sundstrom J, Arima H, . Blood pressure-lowering treatment based on cardiovascular risk: a meta-analysis of individual patient data. Lancet. 2014;384(9943):591–8. PMID: 25131978. http://dx.doi.org/10.1016/S0140-6736(14)61212-5 25131978
237 Ettehad D, Emdin CA, Kiran A, . Blood pressure lowering for prevention of cardiovascular disease and death: a systematic review and meta-analysis. Lancet. 2016;387(10022):957–67. PMID: 26724178. http://dx.doi.org/10.1016/S0140-6736(15)01225-8 26724178
238 Emerging Risk Factors Collaboration, Seshasai SR, Kaptoge S, . Diabetes mellitus, fasting glucose, and risk of cause-specific death. N Engl J Med. 2011;364(9):829–41. PMID: 21366474. http://dx.doi.org/10.1056/NEJMoa1008862 21366474
239 Emerging Risk Factors Collaboration, Sarwar N, Gao P, . Diabetes mellitus, fasting blood glucose concentration, and risk of vascular disease: a collaborative meta-analysis of 102 prospective studies. Lancet. 2010;375(9733):2215–22. PMID: 20609967. http://dx.doi.org/10.1016/S0140-6736(10)60484-9 20609967
240 Afzal S, Tybjaerg-Hansen A, Jensen GB, . Change in Body Mass Index Associated With Lowest Mortality in Denmark, 1976–2013. JAMA. 2016;315(18):1989–96. PMID: 27163987. http://dx.doi.org/10.1001/jama.2016.4666 27163987
241 Wang X, Ouyang Y, Liu J, . Fruit and vegetable consumption and mortality from all causes, cardiovascular disease, and cancer: systematic review and dose-response meta-analysis of prospective cohort studies. BMJ. 2014;349:g4490. PMID: 25073782. http://dx.doi.org/10.1136/bmj.g4490 25073782
242 Li Y, Hruby A, Bernstein AM, . Saturated Fats Compared With Unsaturated Fats and Sources of Carbohydrates in Relation to Risk of Coronary Heart Disease: A Prospective Cohort Study. J Am Coll Cardiol. 2015;66(14):1538–48. PMID: 26429077. http://dx.doi.org/10.1016/j.jacc.2015.07.055 26429077
243 Prentice RL, Caan B, Chlebowski RT, . Low-fat dietary pattern and risk of invasive breast cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):629–42. PMID: 16467232. https://dx.doi.org/10.1001/jama.295.6.629 16467232
244 Beresford SA, Johnson KC, Ritenbaugh C, . Low-fat dietary pattern and risk of colorectal cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643–54. PMID: 16467233. http://dx.doi.org/10.1001/jama.295.6.643 16467233
245 Wang JB, Cadmus-Bertram LA, Natarajan L, . Wearable sensor/device (Fitbit One) and SMS text-messaging prompts to increase physical activity in overweight and obese adults: A randomized controlled trial. Telemed J E Health. 2015;21(10):782–92. PMID: 26431257. http://dx.doi.org/10.1089/tmj.2014.0176 26431257
246 Physical Activity Guidelines Advisory Committee. Physical Activity Guidelines Advisory Committee Report, 2008. Washington, DC: U.S. Department of Health and Human Services; 2008. PMID: None.
247 Arem H, Moore SC, Patel A, . Leisure time physical activity and mortality: a detailed pooled analysis of the dose-response relationship. JAMA Intern Med. 2015;175(6):959–67. PMID: 25844730. http://dx.doi.org/10.1001/jamainternmed.2015.0533 25844730
248 Wen CP, Wai JP, Tsai MK, . Minimum amount of physical activity for reduced mortality and extended life expectancy: a prospective cohort study. Lancet. 2011;378(9798):1244–53. PMID: 21846575. https://dx.doi.org/10.1016/S0140-6736(11)60749-6 21846575
249 Brown DW, Balluz LS, Heath GW, . Associations between recommended levels of physical activity and health-related quality of life. Findings from the 2001 Behavioral Risk Factor Surveillance System (BRFSS) survey. Prev Med. 2003;37(5):520–8. PMID: 14572437. http://dx.doi.org/10.1016/S0091-7435(03)00179-8 14572437
250 Kruger J, Bowles HR, Jones DA, . Health-related quality of life, BMI and physical activity among US adults (>/=18 years): National Physical Activity and Weight Loss Survey, 2002. Int J Obes (Lond). 2007;31(2):321–7. PMID: 16703001. http://dx.doi.org/10.1038/sj.ijo.0803386 16703001
251 Wolin KY, Glynn RJ, Colditz GA, . Long-term physical activity patterns and health-related quality of life in U.S. women. Am J Prev Med. 2007;32(6):490–9. PMID: 17533064. http://dx.doi.org/10.1016/j.amepre.2007.02.014 17533064
252 Tessier S, Vuillemin A, Bertrais S, . Association between leisure-time physical activity and health-related quality of life changes over time. Prev Med. 2007;44(3):202–8. PMID: 17208289. http://dx.doi.org/10.1016/j.ypmed.2006.11.012 17208289
253 Wendel-Vos GC, Schuit AJ, Tijhuis MA, . Leisure time physical activity and health-related quality of life: cross-sectional and longitudinal associations. Qual Life Res. 2004;13(3):667–77. PMID: 15130029. https://dx.doi.org/10.1023/B:QURE.0000021313.51397.33 15130029
254 Goodman JM, Burr JF, Banks L, . The Acute Risks of Exercise in Apparently Healthy Adults and Relevance for Prevention of Cardiovascular Events. Can J Cardiol. 2016;32(4):523–32. PMID: 27017149. http://dx.doi.org/10.1016/j.cjca.2016.01.019 27017149
255 LeBlanc ES, O’Connor E, Whitlock EP, . Effectiveness of primary care-relevant treatments for obesity in adults: a systematic evidence review for the US preventive services task force. Ann Intern Med. 2011;155(7):434–47. PMID: 21969342. https://dx.doi.org/10.7326/0003-4819-155-7-201110040-00006 21969342
256 Curry SJ, McNellis RJ. Behavioral Counseling in Primary Care: Perspectives in Enhancing the Evidence Base. Am J Prev Med. 2015;49(3 Suppl 2):S125–8. PMID: 26296546. http://dx.doi.org/10.1016/j.amepre.2015.06.004 26296546
257 McNellis RJ, Ory MG, Lin JS, . Standards of evidence for behavioral counseling recommendations. Am J Prev Med. 2015;49(3 Suppl 2):S150–7. PMID: 26296549. http://dx.doi.org/10.1016/j.amepre.2015.06.002 26296549
258 Krist AH, Baumann LJ, Holtrop JS, . Evaluating Feasible and Referable Behavioral Counseling Interventions. Am J Prev Med. 2015;49(3 Suppl 2):S138–49. PMID: 26296548. http://dx.doi.org/10.1016/j.amepre.2015.05.009 26296548
259 Kurth AE, Miller TL, Woo M, . Understanding Research Gaps and Priorities for Improving Behavioral Counseling Interventions: Lessons Learned From the U.S. Preventive Services Task Force. Am J Prev Med. 2015;49(3 Suppl 2):S158–65. PMID: 26296550. http://dx.doi.org/10.1016/j.amepre.2015.06.007 26296550
260 Community Preventive Services Task Force. The Guide to Community Preventive Services: Increasing Physical Activity. http://www.thecommunityguide.org/pa/index.html. Accessed May 13, 2016. PMID: None.
261 National Cancer Institute. Research-tested Intervention Program (RTIPs). Diet/Nutition Intervention Programs. http://rtips.cancer.gov/rtips/topicPrograms.do?topicId=102266&choice=default. Accessed May 13, 2016. PMID: None.
262 Grant RW, Schmittdiel JA, Neugebauer RS, . Exercise as a vital sign: A quasi-experimental analysis of a health system intervention to collect patient-reported exercise levels. J Gen Intern Med. 2014;29(2):341–8. PMID: 24309950. http://dx.doi.org/10.1007/s11606-013-2693-9 24309950
263 Svetkey LP, Harsha DW, Vollmer WM, . Premier: a clinical trial of comprehensive lifestyle modification for blood pressure control: rationale, design and baseline characteristics. Ann Epidemiol. 2003;13(6):462–71. PMID: 12875806. http://dx.doi.org/10.1016/S1047-2797(03)00006-1 12875806
264 Writing Group for the Activity Counseling Trial Research Group. Effects of physical activity counseling in primary care: the Activity Counseling Trial: a randomized controlled trial. JAMA. 2001;286(6):677–87. PMID: 11495617. http://dx.doi.org/10.1001/jama.286.6.677 11495617
265 Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119(15):2026–31. PMID: 19349322. http://dx.doi.org/10.1161/CIRCULATIONAHA.108.809491 19349322
266 Block G, Hartman AM, Dresser CM, . A data-based approach to diet questionnaire design and testing. Am J Epidemiol. 1986;124(3):453–69. PMID: 3740045.3740045
267 Block G, Woods M, Potosky A, . Validation of a self-administered diet history questionnaire using multiple diet records. J Clin Epidemiol. 1990;43(12):1327–35. PMID: 2254769.2254769
268 Newell SA, Girgis A, Sanson-Fisher RW, . The accuracy of self-reported health behaviors and risk factors relating to cancer and cardiovascular disease in the general population: a critical review. Am J Prev Med. 1999;17(3):211–29. PMID: 10987638. http://dx.doi.org/10.1016/S0749-3797(99)00069-0 10987638
269 Parker DR, Evangelou E, Eaton CB. Intraclass correlation coefficients for cluster randomized trials in primary care: the cholesterol education and research trial (CEART). Contemp Clin Trials. 2005;26(2):260–7. PMID: 15837446. https://dx.doi.org/10.1016/j.cct.2005.01.002 15837446
270 IntHout J, Ioannidis J, Borm G. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. PMID: 24548571.24548571
271 Fontanarosa P, Christiansen S. Conventional Units and SI Units in JAMA and the Archives Journals. AMA Manual of Style: A Guide for Authors and Editors (10th edition). Oxford, UK: Oxford University Press; 2007.