# Acknowledgments

We gratefully acknowledge the following individuals for their contributions to this project: Keshia Bigler, MPH, for assistance with data abstraction; Smyth Lai, MLS, for creating and conducting literature searches; Erin Coppola, BS, for assistance with report preparation; Elizabeth O’Connor, PhD, and Ning Smith, PhD, for statistical assistance; and Elizabeth Hess, BA, ESL(D), for editorial support. We also thank Paul James, MD, Sarah Lewington, BSc, MSc, DPhil, Alice Lichtenstein, DSc, JoAnn Manson, MD, DrPH, and Deborah Young, PhD, who provided expert review; David Brown, PhD, at the Centers for Disease Control and Prevention, S. Sonia Arteaga, PhD, Rachel Ballard, MD, MPH, Josephine Boyington, PhD, MPH, Janet de Jesus, MS, RD, Christine Hunter, PhD, Peter Kaufmann, PhD, Charlotte Pratt, PhD, RD, and Deborah Young-Hyman, PhD, at the National Institutes of Health, Michael Bartholomew, MD, at the Indian Health Service, and Michael Goldstein, MD, at the Department of Veterans Affairs, who provided federal partner review. We also thank David Meyers, MD, and Quyen Ngo-Metzger, MD, MPH, at AHRQ, and Jennifer Croswell, MD, formerly at AHRQ, as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.