# 4 Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in updating its 2012 recommendation on healthful diet and physical activity counseling for the primary prevention of CVD.^1^ The current review focused specifically on the effectiveness and harms of primary care–relevant interventions in persons without known CVD or CVD risk factors. We included 88 unique trials, nearly a half of which (k=38) were published since the previous USPSTF review in 2010. The pooled effect estimates found in our updated systematic review are generally consistent in magnitude with the 2010 review on this topic^40^ and slightly lower in magnitude than the effects seen with our 2014 review among persons at high risk for CVD.^65^ The number of studies that contributed to each meta-analysis generally stayed the same or increased slightly but included higher quality and more relevant literature. Most of the new evidence (28 of 38 trials) focused on increasing physical activity among persons with low levels of physical activity and found consistent evidence of small to moderate increases in physical activity.

Table 8 summarizes the findings for this evidence review. We found that healthful diet and physical activity behavioral interventions in persons generally without traditional CVD risk factors were associated with modest reductions in blood pressure, total and LDL cholesterol, and adiposity measures at approximately 6 to 12 months of followup compared with control conditions. Given the consistency in the effect estimates and precision in those estimates over time for each intermediate outcome, we are moderately confident that our pooled estimates lie close to the true effects, although the body of evidence is still fairly small (<20 trials for most outcomes) and there is considerable variation in the interventions. Pooled analyses resulted in moderate or substantial statistical heterogeneity, reflecting the clinical heterogeneity across studies. There was evidence of a dose-response relationship, with increasing intervention intensity being associated with larger improvements in intermediate outcomes, but there was insufficient evidence to assess the effects of low-intensity interventions alone on intermediate outcomes. Most of the medium- to high-intensity interventions for which we saw a benefit on intermediate outcomes included healthful diet messages, with or without physical activity messages, and recruited persons outside of the primary care setting; thus, these interventions may have limited applicability to a general, unselected population. There was considerably more evidence for behavioral outcomes, with 86 trials reporting the effects of counseling interventions on dietary intake, physical activity, and/or sedentary behaviors. The directions of effects for all behavioral outcomes were reasonably consistent and suggested generally a small benefit for dietary outcomes and a moderate benefit for physical activity. However, there was substantial variation in outcomes measures and insufficient evidence on the effects of interventions on sedentary behaviors. Moreover, data on the long-term effects of the interventions on behavioral or intermediate health outcomes were limited.

Table 8 Summary of Evidence, by Key Question

No. of RCTs (k), No. of obs (n) | Summary of findings by outcome | Consistency/precision | Reporting bias | Study quality | Body of evidence limitations | EPC assessment of strength of evidence | Applicability
KQ 1. Health outcomes
k=12 n=58,848 (2/12 trials identified in update; both new studies reported QOL outcomes) | No difference in all-cause or CVD-related mortality in high-intensity diet-only interventions at 3 to 15 years FU (k=4, n=51,356). Mixed findings for effects on CVD events in 3 high-intensity diet-only interventions at 8 to 15 years FU. Largest trial in postmenopausal women (n=48,835) found no difference in major CVD events or stroke among women without a history of CVD over 8.1 years FU. No consistent benefit of interventions on QOL at 6 to 12 months (k=10, n=52,423). | Reasonably consistent^*^ Imprecise | Undetected for mortality and CVD events Suspected for QOL^†^ | Good: 5 Fair: 7 | Data from 2 trials based on observational FU after trials were completed. Few studies reported QOL measures; most reported domain-specific QOL instead of summary scores. | Low | Mortality and CVD event data limited to high-intensity diet-only interventions and most studies were among adults with high-normal BP. Largest trial in postmenopausal women. QOL data limited to mostly physical activity trials.
KQ 2. Intermediate outcomes
k=34 n=75,793 (10/34 trials identified in update) | Small, statistically significant improvements in systolic (−1.26 mm Hg [95% CI, −1.77 to −0.76], k=22) and diastolic blood pressure (−0.49 mm Hg [95% CI, −0.82 to −0.16], k=23), LDL cholesterol (−2.58 mg/dL [95% CI, −4.30 to −0.85], k=13), total cholesterol (−2.85 mg/dL [95% CI, −4.95 to −0.75], k=19), and adiposity outcomes (BMI, −0.41 kg/m^2^ [95% CI, −0.62 to −0.19], k=20) at 6 to 12 months associated with healthful diet and/or physical activity interventions. Evidence of dose-response effect with increasing intervention intensity associated with larger improvements in intermediate outcomes. Insufficient evidence to assess the effects of low-intensity interventions alone. No evidence of an association with HDL cholesterol, triglycerides, or fasting glucose. | Consistency and precision varied across intermediate outcomes; more consistent and precise for blood pressure and LDL cholesterol^‡^ | Undetected | Good: 13 Fair: 21 | Considerable statistical heterogeneity (I^2^>90%) for meta-analyses of adiposity outcomes. Limited evidence beyond 12 months or for incidence of hypertension, dyslipidemia, or diabetes. | Moderate | Generally applicable to adults not at risk for CVD. Intensity of intervention confounded with setting; high-intensity interventions were more likely to take place outside of primary care and show effectiveness. Few physical activity-focused trials reported intermediate outcomes.
KQ3. Behavioral outcomes
k=86^§^ n=117,589 (36/86 trials identified in update) | Magnitude and precision in differences for dietary outcomes were quite variable across studies and resulted in considerable heterogeneity in meta-analysis. Between-group differences for dietary outcomes were in the magnitude of 65 (favoring the control group) to −500 kcal/day (favoring the intervention group) in total energy intake (k=11), 0.8 to −11 percentage points in the percent of calories from fat (k=15) and −0.3 to −4.1 percentage points in the percent of calories from saturated fat (k=9), and approximately −380 to nearly −1,400 mg/day of sodium (k=6). Effects on fruit and vegetable intake ranged from between-group differences of −0.2 servings/day (favoring the control group) to 2.2 servings/day (favoring the intervention group) (k=16); between-group differences in grams of fiber per day ranged from 1 to 2.5 g/day in favor of the intervention group (k=6). Small, statistically significant association with behavioral interventions and physical activity in favor of interventions over controls (SMD, 0.20 [95% CI, 0.14 to 0.26], k=46). An analysis of minutes per week of physical activity found difference of approximately 35 min/week of physical activity between groups (MD, 34.5 min/week [95% CI, 22.0 to 47.0], k=27). Significantly higher odds of meeting PA recommendations (150 min/week of PA) among intervention vs. control group participants (OR, 1.32 [95% CI, 1.12 to 1.64], k=16). Effects on cardiorespiratory fitness were generally consistent with results for self-reported physical activity. Insufficient evidence for sedentary behaviors. | Reasonably consistent Imprecise | Undetected | Good: 18 Fair: 68 | Almost all outcomes based on self-report. Instruments, recall periods, and summary measures were extremely heterogeneous, with varying evidence of validity and reliability. Few interventions incorporated messages to decrease sedentary behavior. | Low | Generally applicable to adults not at risk for CVD. Larger effect sizes for physical activity outcomes were seen for persons with lower levels of physical activity at baseline. Most trials that reported a physical activity outcome were of low or medium intensity.
KQ 4. Harms
k=14 n=8,220 (7/14 trials identified in update) | No serious adverse events related to behavioral interventions (k=8). Seven physical activity trials generally found no differences in rates of injuries, fractures, falls, or CV events. Only one trial among women ages 40–74 years found significantly more injuries and falls among intervention vs. control group participants. | Reasonably consistent Precise | Undetected | Good: 7 Fair: 7 | Harms sparsely reported for included trials. Few details provided about how harms were recorded and specific events that occurred. | Moderate^\|\|^ | Applicable to physical activity interventions. Did not include observational evidence on harms related to changes in diet or physical activity.

* Inconsistent in direction and magnitude of effects for QOL outcomes.

† Possible selective reporting or selective analysis bias.

‡ Reasonably consistent and reasonably precise for SBP; reasonably consistent and imprecise for DBP and LDL cholesterol; inconsistent and imprecise for TC, HDL cholesterol, and TG; and inconsistent and reasonably precise for adiposity outcomes.

§ All but one study was a randomized, controlled trial; the one remaining study was a nonrandomized controlled trial.

|| Despite the relatively limited number of studies that reported harms related to interventions, we are moderately confident that there are no serious harms related to behavioral counseling interventions for healthful diet and physical activity.

Abbreviations: BMI=body mass index; CI=confidence interval; CV=cardiovascular; EPC=evidence-based practice center; FU=followup; HDL=high-density lipoprotein; k=number of trials; KQ=key question; MD=mean difference; min=minute; obs=observations; OR=odds ratio; PA=physical activity; QOL=quality of life; RCT=randomized, controlled trial’ SBP=systolic blood pressure; SMD=standardized mean difference; TC=total cholesterol.

We have limited certainty in the evidence for the effects on longer-term health outcomes, including all-cause and CVD-specific mortality, CVD events, and HrQOL. The evidence for these outcomes was sparse and inconsistent in the effects and reporting of health outcomes, precluding a robust conclusion. No new studies were included for mortality or CVD events. Though the studies reporting these outcomes were generally large and of good quality, most were conducted in a selected population (persons with high-normal blood pressure). These studies consistently showed no difference in all-cause or CVD mortality and showed mixed findings for CVD events. Studies reporting quality of life showed small benefits for participants in intervention groups and no consistent benefit compared with controls. Overall, a limited number of trials reported on harms of physical activity interventions and none reported harms related to dietary interventions; none of these studies reported any serious adverse events related to the interventions. Only one trial among women found a statistically significantly greater incidence of injuries and falls related to a physical activity intervention. Despite a relatively smaller body of evidence related to harms, we are moderately confident that there are no serious adverse events associated with behavioral counseling for healthful diet and physical activity as we did not hypothesize any serious harm from counseling interventions.

## Comparison With Findings From Other Systematic Reviews

The findings of our review are generally concordant with other systematic reviews that synthesized the evidence of healthful diet and physical activity interventions for the primary prevention of CVD. This includes a number of diet-related reviews by the Cochrane Collaboration focused on general dietary advice,^222^ fruit and vegetable intake,^223^ reductions in fat^224^ and saturated fat,^225^ fiber intake,^226^ and adherence to a Mediterranean diet,^227^ as well as reviews focused on increasing physical activity.^228–231^ Similar to our review, findings of other existing diet-focused reviews suggested that persons randomized to receive dietary advice experienced statistically significant higher reductions in SBP (MD, 2.61 mm Hg [95% CI, 1.31 to 3.91]), DBP (MD, 1.45 mm Hg [95% CI, 0.68 to 2.22]), LDL cholesterol (MD, 0.16 mmol/L [6.2 mg/dL] [95% CI, 0.08 to 0.24]), and total cholesterol (MD, 0.15 mmol/L [5.8 mg/dL] [95% CI, 0.06 to 0.23]) after 3 to 36 months, whereas mean changes in HDL cholesterol and triglyceride levels were not different between groups.^222^ Also concordant with our review, there was significant heterogeneity in the analyses for self-reported dietary intake, but the results generally suggested improvements in fruit and vegetable, fiber, sodium, fat, and saturated fat intake with dietary advice.^222, 223^ Among those reviews, there was no clear effect of any dietary intervention compared with usual care or control diet on total or CVD mortality. One review, however, reported a reduction in cardiovascular events for dietary fat interventions compared with usual diets (pooled RR, 0.86, [95% CI, 0.77 to 0.96]; n=65,508) among persons at high or low risk for CVD.^224^

The National Institute for Health and Care Excellence performed two separate reviews of the literature to determine the effectiveness of brief advice^231, 232^ and exercise referral schemes^230, 233^ in increasing physical activity. In the first review, moderate evidence from 15 trials suggested an increase in self-reported physical activity among participants who received brief advice or who were seen by primary care professionals trained to deliver brief advice. Brief advice was defined as interventions delivered in one session or in fewer than 30 minutes. There was weak evidence, however, of a benefit of exercise referral schemes in increasing the number of participants who achieved 90 to 150 minutes of at least moderate-intensity physical activity per week at 6 to 12 months of followup (pooled RR, 1.11 [95% CI, 0.99 to 1.25]) versus usual care.

## Observational Evidence on the Association Between Differences in Intermediate and Behavioral Outcomes and Health Outcomes

Due to sparse direct RCT evidence on the effect of healthful diet and physical activity counseling interventions on health outcomes, we present observational evidence to contextualize our results. This evidence likely represents an upper bound of potential benefit due to a broader inclusion of studied populations, including those at higher CVD risk, as well as an optimistic assumption that behavior modification, and hence subsequent differences in intermediate outcomes, are maintained over time.

Overall, observational data from very large individual participant data (IPD) meta-analyses of prospective cohort studies show that small differences in intermediate outcomes translate into small differences in important health outcomes, with greater proportional (though not absolute) benefit occurring at progressively younger ages (Table 9).^19, 234, 235^ The relationships between blood pressure (>115/75 mm Hg) and death from ischemic heart disease or stroke and between cholesterol and death from ischemic heart disease or stroke are generally log-linear. These associations are stronger than the association between fasting glucose and death from ischemic heart disease or stroke—a relationship that exhibits a nonlinear pattern and a threshold around 100 mg/dL, below which increases do not raise vascular risk. The relationship between BMI and ischemic heart disease and stroke death is also nonlinear, existing only above a BMI of 25 kg/m^2^. However, BMI is highly correlated with other intermediate outcomes.

Table 9 Association of Differences in Intermediate Outcomes With Relevant Health Outcomes

Intermediate outcome | Original increment difference | HR (95% CI) for health outcome for original increment change in intermediate outcome | Converted increment difference | Age, years | Mortality outcome | HR (95% CI) for health outcome for converted increment change in intermediate outcome
SBP^234*^ | ↓20 mm Hg | 0.49 (0.45 to 0.53) | ↓2 mm Hg | 40–49 | IHD | 0.93 (0.92 to 0.94)
SBP^234*^ | ↓20 mm Hg | 0.54 (0.53 to 0.55) | ↓2 mm Hg | 60–69 | IHD | 0.94 (0.94 to 0.94)
SBP^234*^ | ↓20 mm Hg | 0.36 (0.32 to 0.40) | ↓2 mm Hg | 40–49 | Stroke | 0.90 (0.89 to 0.91)
SBP^234*^ | ↓20 mm Hg | 0.43 (0.41 to 0.45) | ↓2 mm Hg | 60–69 | Stroke | 0.92 (0.91 to 0.92)
Non–HDL-C^235†^ | ↓1 mmol/L | 0.57 (0.52 to 0.62) | ↓3 mg/dL | 40–59 | IHD | 0.96 (0.95 to 0.96)
Non–HDL-C^235†^ | ↓1 mmol/L | 0.66 (0.61 to 0.71) | ↓3 mg/dL | 60–69 | IHD | 0.97 (0.96 to 0.97)
HDL-C^235†‡^ | ↑0.33 mmol/L | 0.61 (0.54 to 0.69) | ↑1 mg/dL | 40–59 | IHD | 0.96 (0.95 to 0.97)
HDL-C^235†‡^ | ↑0.33 mmol/L | 0.55 (0.49 to 0.61) | ↑1 mg/dL | 60–69 | IHD | 0.95 (0.95 to 0.96)
TC^235§^ | ↓1 mmol/L | 0.44 (0.42 to 0.48) | ↓3 mg/dL | 40–49 | IHD | 0.94 (0.93 to 0.94)
TC^235§^ | ↓1 mmol/L | 0.72 (0.69 to 0.74) | ↓3 mg/dL | 60–69 | IHD | 0.97 (0.97 to 0.98)
TC^235\|\|^ | ↓1 mmol/L | 0.90 (0.84 to 0.97) | ↓3 mg/dL | 40–59 | Stroke | 0.99 (0.99 to 1.00)
TC^235\|\|^ | ↓1 mmol/L | 1.02 (0.97 to 1.08) | ↓3 mg/dL | 60–69 | Stroke | 1.00 (1.00 to 1.01)
FBG^238,239¶^ | ↑1 mmol/L | 1.12 (1.08 to 1.15) | ↑2 mg/dL | 56^#^ | F+NF CHD | 1.01 (1.01 to 1.02)
FBG^238,239¶^ | ↑18.02 mg/dL | 1.13 (1.11 to 1.15) | ↑2 mg/dL | 53^#^ | Vascular | 1.01 (1.01 to 1.02)
FBG^238,239¶^ | ↑18.02 mg/dL | 1.10 (1.09 to 1.11) | ↑2 mg/dL | 53^#^ | All-cause | 1.01 (1.01 to 1.01)
BMI^19**^ | ↑5 kg/m^2^ | 1.50 (1.39 to 1.62) | ↑1 kg/m^2^ | 35–59 | IHD | 1.08 (1.07 to 1.10)
BMI^19**^ | ↑5 kg/m^2^ | 1.40 (1.32 to 1.49) | ↑1 kg/m^2^ | 60–69 | IHD | 1.07 (1.06 to 1.08)
BMI^19**^ | ↑5 kg/m^2^ | 1.76 (1.52 to 2.04) | ↑1 kg/m^2^ | 35–59 | Stroke | 1.12 (1.09 to 1.15)
BMI^19**^ | ↑5 kg/m^2^ | 1.49 (1.34 to 1.67) | ↑1 kg/m^2^ | 60–69 | Stroke | 1.08 (1.06 to 1.11)

* For SBP >115 mm Hg. Adjusted for age (within range being considered), sex, and study. Adjustments for lipids, diabetes, weight, alcohol, and smoking did not change results.

† Adjusted for age (within range being considered), sex, and study. Formal test for heterogeneity NS for sex (significant for age)

‡ Directionality inverted from negative to positive

§ Adjusted for age (within range being considered), sex, and study. Result slightly attenuated by adjustment for SBP and unaltered by adjustment for smoking. Formal test for heterogeneity NS for sex for age <69 years; formal test for heterogeneity significant for age.

|| Adjusted for age (within range being considered), sex, and study. Result attenuated with adjustment for SBP and minimal increase in HR with further adjustment for smoking for ages 40–59 years only.

¶ For FBG >100 mg/dL and assuming log-linear association. Adjusted for age, smoking, BMI, and SBP.

# Mean age.

** For BMI >25 kg/m^2^. Adjusted for sex and smoking.

Abbreviations: BMI=body mass index; CHD=coronary heart disease; CI=confidence interval; F+NF=fatal plus nonfatal; FBG=fasting blood glucose; HDL-C=high-density lipoprotein cholesterol; HR=hazard ratio; IHD=ischemic heart disease; NS=not significant; SBP=systolic blood pressure; TC=total cholesterol.

### Blood Pressure

Our review found that primary care–relevant healthful diet and physical activity counseling can decrease SBP and DBP by approximately 1.3 and 0.5 mm Hg, respectively, at 6 to 12 months of followup compared with usual care. Within the included evidence, most participants were normotensive or had high-normal blood pressure, with a mean blood pressure across trials of 127/78 mm Hg. Epidemiologic data suggest that even small differences in blood pressure may decrease the risk for CVD-related mortality (Table 9). An IPD meta-analysis of nearly 1 million adults without CVD studied in 61 prospective observational cohorts found a strong and direct relationship between blood pressure and age-specific mortality for stroke, ischemic heart disease, and other vascular causes; this relationship persisted after adjustment for lipid levels, diabetes, weight, alcohol intake, and smoking.^234^ The continuous and positive association found in this analysis existed across a wide range of blood pressures, including the normotensive range; there was no evidence of a threshold for which lower blood pressure was not associated with lower CVD risk, down to levels of 115/75 mm Hg. When associations from this analysis, expressed as hazard ratios per 20-mm Hg difference in SBP and per 10-mm Hg difference in DBP, were converted into smaller increments more consistent with our results, the findings suggested that even a small blood pressure difference in SBP of 2 mm Hg in adults ages 40 to 49 years was associated with a stroke mortality reduction of 10 percent (HR, 0.90 [95% CI, 0.89 to 0.91]) and an ischemic heart disease mortality reduction of 7 percent (HR, 0.93 [95% CI, 0.92 to 0.94]) (Table 9).^234^ These associations were similar in magnitude for DBP when estimated for increments of 1 mm Hg.^107^ An IPD meta-analysis of trial data of all classes of antihypertensive medications offered support for the generalizability of the benefits of blood pressure lowering across a spectrum of overall risk and risk factor levels.^236, 237^

### Lipids

Our meta-analyses of lipid outcomes suggested that diet and physical activity counseling interventions decrease LDL cholesterol level by approximately 2.6 mg/dL and total cholesterol level by approximately 2.8 mg/dL at 6 to 12 months of followup compared with usual care. High-intensity interventions resulted in greater benefit: a reduction of nearly 4.5 and 5.3 mg/dL for LDL and total cholesterol, respectively. There was no evidence of an effect of interventions on HDL cholesterol or triglyceride level. Most studies reported mean levels of LDL cholesterol below 129 mg/dL, below 200 mg/dL for total cholesterol, and above 50 mg/dL for HDL cholesterol. The relationship between cholesterol and health outcomes is complicated by lipid components that work in different directions and varying strengths of association across different outcomes. Based on a related IPD meta-analysis of about 900,000 individuals without CVD, there is evidence of a strong positive relationship between non-HDL cholesterol level (reported instead of LDL cholesterol in the IPD meta-analysis) and ischemic heart disease mortality and a strong inverse relationship between HDL cholesterol level and this outcome.^235^ These associations were seen for all age groups, with no evidence of thresholds above or below which these relationships did not persist; the proportional strength of association, however, became weaker with increasing age. On average, a difference in non-HDL cholesterol level of 3 mg/dL was associated with a 4 percent reduction in fatal ischemic heart disease risk at ages 40 to 59 years (HR, 0.96 [95% CI, 0.95 to 0.96]) and a 3 percent reduction (HR, 0.97 [95% CI, 0.96 to 0.97]) at ages 60 to 69 years (Table 9).^235^ There was no statistically significant association between non-HDL cholesterol level and stroke mortality, although analyses were limited by fewer events for this outcome.^235^

### Fasting Glucose

Our pooled analysis of interventions of all levels of intensity did not find a significant effect for diet or physical activity counseling interventions on fasting glucose; analyses restricted to high-intensity interventions found a small effect of −1.4 mg/dL. Our review excluded adults with diabetes as well as those with impaired fasting glucose, and the mean baseline value of fasting glucose was 97 mg/dL for persons included in our pooled analysis. Epidemiologic evidence does not suggest that lowering blood glucose level in persons with normal glucose levels imparts benefit. In an IPD meta-analysis of 284,686 individuals without CVD from 54 prospective studies, fasting glucose levels between 70 and 100 mg/dL were not associated with excess vascular or all-cause mortality risk in analyses adjusted for age, smoking, and BMI^238^; similar results were found for coronary heart disease and stroke outcomes inclusive of nonfatal events in a related IPD meta-analysis.^239^ At levels above 100 mg/dL, however, an increment of 2 mg/dL was associated with a 1 percent increase in fatal plus nonfatal coronary heart disease risk (HR, 1.01 [95% CI, 1.01 to 1.02]) (Table 9).^239^ At the same glucose concentration, this same 2 mg/dL increment increase had a similar effect on vascular death (HR, 1.01 [95% CI, 1.01 to 1.02]) and an increase of 1 percent for all-cause mortality (HR, 1.01 [95% CI, 1.01 to 1.01]).^238^ There is a well-established link between the presence of diabetes and the incidence of cardiovascular events that roughly doubles the risk for both fatal and nonfatal coronary heart disease and stroke.^239^ This link highlights the importance of preventing progression to diabetes in persons at highest risk. Our separate review focused on persons with known CVD risk factors, including those with impaired fasting glucose or glucose tolerance, found that counseling interventions in high-risk populations substantially reduced the risk of progression to diabetes at 12 to 24 months (pooled RR, 0.58 [95% CI, 0.37 to 0.89]; k=8; I^2^=32%).^65^

### Adiposity

By design, the included trials in our review did not explicitly focus on weight loss. Nevertheless, small improvements in BMI, weight, and waist circumference were found to be associated with diet and physical activity interventions at 6 to 12 months of followup. The statistical heterogeneity for these pooled effects was considerable, however, and therefore some uncertainty in the average effects remains. The between-group differences found in our included trials suggested a reduction in BMI of approximately −0.41 kg/m^2^ (95% CI, −0.62 to −0.10), a decrease in weight of approximately −1.0 kg (2.3 lb) (95% CI, −1.56 to −0.51), and a decrease in waist circumference of −1.19 cm (0.5 in) (95% CI, −1.79 to −0.59). These effects are slightly lower than those seen for our separate review focused on persons with increased CVD risk^65^ and for our review on behavioral weight loss interventions.^42^ Within these reviews, a between-group difference in weight loss of approximately 3 kg was seen. The average BMI of participants within these two reviews was also slightly higher (29.8 and 31.9 kg/m^2^, respectively) than that of the current review (27.7 kg/m^2^).

An IPD meta-analysis of 57 prospective studies with nearly 900,000 adults without CVD found that all-cause mortality was lowest in BMI ranges of 22.5 to 25 kg/m^2^; above this level, increases of 1 kg/m^2^ were associated with an 8 percent increase in the risk of ischemic heart disease death (HR, 1.08 [95% CI, 1.07 to 1.10]) and a 12 percent increase in the risk of fatal stroke (HR, 1.12 [95% CI, 1.09 to 1.15]) at ages 35 to 59 years, with progressively weaker associations at older ages (Table 9).^19^ These estimates were not adjusted for blood pressure level, lipid levels, or diabetes, as these are the mechanisms through which BMI affects vascular mortality.^19^ A 2016 analysis of a recent Danish cohort suggests that the association between BMI and mortality is changing over time, perhaps due to greater effects of improved treatment of cardiovascular risk factors among persons with a higher BMI. Data from a 2003–2013 Danish cohort found that the BMI value associated with the lowest all-cause mortality was 27.0 kg/m^2^ and that associations between BMI higher than 30 kg/m^2^ and all-cause mortality have decreased over time (2003–2013: HR, 0.99 [95% CI, 0.92 to 1.07]; 1991–1994: HR, 1.13 [95% CI, 1.04 to 1.22]; 1976–1978: HR, 1.31 [95% CI, 1.23 to 1.39]).^240^ Because of the strong associations between BMI and known cardiovascular risk factors, including blood pressure level, lipid levels, and diabetes,^19^ the clinical significance of changes in weight should also consider the accompanying changes in these outcomes.

### Diet

Our review of the evidence found that healthful diet interventions were associated with reduced intake of total energy, fat, saturated fat, and sodium intake and increased intake of fiber and fruits and vegetables compared with control arms. Between-group differences for dietary outcomes were in the magnitude of 65 kcal/day (favoring the control group) to −500 kcal/day (favoring the intervention group) in total energy intake, 0.8 to −11 percentage points in the percent of calories from fat, −0.3 to −4 percentage points in the percent of calories from saturated fat, and approximately −380 to nearly −1,400 mg/day of sodium. Effects on fruit and vegetable intake ranged from between-group differences of −0.2 servings/day (favoring the control group) to 2.2 servings/day (favoring the intervention group); between-group differences in grams of fiber per day ranged from 1 to 2.5 g in favor of the intervention group. Persistent effects of the interventions were seen over time for all dietary outcomes among studies that reported multiple time points. Observational data offer support that small changes such as these may be associated with important health benefits. A 2014 meta-analysis of prospective cohort studies by Wang et al,^241^ for example, found that an additional serving of fruit and vegetables per day was associated with a 4 percent reduction in cardiovascular mortality (HR, 0.96 [95% CI, 0.92 to 0.99]; k=4) and a 5 percent reduction in all-cause mortality (HR, 0.95 [95% CI, 0.92 to 0.98]; k=7). Although we did not pool our estimates due to high heterogeneity (which was also present for some outcomes in the meta-analysis of Wang et al), increases in fruit and vegetable consumption from our review are likely consistent with this magnitude. Baseline servings of fruits and vegetables in our included studies that reported this outcome ranged from about 1.5 to more than 5.5 servings/day. Further, a 2015 analysis using two very large U.S.-based prospective cohort studies (the Nurses’ Health Study and the Health Professionals Followup Study) found that an isocaloric replacement of 5 percent of total energy from saturated fat with energy from polyunsaturated fatty acids, monounsaturated fatty acids, or whole grain-based carbohydrates was associated with statistically significant reductions in risk for coronary heart disease of 25, 15, and 9 percent, respectively (HR, 0.75 [95% CI, 0.67 to 0.84]; HR, 0.85 [95% CI, 0.74 to 0.97]; and HR, 0.91 [95% CI, 0.85 to 0.98], respectively).^242^ Mean between-group decreases in percent energy from saturated fat in our included studies were consistently less than 5 percent but greater than 3 percent in four trials,^97, 106, 194, 209^ and statistically significantly reduced in all but one trial.^176^ Our results related to decreases in total fat intake should be interpreted in light of increasing evidence (including from the large WHI Dietary Modification Trial included in this review^209^) that low-fat dietary patterns may not assist with weight loss or be protective for CVD and several types of cancer.^138, 139, 243, 244^ Recent guidance^2^ has moved away from advocating low fat intake in general to an emphasis on the type of fat (e.g., increasing monounsaturated and polyunsaturated fats).

Finally, a 2015 model based on data from NHANES and the same two very large prospective cohort studies estimated that modest improvements in the quality of the U.S. diet from 1999 to 2012 were associated with a sizeable reduction in disease burden and prevented as many as 1.1 million premature deaths and 8.6 percent fewer cases of CVD.^245^ These diet improvements were measured by the Alternate Healthy Eating Index, which increased from 39.9 to 48.2 (perfect score=110) during this time period. The improvements were driven largely by reduced consumption of trans fat (which has been a target of government regulation) but also by modest improvements in the intake of fruit, whole grains, nuts and legumes, polyunsaturated fats, sugar-sweetened beverages and juices, and red and processed meat. Despite these temporal improvements in diet quality, however, the U.S. diet remains poor, and socioeconomic disparities in diet quality persist.

### Physical Activity

The bulk of the included literature (63 of 88 studies) and, in particular, the newly added trials (28 of 38 studies), evaluated the effects of counseling interventions on physical activity behaviors. Very few of these studies (k=17) reported the effects of the interventions on intermediate cardiometabolic outcomes or health outcomes; those that did were generally limited to measures of adiposity and quality of life. Instead, the primary outcome within most of these trials was self-reported physical activity. Our pooled analyses of these trials indicated a fairly large increase in physical activity participation, although there was some imprecision in the magnitude of effects across studies. Physical activity interventions, with or without components focused on dietary improvements, resulted in an increase of approximately 35 minutes of physical activity per week compared with control conditions. Studies among persons with low levels of baseline physical activity resulted in greater increases in physical activity compared with persons at levels above recommendations. Additionally, intervention participants had a 32-percent higher odds of meeting physical activity recommendations (150 minutes of moderate-intensity or 75 minutes of vigorous-intensity physical activity per week) compared with controls. The baseline level of physical activity in trials in our meta-analyses varied from 12 to 519 minutes/week among control groups (mean, 124 minutes/week). The dose-response pattern shown in observational evidence suggests that as long as changes persist and regardless of baseline physical activity level, our findings of an increase of about 35 minutes/week from behavioral counseling interventions could translate into additional benefit for cardiovascular and all-cause mortality.

Observational data consistently show that physical activity reduces the risk of cardiovascular and all-cause mortality in a dose-response fashion and that substantial benefits accrue even when physical activity is performed in amounts less than the nationally recommended 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity activity per week (approximately 500 to 1,000 MET-minutes/week).^246^ Activity less than the recommended minimum (<450 MET-minutes/week) is associated with a 20 percent reduction in cardiovascular death (HR, 0.80 [95% CI, 0.77 to 0.84]) and a similar reduction in all-cause mortality (HR, 0.80 [95% CI, 0.78 to 0.82)] compared with no activity (adjusted for clinical and demographic characteristics, including BMI).^247^ Levels at national recommendations (approximately 500 to 1,000 MET-minutes/week) are associated with further reductions in cardiovascular and all-cause mortality risk of 33 and 31 percent, respectively (HR, 0.67 [95% CI, 0.65 to 0.70] and HR, 0.69 [95% CI, 0.67 to 0.70], respectively). Further, the benefit of physical activity appears broadly generalizable, with reasonably consistent point estimates across subpopulations defined by age, sex, race/ethnicity, BMI, smoking, and history of heart disease. These findings are supported by a large Taiwanese prospective cohort study of more than 400,000 individuals which also found that even low levels of activity below recommendations, characterized by about 90 minutes/week or 15 minutes/day, were associated with a 19 percent reduction in the risk of cardiovascular mortality (HR, 0.81 [95% CI, 0.71 to 0.93]) and 14 percent reduction in the risk of all-cause mortality (HR, 0.86 [95% CI, 0.81 to 0.91]), with additional benefit accruing at progressively higher levels of activity.^248^ Furthermore, this analysis found that additional increments of 15 minutes/day (beyond a minimum of 15 minutes/day) were associated with an all-cause mortality risk reduction of 4 percent (95% CI, 2.5 to 7.0).^248^

Large cross-sectional analyses show that physical activity is associated with better overall quality of life and perceived health status, independent of BMI.^249, 250^ Results of longitudinal analyses are mixed, with some showing that increases in physical activity over 3 to 4 years of followup are associated with improvements in a range of quality-of-life domains with either substantial^251^ or limited clinical impact;^252^ other studies show that cross-sectional associations are not confirmed by longitudinal analyses.^253^ These mixed results are echoed by our results from intervention studies of 6 to 12 months’ duration.

### Harms

Very few of the included trials reported on adverse effects of interventions, and only two trials found more harms among intervention versus control participants. These harms were categorized as “mild” or “moderate” within the trials and included falls and injuries related to increased physical activity; the mean age of the participants in these trials was 59 years^160^ and 71 years,^94^ respectively. We did not, however, hypothesize any serious harm from diet and physical activity counseling. Observational data suggest that the rate of adverse cardiovascular events in generally healthy adults is extremely low during and immediately after physical activity of varying types and levels of intensity and is significantly lower among those with a history of being active.^254^ Increasing age and physical activity intensity are related to greater risk of adverse cardiovascular events. Risk of musculoskeletal injury varies substantially across different activities; activities with limited or no contact (e.g., baseball, walking, running, biking) carry the lowest risk of injury. Consensus exists that the benefits of regular physical activity outweigh the inherent risk of adverse events.^246^ The possible harms of dietary counseling have not been well defined or measured. There is potential that focusing counseling on, for example, reducing total fat intake but not reducing caloric intake, might lead to an increased intake of carbohydrates (in the form of reduced-fat or low-fat food products), which could result in weight gain and decrements in other cardiometabolic indicators. Likewise, unsupervised behavior changes to extreme levels (e.g., very-low-fat or low-calorie “diets”) could cause nutrient inadequacy or other adverse effects.

## Considerations for Applicability of Findings

By design, the current review included unselected adults or those generally at low risk for CVD. Otherwise, the persons represented in the trials exhibited a broad range of sociodemographic and behavioral characteristics. A number of studies were limited to specific subpopulations for which particular CVD risk factors and dietary and activity habits may differ from their counterparts, including women (in particular, the large WHI trial [n=48,835]), older adults, racial/ethnic minority groups, persons with high-normal blood pressure, persons with a family history of CVD or diabetes, and persons who are overweight or have obesity. Likewise, nearly half of the studies limited enrollment to persons with suboptimal levels of physical activity, inadequate dietary habits, or both. The remaining studies were conducted among unselected adults with varying sociodemographic and clinical characteristics. Across all of the studies, baseline dietary and physical activity behaviors were highly variable. For instance, minutes of physical activity per week ranged from 2 to more than 600. Likewise, baseline daily servings of fruits and vegetables ranged from 1.5 to 5.5.

Although the majority of studies recruited participants directly (via invitations through primary care, the broader health care system, or some other convenience sample rather than relying on community volunteers), the adults who took part in these studies are likely to have been more motivated to change their behaviors than those not represented in these trials. Indeed, we saw generally high rates of retention (>85% at 12 months) over the course of the studies and good adherence to the interventions—rates which may not be seen in real-world scenarios. Regardless, given the broad representation across population characteristics and the fact that most of the studies took place in the United States, we believe the findings of this review are generalizable to a U.S. primary care population, although the magnitude of the effects may be slightly lower when applied to general practice.

There was some evidence, at least for intermediate outcomes, that increasing intervention intensity was related to greater benefit. It is difficult to disentangle differences in the various intervention, population, and broader study characteristics, however, when attempting to explain the effectiveness of the interventions on these outcomes. Most of the studies that reported intermediate outcomes were of medium- or high-intensity interventions that often were conducted among persons with slightly higher risk for CVD. Additionally, most of these interventions focused messages on dietary changes and may or may not have included messages about increasing physical activity. Even within the high-intensity interventions, the estimated intervention contact (minutes of counseling) ranged considerably—from 420 minutes (7 hours) to 2,340 minutes (39 hours) over the course of 4 weeks to 6 years. Furthermore, most of these high-intensity interventions took place outside of the primary care setting and may represent persons with higher motivation to change their behaviors. Similarly, the effects seen for dietary outcomes were mostly for medium- or high-intensity interventions, whereas the effects for physical activity outcomes included trials testing mostly low- and medium-intensity interventions. There was no evidence of a dose-response relationship with intervention intensity, but there was evidence that trials targeting persons with baseline activity below recommended levels saw larger improvements in physical activity participation than trials in which participants were already achieving higher levels of physical activity. These latter studies, however, emphasized both dietary changes and, to a lesser extent, changes in physical activity.

Based on the included literature, we are not able to define either the minimum necessary intervention components for an effective intervention or identify a representative intervention. No two studies had exactly the same goals, modes of delivery, or delivery schedule, although some explicitly built off of learnings from earlier trials (for example, the STRIDE,^167^ COSTRIDE,^98^ and VA-STRIDE^117^ trials). Using qualitative analyses and meta-regression, we did not find that the intervention focus (healthful diet alone, physical activity alone, or healthful diet plus physical activity), format (group vs. individual, phone, print), number of sessions, person delivering the intervention, or duration of the intervention significantly affected the direction or magnitude of the benefit. Though we broadly focused on studies related to the primary prevention of CVD among healthy adults, the specific aims of each trial differed (e.g., prevention of hypertension, weight gain prevention, increasing physical activity) and appropriately resulted in different intervention goals and components. For instance, the trials targeting persons with high-normal blood pressure focused the interventions on reducing dietary sodium, whereas the trials aimed at increasing physical activity among persons with very low levels of physical activity included highly tailored written and verbal messages and tools for self-monitoring physical activity. Across all of the interventions, most included tailored advice and materials and encouraged goal setting and self-monitoring. Therefore, the ideal counseling intervention for any given person will depend on consideration of their specific clinical characteristics, including existing diet and physical activity behaviors, and the larger context of other prevention or screening priorities, given the limited time for a typical primary care encounter.

## Limitations of Our Approach

There are limitations of this review that arise from scoping and analytic decisions that should be acknowledged. First, this updated review represents only a subset of the literature focused on dietary and physical activity counseling. To be consistent with the scope and mission of the USPSTF and to avoid duplication of literature addressed in other reviews for the USPSTF, we excluded some related bodies of evidence, including studies focused on persons with known disease (e.g., coronary heart disease, diabetes, impaired fasting glucose, hypertension, dyslipidemia), trials focused on weight loss or weight management, and trials focused on dietary or physical activity counseling to prevent or manage other health risks and conditions (e.g., falls, cognitive impairment, cancer) or for general health promotion. In addition, a wide variety of interventions are available for primary prevention of CVD; we excluded trials evaluating other (not dietary or physical activity counseling) interventions, such as stress management interventions (e.g., yoga, tai chi, low-dose aspirin, statins, and tobacco cessation). Many of these topics are the focus of other USPSTF reviews and recommendations.^41, 43, 45, 64, 255^

Although we focused this review specifically on adults “without known CVD risk factors,” precisely defining a level of CVD risk is difficult given the multifactorial and continuous nature of cardiometabolic indicators, some of which (e.g., LDL cholesterol) have no threshold for which lower levels are not associated with lower risk.^234, 235^ Moreover, exceptionally few studies performed cardiovascular risk assessment using a multivariate tool. We excluded studies that explicitly enrolled participants on the basis of known hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors. Additionally, we examined the baseline characteristics of each sample and excluded studies for which the sample mean for one or more risk factors was “high” (i.e., mean SBP >140 mm Hg or DBP >90 mm Hg, total cholesterol >240 mg/dL, LDL cholesterol >160 mg/dL, impaired fasting glucose >110 mg/dL). We did, however, include studies among adults who may otherwise be at increased risk for CVD due to being overweight or having obesity, family history, having high-normal blood pressure, or suboptimal dietary or physical activity behavior at baseline. Despite these operational criteria, there was still some subjectivity in determining risk and deciding which review (or reviews) each trial best fit (i.e., the current review, which focused on adults not at high risk, and/or our separate review, which focused on high-risk adults). Two trials are included in this current update as well as our review among high-risk adults.^65^ Most of the studies included in this review represented an unselected population or persons selected on the basis of suboptimal behaviors, but did not report baseline values of blood pressure, lipid levels, glucose levels, current smoking, or adiposity.

Our review was limited to interventions that were conducted in primary care or those that we felt may be feasible for primary care. Only 23 of the 88 trials, however, actually took place in a primary care setting or involved primary care staff in the delivery of the intervention. An additional 21 studies recruited participants through mailings or phone calls from their primary care office or health insurance provider, but the interventions themselves were delivered in a research setting, at home, or elsewhere and did not include primary care staff. The remaining 44 studies had no connection to the primary care setting; however, we judged them to be potentially feasible for implementation in a primary care setting given the nature of the intervention components (e.g., print material, telephone counseling, computer based) or interventionists (e.g., health educators, trained staff). Many of these latter studies recruited participants through community venues, including mass advertising or through existing convenience lists (e.g., existing research cohorts), and therefore may represent populations with higher levels of motivation to change their behaviors or participate in research. Defining what interventions are “feasible for” or “referable from” primary care is an ongoing challenge as it applies to USPSTF-related behavioral counseling interventions.^256–259^ In addition, because our focus was on primary care–conducted or referable interventions, our review excluded interventions delivered through worksites, churches, and other community organizations as well as interventions that focused on environmental and policy changes that may not be easily replicated or implemented solely through primary care. For these interventions, we refer to the Community Preventive Services Task Force^260^ and the National Cancer Institute’s Research-Tested Intervention Programs.^261^ Additionally, our review focused on counseling to improve dietary habits and did not review the evidence on the relationship between particular dietary patterns (e.g., Mediterranean-style, DASH-style, vegetarian) and health outcomes. The Scientific Report of the 2015 Dietary Guidelines Advisory Committee provides a thorough review of this evidence.^3^ Likewise, our review excluded observational studies that have shown that including physical activity as a vital sign within health systems’ electronic medical records increases the documentation of exercise behaviors and referrals for lifestyle-related counseling (e.g., Grant et al^262^).

We also excluded studies without a true control and thus did not address the comparative effectiveness of different types of behavioral interventions. Our requirement was that the control group receive counseling that was no longer than 15 minutes, which we deemed to be equivalent to usual care for persons at low risk for CVD. This criterion led to the exclusion of a number of high-profile trials that otherwise would have been included in this review, such as PREMIER^263^ and the Activity Counseling Trial.^264^ In the PREMIER trial, adults (n=810) with untreated high-normal blood pressure or stage I hypertension (SBP, 120 to 159 mm Hg; DBP, 80 to 90 mm Hg) were randomized to an advice-only group (print materials plus a 30-minute counseling session), a group focused on established recommendations for blood pressure control (i.e., sodium reduction, weight loss, and increased physical activity), or an established plus DASH group that combined the established recommendations with the DASH diet. Among all participants, compared with the advice-only arm, mean SBP was 3.7 and 4.3 mm Hg lower in the established and established plus DASH groups, respectively (p<0.001). Likewise, at both 6 and 18 months, a greater reduction in the median 10-year CVD risk was seen among the established and established plus DASH groups compared with the advice-only arm; this finding was true among the subset of participants with high-normal blood pressure as well as the subset of participants with stage 1 hypertension.^265^ The multisite Activity Counseling Trial (n=874) compared the effects of three physical activity counseling interventions within the primary care setting: 1) advice that included brief physician advice, written educational materials, and referral to a health educator; 2) advice plus counseling with the health educator and followup telephone calls, tailored mailings, and self-monitoring; or 3) advice, counseling, plus more intense telephone counseling and group sessions over the course of the 2-year intervention. All three groups emphasized increasing physical activity to 30 minutes of moderate-intensity physical activity for 5 or more days per week or 30 minutes of vigorous-intensity physical activity for 3 or more days per week. At 2 years, no differences in self-reported physical activity were found between groups, among both men and women. Among women, however, cardiorespiratory fitness was statistically significantly higher in both the advice plus counseling and counseling plus arms compared with the advice-only arm.^264^

With complex interventions such as these, describing and synthesizing intervention characteristics is difficult. The included interventions varied considerably in terms of the nature of the advice, mode of delivery, and delivery schedule. We diligently abstracted as much detail as possible about each intervention, used an established taxonomy for describing the behavior change techniques used in the interventions,^70^ and carefully summarized this detail in tabular and narrative format. We used consistent rules for estimating the total minutes of contact (i.e., intensity) across studies and used our established^40, 65^ cutpoints to categorize each intervention arm as low intensity (≤30 minutes), medium intensity (31 to 360 minutes), or high intensity (>360 minutes). Despite this consistency, the rules are still somewhat arbitrary, and many medium-intensity interventions were quite intensive in terms of participant contact (e.g., nearly 5 hours of participation). Furthermore, in many cases, detailed reporting of the number and length of sessions was lacking, so we had to make several assumptions. Our analysis of the effect of intensity (both as a continuous variable and when comparing high- vs. medium- and low-intensity interventions) provided some evidence that higher intensity interventions are associated with larger improvements in intermediate outcomes, although there were very few low-intensity (≤30 minutes) interventions that reported intermediate outcomes. There was no evidence of a specific threshold of intensity (i.e., a certain number of sessions, number of minutes, or duration) that resulted in greater benefit. There is clearly a need to continue evaluating the effect of lower intensity interventions that take place in or involve primary care staff on intermediate health outcomes in addition to behavioral outcomes. Additionally, we did not collect or evaluate any data on costs or cost-effectiveness of the interventions given resource limitations, although such information could be useful for decisionmakers.

Finally, we purposefully pooled across a body of literature that was heterogeneous with respect to clinical and demographic characteristics, interventions, and settings. For most outcomes, the statistical heterogeneity was unimportant (I^2^<40%) or moderate (I^2^=30% to 60%) and therefore still reasonable to allow for interpreting of pooled estimates. However, given the clinical heterogeneity, looking at the confidence intervals for each point estimate helps us to understand the true magnitude of effects on the individual outcomes. There was considerable heterogeneity (I^2^>90%) in the meta-analyses of adiposity and dietary outcomes, which is consistent with both the clinical variability of included populations and the variability in interventions among the included studies as well as the continuous nature of the data. Nevertheless, the high statistical heterogeneity may indicate that the pooled average effect of the interventions should be interpreted with caution. In light of the considerable heterogeneity and relatively few studies within each analysis, we chose not to present the pooled effects for any of the dietary outcomes.

Other potential sources of risk of bias in our review include limiting the search to English-only publications and published trials.

## Limitations of the Studies and Future Research Needs

A number of limitations related to the included studies should be noted. Most of the included evidence recruited participants more than a decade ago, many did not report measures of intermediate cardiometabolic outcomes, and even fewer reported longer term health outcomes. As the prevalence and rate of these health outcomes are lower in lower risk groups (by definition), these studies require larger sample sizes and longer followup to observe an effect of an intervention in a low-risk group of participants.^257^ As such, enhanced methods for using observational data to understand the effect of small differences in intermediate outcomes from these interventions on long-term health outcomes are needed; some methods are used herein. Additionally, patient-centered outcomes, namely HrQOL measures, were also rarely reported in this literature base; future research should consistently measure and report quality of life and other related patient-centered outcomes. Additional studies should also determine if less intensive interventions are as effective as higher intensity interventions for these intermediate and health outcomes.

It is clear that healthful diet and physical activity behaviors both contribute to good cardiovascular and overall health. Additional research on the additive or differential benefit of different counseling foci (i.e., diet, physical activity, or both) in different populations would be helpful in determining whether clinical scenarios focusing on diet alone or physical activity alone is advisable (or preferable) to combined counseling. Likewise, there is a need for more data from well-designed pragmatic trials and better reporting of intervention characteristics to facilitate evaluation and dissemination of evidence-based practices. As outlined by Krist et al,^258^ research on behavioral counseling interventions such as the type synthesized here would benefit from application of checklists and frameworks such as the Template for Intervention Description and Replication (TIDierR); Research, Effectiveness, Adoption, Implementation, and Maintenance (RE-AIM); and the Pragmatic-Explanatory Continuum Indicator Summary (PRECIS) to assess the feasibility and applicability of interventions as well as to improve replication and dissemination. Our review found no evidence of a difference in effects by the focus of the message, but analyses were highly confounded by the intensity of interventions (i.e., healthful diet interventions were mainly medium or high intensity, whereas physical activity interventions were mainly low or medium intensity). Also, only one of the included studies targeted reductions in sedentary behavior (i.e., sitting time) as the main focus of the trial and only three trials reported the outcomes of sedentary behavior. More research on the effects of counseling to reduce sedentary behavior on behavioral and intermediate health outcomes is warranted. Very few studies explored whether effectiveness of the intervention varied among important subpopulations (including the prespecification of such analyses). Such analyses could assist in identifying groups of adults who might benefit more from such interventions.

Additionally, most of the trials relied on self-reported dietary and physical activity measures with variable levels of evidence of the reliability and validity of the measures. Dietary intake was generally measured by food frequency questionnaires (such as the full-length or shorter versions of the Block Food Frequency Questionnaire^266, 267^), entries in food diaries, or 24-hour food recalls. The tools and summary variables used to measure physical activity were even more inconsistent. Physical activity was summarized in terms of total physical activity, leisure-specific physical activity, moderate- and/or vigorous-intensity physical activity, walking behaviors, and multiple other indicators; in addition, the results were expressed in different units across studies (e.g., minutes/week, MET-minutes/week, steps/day, summary “scores”). Each of these methods can be prone to bias.^268^ While researchers must fit the specific measurement instruments and summary variables to the needs of their particular study aims, research protocols, and sample characteristics, it is clear we could benefit from more standardization of behavioral outcome measurement.^257^ Only three trials measured urinary sodium excretion, and six trials used accelerometers or pedometers to objectively measure physical activity.

We identified 14 trials, including seven conducted in the United States, currently under way that may contribute to this evidence base (Appendix G).

## Conclusions

The beneficial effects of healthful diet and physical activity interventions on physiologic and behavioral outcomes that we observed in our updated systematic review are generally consistent in direction and magnitude with our 2010 review on this topic. Healthful diet and physical activity behavioral interventions for persons not at risk for CVD resulted in small but statistically significant benefits across a variety of important intermediate health outcomes, including blood pressure, LDL and total cholesterol levels, and adiposity, with evidence of a dose-response effect with higher intensity interventions resulting in greater improvements. Small and moderate changes in self-reported dietary and physical activity behaviors were also evident. Very limited evidence exists regarding the health outcomes or harmful effects of these interventions. However, the improvements we saw in intermediate and behavioral health outcomes could translate into long-term reduction in CVD-related events. Future research on behavioral counseling in this population should focus on the effectiveness of lower intensity, primary care–conducted interventions and consistently include measures of intermediate cardiometabolic health outcomes and patient-centered outcomes such as HrQOL.