# 3 Results

## Description of Included Studies

Our literature search yielded 10,045 unique citations. From these, we provisionally accepted 351 articles for review based on titles and abstracts (Appendix A Figure 1). After reviewing the full-text articles and performing critical appraisal, we included 88 studies that were reported in 145 publications.^72, 80–221^ Appendix C contains a full list of included studies. We carried forward 50 studies from our prior review; 38 new studies were added.

For the 351 articles that were reviewed in full, the most common reasons for exclusion were: not an included population (i.e., studies were among adults at high risk for CVD, who had CVD, or who had other known chronic disease; k=60), not an included study design (i.e., not an RCT or controlled clinical trial for KQs 1–3; k=53), and not a relevant study aim (k=28) or relevant outcome (k=28). Appendix D contains a list of all excluded trials and their reasons for exclusion.

Of the 88 included studies, 12 trials reported health outcomes (KQ 1) (e.g., CVD events, self-reported quality of life), 34 trials reported intermediate health outcomes (KQ 2) (e.g., lipid, blood pressure, and glucose levels; weight measures), and 86 trials reported behavioral outcomes (KQ 3) (objective or self-reported measures of diet, physical activity, or sedentary time). Fourteen trials explicitly reported on harms (or the lack thereof) of a counseling intervention (KQ 4) (Table 2).

Table 2 Study and Population Characteristics for All Studies, by Author

Author, year(Study name) Quality | Country Date | KQ1 | KQ2 | KQ3 | KQ4 | N Rand | Population description | Subopt behavior | Elev CVD risk | Mean age (range) | % Female | Race/ethnicity, % | % Empl | % >HS | Mean BMI | % Smoking | PCP^####^
Aadahl, 2014^80^ (Sedentary Intervention Trial [SIT]) Good | Denmark 2010–2011 | | X | X | | 166 | Adults | X | | 52.0 (18–69) | 57.2 | NR | 45.8 | NR | 27.3 | 15.7
Aittasalo, 2006^81^ Fair | Finland 2003–2004 | | | X | X | 265 | Adults | X | | 47.0 (20–65) | 75.8 | NR | NR | NR | NR | NR | X
Albright, 2014^83^ (Nā Mikimiki) Fair | US 2008–2010 | | | X | | 311 | Postpartum women^*^ | X | | 31.8 (18–45) | 100 | White: 15.1 Hisp: 17.4 Asian: 65.3 | 64.0 | 77.8 | 27.9 | 3.5 | X
Aldana, 2006^85^ (Coronary Health Improvement Project [CHIP]) Fair | US 2003 | | X | X | | 348 | Adults | | | 50.5 (24–81) | 71.8 | White: 94.0 Black: 4.0 | NR | 72.0 | 32.4 | NR
Alexander, 2010^86^ (Making Effective Nutritional Choices [MENU]) Fair | US 2005–2006 | | | X | | 2540 | Adults | | | 46.3 (21–65) | 68.8 | Black: 23.3 Hisp: 7.6 | NR | 91.0 | NR | NR | X
Baron, 1990^90^ Fair | UK NR | | X | X | | 368 | Adults | | | 41.7 (25–60) | 48.6 | NR | NR | NR | 24.5 | 34.5 | X
Bennett, 2013^91^ (Shape Program) Good | US 2009–2011 | | X | | X | 194 | Overweight or obese black women^†^ | | X | 35.4 (25–44) | 100 | Black: 100 | 71.4 | 65.4 | 30.2 | NR | X
Beresford, 1997^92^ (Eating Patterns Study) Fair | US 1990–1992 | | | X | | 4778 | Adults | | | NR (NR) | 68.0 | White: 91.0 | NR | 73.0 | NR | NR | X
Bernstein, 2002^93^ Fair | US 1994–1996 | | | X | | 70 | Older adults | X | | 77.9 (≥70) | 80.0 | White: 97.1 Black: 2.9 | NR | NR | 28.5 | NR
Bickmore, 2013^94^ Fair | US 2009–2011 | | | X | X | 263 | Older adults | X | | 71.3 (≥65) | 61.2 | White: 28.5 Black: 62.7 Hisp: 7.6 | NR | 48.7 | 29.5 | 8.7 | X
Brekke, 2005^97‡^ Fair | Sweden 1997–1999 | | X | X | | 77 | Adults with family history of type 2 diabetes^§^ | | X | 42.6 (25–55) | 36.8 | NR | NR | NR | 25.7 | 38
Bryan, 2013^98^ (Colorado Stride [COSTRIDE]) Fair | US NR | | X | X | | 238 | Adults | X | | 28.2 (18–45) | 80.4 | White: 67.1 | NR | NR^\|\|^ | 25.2 | NR
Burke, 2013^100^ (Physical Activity and Nutrition for Seniors [PANS]) Fair | Australia 2010 | | | X | X | 478 | Older adults | X | | 65.8 (60–70) | 48.3 | NR | NR | 47.2 | NR | 5.6
Carpenter, 2004^101^ Fair | US NR | | | X | | 98 | Adults | | | 49.6 (29–71) | 64.3 | White: 86.7 Black: 8.2 Hisp: 2 | NR | 82.7 | NR | NR
Carroll, 2010^102^ (Computerized Health Improvement Project [CHIP]) Fair | US 2004–2007 | | | X | | 394 | Adults | | | 46.4 (≥18) | 69.0 | White: 36.0 Black: 59.0 | 79.0 | 80.0 | 30.4 | NR | X
Castro, 2011^103^ (Telephone Advice and Mentoring [TEAM]) Fair | US NR | | | X | X | 181 | Adults | X | | 59.1 (≥50) | 65.8 | White: 67.4 Hisp: 15.2 Asian: 13.5 | 70.8 | NR | NR | NR
Coates, 1999^106^ (Women’s Health Trial Feasibility Study in Minority Populations [WHT:FSMP]) Fair | US 1991–1995 | | X | X | | 2208 | Postmenopausal women^¶^ | X | | 60.0 (50–79) | 100 | White: 54.6 Black: 28.2 Hisp: 16 | NR | 68.0 | 28.8 | 9.3
de Vet, 2009^108^ Fair | Netherlands 2003–2004 | | | X | | 709 | Adults | | | 45.9 (18–65) | 67.3 | NR | NR | 66.0 | NR | NR
Delichatsios, 2001^109^ Fair | US NR | | | X | | 298 | Adults | X | | 45.9 (≥25) | 72.1 | White: 44.9 Black: 44.6 | 85.2 | 71.0 | 28.7 | 18.5 | X
Elley, 2003^111^ Good | New Zealand 2000–2001 | X | X | X | X | 878 | Adults^#^ | X | | 57.9 (40–79) | 66.3 | NR | NR | 25.9 | 30.0 | 17.5 | X
Estabrooks, 2011^112^ Fair | US 2004 | | | X | | 115 | Adults | X | | 48.8 (≥18) | 61.0 | White: 60.0 Black: 22.0 Hisp: 13.0 | NR | 62.0 | NR | NR | X
Fjeldsoe, 2015^113^ (MobileMums) Fair | Australia NR | | | X | | 263 | Women with young children | | | 31.9 (NR) | 100 | NR | NR | NR | 28.1 | NR
Franko, 2008^115^ Fair | US 2005 | | | X | | 476 | College students | | | 20.1 (18–24) | 56.3 | White: 58.2 Black: 14.1 Asian: 14.9 AI/NA: 6.1 | NR | NR | NR | NR
Fries, 2005^116^ (Rural Physician Cancer Prevention Project) Fair | US 1999–2003 | | | X | | 754 | Adults | | | 47.3 (18–72) | 64.1 | White: 59.5 Black: 37.7 | NR | 49.8 | NR | NR | X
Gao, 2016^117^ (VA-STRIDE) Fair | US 2010–2012 | | | X | | 261 | Older adults | X | | 63.2 (NR) | 17.2 | White: 74.6 Black: 23.3 Hisp: 3.1 | 30.2 | 63.8 | 31.8 | NR | X
Gell, 2015^119^ Fair | US 2010 | | | X | | 87 | Women | | | 47.2 (NR) | 100 | NR | NR | NR | 29.2 | NR
Goldstein, 1999^120^ (Physically Active for Life [PAL]) Fair | US NR | | | X | | 355 | Adults | X | | 65.6 (≥50) | 64.5 | White: 95.8 | 36.0 | NR | NR | NR | X
Grandes, 2009^122^ Good | Spain 2003–2004 | X | X | X | | 4,317 | Adults^**^ | X | | 50.0 (20–80) | 65.6 | NR | 50.6 | 16.8 | 27.3 | 30.4 | X
Green, 2002^123^ Fair | US 1997-1998 | | | X | | 316 | Adults | X | | 44.0 (18–65) | 52.5 | White: 91.5 Black: 1.6 Hisp: 0.6 Asian: 4.4 | NR | NR | NR | NR | X
Greene, 2008^125^ (Study of Exercise and Nutrition in Older Rhode Islanders [SENIOR]) Fair | US NR | | | X | | 1,280 | Older adults | | | 75 (≥60) | 69.6 | White: 77.1 Black: 2.1 Hisp: 14.2 | NR | 39.0 | 27.2 | NR
Greenlee, 2015^126^ (¡Cocinar Para Su Salud!) Fair | US 2011–2012 | | X | X | | 70 | Breast cancer survivors | X | | 56.6 (36–81) | 100 | White: 40 Black: 25.7 Hisp: 100 | 40.0 | 38.6 | 30.9 | NR
Halbert, 2000^128^ Fair | Australia 1996 | X | | X | | 299 | Older adults | X | | 67.6 (≥60) | 54.5 | NR | 37.5 | NR | 27.1 | 7.4 | X
Hargreaves, 2016^130^ (StepWise) Fair | New Zealand 2012 | | X | X | | 97 | Adults | X | | 46.2 (NR) | 84.5 | NR | 76.2 | 86.6 | 31.1 | NR
Harland, 1999^131^ Fair | UK 1995–1996 | | | X | | 523 | Adults | X | | NR (40–64) | 58.3 | NR | 51.6 | NR | NR | NR | X
Harris, 2015^132^ (Pedometer Acelerometer Consultation Evaluation [PACE-LIFT]) Good | UK 2011–2012 | | | X | X | 298 | Older adults | | | NR (60–75) | 53.7 | White: 97.3 | NR | NR | NR | 5.4 | X
Hellenius, 1993^135††^ Fair | Sweden 1990 | X | X | X | | 158 | Men with moderately elevated CVD risk factors^‡‡^ | | X | 46.0 (35–60) | 0 | NR | NR | NR | 25.3 | 26 | X
Hinderliter, 2014^137^ (Exercise and Nutrition Interventions for Cardiovascular Health [ENCORE]) Good | US 2003–2008 | | X | X | X | 95 | Overweight or obese adults with above-normal BP^§§^ | | X | 51.8 (NR) | 66.3 | White: 54.7 Black: 43.2 Hisp: 3.2 Asian: 2.1 AI/NA: 0 | NR | 48.4 | 32.9 | 8.4 | X
Hivert, 2007^72^ Fair | Canada 2002–2003 | | X | X | | 115 | College students | | | 19.7 (NR) | 81.7 | White: 93.0 | NR | NR | 22.4 | NR
HPT, 1990^140^ (Hypertension Prevention Trial [HPT]) Good | US 1982–1986 | X | X | X | | 587 | Adults with high-normal DBP^\|\|\|\|^ | | X | 38.6 (25–49) | 36.8 | White: 83.8 | NR | 56.1 | 26.3 | 15.0
Jacobs, 2011^141^ Fair | Belgium 2007 | | | X | | 314 | Adults | | | 40.5 (25–75) | 66.6 | NR | NR | NR | 25.2 | 21.3
Jeffery, 1999^143^ (Pound of Prevention) Fair | US NR | | X | X | | 1,226 | Adults | | | 38.3 (20–45) | 80.2 | White: 89.6 | NR | 88.9 | 26.6 | 16.4
John, 2002^144^ Fair | UK 1997–1998 | | X | X | | 729 | Adults | | | 45.9 (25–64) | 51.0 | NR | NR | NR | 25.8 | 16.5 | X
Kallings, 2009^146^ Good | Sweden 1997–1999 | | X | X | | 101 | Overweight or obese older adults^¶¶^ | | X | NR (≥60) | 57.4 | NR | NR | NR | 30.1 | 6.9 | X
Kattelmann, 2014^147^ (Young Adults Eating and Active for Health [YEAH]) Fair | US 2011 | | X | X | | 1639 | Young adults | | | 19.3 (18–24) | 67.2 | White: 72.1 Black: 13.1 Hisp: 5.7 Asian: 9.9 AI/NA: 0.7 | NR | NR | 24.1 | NR
Katz, 2008^148^ Fair | US 2001–2002 | | | X | | 316 | Adults | | | NR (≥18) | 67.1 | White: 35.4 Black: 29.1 Hisp: 20.6 | NR | 30.0 | NR | NR | X
Kerr, 2016^149^(Connecting Health and Technology [CHAT]) Fair | Australia NR | | X | X | | 247 | Young adults | | | 24.3 (18–30) | 65.6 | White: 77.3 Black: 0.4 Asian: 16.6 | NR | NR | 24.4 | 5.3
King, 2007^153^ (Community Health Advice by Telephone [CHAT]) Fair | US NR | | | X | X | 218 | Adults | X | | 60.8 (≥55) | 69.8 | White: 87.3 | 64.0 | NR^##^ | 29.5 | NR
King, 2013^152^ (Counseling Advice for Lifestyle Management [CALM]) Good | US NR | | | X | | 200 | Adults | X | | 55.2 (≥45) | 51.3 | White: 70.6 | 68.0 | NR^***^ | 29.2 | NR
Kinmonth, 2008^154^ Fair | UK 2001–2003 | X | X | X | | 365 | Adults with family history of type 2 diabetes^†††^ | | X | 40.6 (30–50) | 62.0 | NR | NR | NR | 27.8 | NR | X
Kolt, 2007^155^ Good | New Zealand 2003–2004 | X | | X | X | 186 | Older adults | X | | 74.2 (≥65) | 66.1 | NR | NR | 44.1 | NR | NR | X
Kristal, 2000^156^ (Puget Sound Eating Patterns [PEP]) Fair | US 1997–1998 | | X | X | | 1,459 | Adults | | | 44.9 (18–69) | 49.1 | White: 85.9 Black: 4.5 Hisp: 3.0 Asian: 5.8 | NR | NR | 26.5 | 14.1 | X
Lawton, 2008^160^ Good | New Zealand 1999–2002, 2004–2005 | | X | X | X | 1,089 | Women | X | | 58.9 (40–74) | 100 | White: 77.7 Asian: 13.1 | NR | NR | 29.2 | 12.6 | X
Lewis, 2013^161^ Good | US 2005–2008 | | | X | | 448 | Adults | X | | 42.6 (≥18) | 87.1 | White: 69.9 Black: 25.4 | 88.0 | 57.8 | NR | 13.6
Lutz, 1999^162^ Fair | US 1995 | | | X | | 710 | Adults | | | 39.3 (≥18) | 64.4 | White: 77.9 Black: 19.3 | NR | 60.0 | NR | NR | X
Mailey, 2014^164^ Fair | US 2011 | | | X | | 141 | Women | X | | 37.3 (25–52) | 100 | White: 80.1 Black: 9.2 Asian: 7.1 | 100 | 87.2 | NR | NR
Marcus, 2007^167^ (Project STRIDE) Fair | US NR | | | X | | 239 | Adults | X | | 44.5 (18–65) | 82.0 | White: 90.3 | 90.4 | 70.6 | 28.1 | 12.6
Marcus, 2013^166^ (Seamos Saludable Trial) Good | US 2009–2013 | | | X | | 292 | Hispanic/Latina women | X | | 40.7 (18–65) | 100 | Hisp: 100 | 53.0 | 46.2 | 29.4 | NR
Marsaux, 2015^169^ (Food4Me) Fair | Europe^*****^ 2012–2013 | | | X | | 1,067 | Adults | | | 39.9(18–79) | 58.4 | White: 96.8 Black: 0.1 Asian: 0.7 | NR | NR | 25.5 | 12.1
Marshall, 2003^170^ Fair | Australia 1997 | | | X | | 462 | Adults | | | 49.0 (40–60) | 57.6 | NR | NR | NR | 26.4 | NR
Martinson, 2008^172^ (Keep Active Minnesota) Good | US 2004–2005 | | | X | | 1,049 | Adults | | | 57.1 (50–70) | 72.4 | White: 94.0 Black: 3.3 Hisp: 1.8 Asian: 0.9 AI/NA: 0.2 | NR | 66.7 | 27.6 | NR | X
Mosca, 2008^176^ (Family Intervention Trial for Heart Health [FIT Heart]) Good | US 2005–2007 | | X | X | | 501 | Adults with family history of CVD^‡‡‡^ | | X | 48 (20–79) | 66.3 | White: 64.5 | 74.0 | 78.0 | 28.1 | 10.2 | X
Napolitano, 2006^177^ Fair | US 2002–2005 | | | X | | 280 | Women | X | | 47.2 (18–65) | 100 | White: 94.6 Hisp: 27.9 | 81.4 | 54.5 | 28.7 | NR
Norris, 2000^179^ Fair | US NR | X | | X | X | 847 | Adults | | | 54.9 (≥30) | 52.1 | White: 90.9 | NR | 82.2 | NR | 19.3 | X
Parekh, 2014^181^ (10 Small Steps Study) Fair | Australia 2008 | | | X | | 4,676 | Adults | | | 46.9 (18–70) | 69.2 | NR | 65.2 | 58.7 | NR | NR | X
Pekmezi, 2009^184^ (Seamos Activas [Let’s Be Active]) Fair | US 2007–2008 | | | X | | 93 | Hispanic/ Latina women | X | | 41.4 (18–65) | 100 | Hisp: 100 | NR | 52.0 | NR | NR
Pinto, 2002^185^ Fair | US NR | | | X | | 298 | Adults | X | | 45.9 (≥25) | 72.1 | White: 44.9 Black: 44.6 | 85.2 | 71.0 | 28.7 | 18.5 | X
Pinto, 2005^186^ (Physically Active for Life 2 [PAL2]) Fair | US 2000–2002 | | | X | | 100 | Older adults | X | | 68.5 (≥60) | 65.0 | White: 81.0 Black: 14.0 | 30.1 | 57.9 | 29.2 | NR | X
Roderick, 1997^188^ Fair | UK 1991–1993 | | X | X | | 956 | Adults | | | 47.3 (35–59) | 50.0 | NR | NR | NR | 26.1 | 28 | X
Ruffin, 2011^189^ (Family Healthware Impact Trial) Fair | US 2005–2007 | | | X | | 4,248 | Adults | | | 50.6 (35–65) | 69.7 | White: 91.2 Black: 3.2 Hisp: 2.3 Asian: 2.8 AI/NA: 0.1 | NR | NR | 27.3 | 7.7 | X
Sacerdote, 2006^190^ Fair | Italy NR | | X | X | X | 3,179 | Adults | | | 44.4 (18–65) | 50.0 | NR | NR | NR | NR | NR | X
Simkin-Silverman, 1995^194^ (Women’s Healthy Life-style Project [WHLP]) Good | US 1992–1994 | | X | X | | 535 | Premenopausal women | | | 47.1 (44–50) | 100 | White: 97.8 | 86.0 | 85.0 | 25.1 | 9
Smith, 2014^197^ Fair | Australia NR | | | X | | 59 | Overweight or obese women with history of gestational diabetes^§§§^ | | X | 35.4 (NR) | 100 | NR | 49.0 | 59.3 | 30.5 | NR | X
Springvloet, 2015^198^ Fair | Netherlands 2012 | | | X | | 1,349 | Adults | | | 49.4(20–65) | 64.6 | NR | NR | 45.7 | 25.6 | NR
Stewart, 2001^201^ (Community Healthy Activities Model Program for Seniors [CHAMPS II]) Fair | US NR | | | X | | 173 | Older adults^\|\|\|\|\|\|^ | X | | 74.4 (65–90) | 65.9 | NR | NR | 56.1 | NR | NR | X
Taveras, 2011^203¶¶¶^ Fair | US 2008 | | | X | | 84 | Postpartum women^###^ | | | 32.9 (NR) | 100 | White: 74.0 | NR | 93.0 | 23.5 | NR | X
Thompson, 2008^207^ Fair | US 2002–2006 | | X | X | | 200 | American Indian women^****^ | | | 29.2 (18–40) | 100 | AI/NA: 100 | NR | 84.6 | 29.4 | NR
Thompson, 2014^208^ (Go4Life) Good | US NR | | X | X | X | 49 | Older adults | X | | 79.5 (≥65) | 81.2 | NR | NR | NR | NR | NR
Tinker, 2008^209^ (Women’s Health Initiative Dietary Modification Trial [WHI DMT]) Good | US 1993–1998 | X | X | X | | 48,835 | Postmenopausal women^††††^ | X | | 62.2 (50–79) | 100 | White: 82.4 Black: 10 Hisp: 3.7 Asian: 2.2 AI/NA: 0.4 | NR | NR | 28.9 | 6.7
TOHP I, 1992^204^ (Trials of Hypertension Prevention, Phase 1 [TOHP-I]) Fair | US 1987–1988 | X | X | X | | 744 | Adults with high-normal DBP^‡‡‡‡^ | | X | 43.0 (30–54) | 28.6 | White: 77.2 Black: 20.3 | 91.8 | 55.3 | 27.1 | 10.9
TOHP II, 1997^205^ (Trials of Hypertension Prevention, Phase 2 [TOHP-II]) Good | US 1990–1992 | X | X | X | | 1190 | Moderately overweight adults with high-normal DBP^§§§§^ | | X | 43.7 (30–54) | 33.4 | White: 80.3 Black: 17.1 | 88.2 | 52.4 | 30.9 | 8.9
Tokunaga-Nakawatase, 2014^210^ (Lifestyle Intervention Support Software for Diabetes Prevention [LISS-DP]) Fair | Japan 2010 | | | X | | 216 | Adults with family history of type 2 diabetes^\|\|\|\|\|\|\|\|^ | | X | 45.2 (30–60) | 34.8 | NR | 49.0 | 39.0 | 22.7 | NR | X
Valve, 2013^211^ (LINDA) Fair | Finland 2006 | | X | | | 3059 | College-age women | | | 19.0 (17–21) | 100 | NR | NR | 47.8 | 22.0 FN: Median | NR
Van Hoecke, 2014^212^ Fair | Belgium NR | X | | X | | 442 | Older adults | X | | 69.5 (60–93) | 66.7 | NR | NR | 32.6^¶¶¶¶^ | 27.1 | NR
Van Stralen, 2010^214^ Fair | Netherlands 2007 | | | X | | 8,500 | Adults | | | 64.0 (≥50) | 57.0 | NR | 45.0 | 52.0 | 25.5 | NR | X
Vandelanotte, 2005^217^ Fair | Belgium NR | | | X | | 1,023 | Adults | | | 39.1 (20–60) | 64.5 | NR | 86.3 | 69.6 | 24.5 | NR
Vrdoljak, 2013^218^ Fair | Croatia 2008 | | | X | | 738 | Older adults | | | 72.3 (≥65) | 61.2 | NR | NR | NR | NR | 6.8 | X
Wadsworth, 2010^219^ Fair | US NR | | X | X | | 91 | College-age women | X | | NR (NR) | 100 | NR | NR | NR | 27.5 | NR
Warner, 2016^220^ (Active Retirement) Fair | Germany 2012 | | | X | | 360 | Older adults | X | | 70.3 (64–92) | 75.2 | NR | NR | NR | NR | NR

* 2–12 months postpartum.

† Study inclusion criteria required BMI of 25–34.9 kg/m^2^; at baseline, 36.4% with hypertension and 6.5% with diabetes.

‡ Includes both combined and healthful diet–only intervention arms.

§ Study inclusion criteria required 2 first-degree relatives or 1 first-degree and ≥2 second-degree relatives with type 2 diabetes; at baseline, 13% had impaired fasting glucose.

|| 15.8 mean years of education.

¶ 38.9% with hypertension and 24.5% taking medication for hypertension at baseline.

# 52.4% with hypertension, 10.5% with diabetes, and 19.0% with previous CVD at baseline.

** 24.4% with hypertension and 8.2% with diabetes at baseline.

†† Includes combined, healthful diet–only, and physical activity–only intervention arms.

‡‡ Study inclusion criteria required serum cholesterol of 5.2–7.8 mmol/L, FBG ≤6.7 mmol/L, fasting triglycerides ≤5.6 mmol/L, and DBP ≤100 mm Hg.

§§ Study inclusion criteria required BMI of 25–39.9 kg/m^2^ and SBP of 130–159 mm Hg or DBP of 80–99 mm Hg.

|||| Study inclusion criteria required DBP of 76–99 mm Hg at baseline and DBP of 78–89 mm Hg 7–30 days later.

¶¶ Study inclusion criteria required BMI of 25–40 kg/m^2^ and abdominal obesity of ≥88 cm for women or ≥102 cm for men.

## 16.2 mean years of education.

*** 15.8 mean years of education.

††† Study inclusion criteria required parental history of type 2 diabetes.

‡‡‡ Study inclusion criteria required that participants had a blood relative, spouse, or cohabitant who had acute atherosclerotic CVD; at baseline, 34.1% with hypertension and 21% were taking medication for hypertension.

§§§ Study inclusion criteria required diagnosis with gestational diabetes within the past 4 years, BMI not reported.

|||||| 39.6% with hypertension and 7.3% with diabetes at baseline.

¶¶¶ Nonrandomized clinical controlled trial.

### 0–1 month postpartum.

**** 21.0% with impaired fasting glucose at baseline.

†††† 37.7% with hypertension at baseline.

‡‡‡‡ Study inclusion criteria required average DBP of 80–89 mm Hg after 3 visits.

§§§§ Study inclusion criteria required BMI of 26.1–37.4 kg/m^2^ for men and 24.4–37.4 kg/m^2^ for women and average DBP of 83–89 mm Hg and SBP <140 mm Hg.

|||||||| Study inclusion criteria required 1 first-degree relative with type 2 diabetes.

¶¶¶¶ ≥15 mean years of education.

#### PCP=conducted in or recruited from primary care setting (X=yes).

***** 7 European countries (Germany, Greece, Ireland, the Netherlands, Poland, Spain, and the United Kingdom).

Abbreviations: AI=American Indian; BMI=body mass index; BP=blood pressure; CVD=cardiovascular disease; DBP=diastolic blood pressure; elev=elevated; empl=employed; FBG=fasting blood glucose; Hisp=hispanic; HS=high school education; KQ=key question; NA=Native American; NR=not reported; PCP=primary care provider; rand=randomized; SBP=systolic blood pressure; Subopt=suboptimal; US=United States, UK=United Kingdom; yr=year; zBMI=body mass index z score.

### Study Characteristics

All of the included studies were RCTs, with the exception of one study that was a nonrandomized controlled clinical trial (Table 2).^203^ Fourteen trials were cluster RCTs with randomization of physicians, clinics, or health care centers.^81, 92, 102, 111, 120, 122, 132, 148, 179, 188, 189, 211, 214, 218^ The majority of the studies (k=52) took place in the United States. The remaining studies were conducted in Europe (k=23), Australia (k=7), New Zealand (k=4), Canada (k=1), and Japan (k=1). Samples sizes for the included studies ranged from 49 to 48,835 participants, and the median sample size was 332. Study duration ranged from 6 months (minimum followup required per inclusion criteria) to 6 years, with the majority reporting outcomes at 6 or 12 months. Half of the studies were conducted within or recruited participants from primary care or the broader health care system (k=44). The remaining studies recruited community volunteers through mass media, targeted recruitment, or larger population-based cohorts (e.g., registered voters, research cohorts).

### Included Populations

Trials included a wide range of populations in terms of age, sociodemographic features, and clinical characteristics (Table 2). The mean age of the samples ranged from 19.0 to 79.5 years (interquartile range, 40.7 to 57.9 years). Fifteen trials specifically targeted older adults age 60 years or older; the mean age in those trials ranged from 63.2 to 79.5 years.^93, 94, 100, 117, 125, 128, 132, 146, 155, 186, 201, 208, 212, 218, 220^ All but three of these trials among older adults focused solely on increasing physical activity. The remaining three focused on improving diet^93, 125^ or improving both diet and physical activity.^100^ Most of the studies (k=71) included both men and women, but one study was limited to men only^135^ and 18 studies were limited to women only.^83, 91, 106, 113, 119, 126, 160, 164, 166, 177, 184, 194, 197, 203, 207, 209, 211, 219^ Many of the studies limited to women were further restricted to specific racial/ethnic subgroups (i.e., American Indian,^207^ Hispanic/Latina,^126, 166, 184^ black^91^), age groups (college age^211, 219^), and postpartum status^83, 203^ or mothers of young children.^113, 164^ Of the 53 studies that reported race/ethnicity, the percentage of nonwhite participants ranged from 2.2 to 100 percent; in only 15 of these studies was more than two thirds of the sample nonwhite. For studies that reported the education level of participants, the proportion of participants with more than a high school education (i.e., some college, vocational or technical school, or more) ranged from 16.8 to 93.0 percent (Table 2).

Among the 88 trials, 37 studies limited inclusion to persons with suboptimal levels of physical activity (e.g., <150 minutes of moderate- to vigorous-intensity physical activity per week), inadequate dietary habits (e.g., suboptimal intake of fruits, vegetables, red and processed meats, whole-fat dairy foods, or whole grains), or both. Thirteen of the 88 trials were specifically among persons at higher risk for CVD (but without levels of traditional CVD risk factors reaching diagnostic thresholds), including those with high-normal blood pressure (e.g., DBP of 80 to 89 mm Hg);^137, 140, 204, 205^ men with moderately elevated cholesterol, fasting blood glucose, triglyceride, and blood pressure levels^135^; those with a family history of type 2 diabetes^97, 154, 210^ or CVD^176^; women who were overweight or had obesity and a history of gestational diabetes^197^; black women who were overweight or had obesity^91^; and adults age 60 years or older who were overweight or had obesity.^117, 146^ In the remaining 38 studies, participants were not chosen on the basis of their baseline behavior or cardiovascular risk but instead represented a general, unselected population. While we excluded trials conducted exclusively among persons with hypertension, dyslipidemia, or impaired fasting glucose, a few of the studies included some participants with hypertension (2.8% to 70.7%), dyslipidemia (11.3% to 27.4%), impaired fasting glucose (13.0% to 21.0%), or diabetes (6.5% to 12.0%). Of the 62 studies that reported baseline mean BMI, the range was 22.0 to 32.9 kg/m^2^ (mean, 27.7 kg/m^2^). The mean BMI was in the overweight range (i.e., 25.0 to 29.9 kg/m^2^) in nearly half of the studies (k=42) and in the obese range (≥30 kg/m^2^) in 12 studies. The proportion of current smokers included in the studies ranged from 3.5 to 38 percent (Table 2).

### Included Interventions

Within the 88 trials there were 121 distinct intervention arms (Table 3). Twenty-three trials focused on both healthful diet and physical activity, 24 focused on healthful diet only, and 44 focused on physical activity only. (Two trials contributed to more than one intervention category;^97, 135^ hence, the number of trials does not equal 88 across these groups.) Most of the newly added trials (published from 2010 to the present) focused on physical activity (20 of 38 new trials); only five new trials focused on healthful diet only. Fourteen new trials had intervention components aimed at improving both healthful diet and physical activity. Across all 121 intervention arms, 40 arms were low intensity (≤30 minutes of estimated contact time), 55 were medium intensity (31 to 360 minutes), and 26 were high intensity (>360 minutes [6 hours]). Intervention intensity ranged from 3 to 2,340 minutes (39 hours) (mean, 371 minutes [6 hours and 11 minutes]) (Figure 2). Details of all of the interventions are provided in Table 4 and Appendix E Table 1.

Table 3 List of Study-Specific Intervention Arms, by Intervention Focus and Intensity (121 Arms in 88 Trials^*^)

Low intensity (≤30 min) 41 arms (29 trials) | Healthful Diet + Physical Activity 32 arms (23 trials) | Healthful Diet 31 arms (24 trials) | Physical Activity 58 arms (44 trials)
Low intensity (≤30 min) 41 arms (29 trials) | 9 arms (5 trials) | 10 arms (7 trials) | 21 arms (16 trials)
Low intensity (≤30 min) 41 arms (29 trials) | Jeffery, 1999^143^ (IG1) | Beresford, 1997^92^ (IG1) | Aittasalo, 2006^81^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | Jeffery, 1999^143^ (IG2) | Carpenter, 2004^101^ (IG2) | Aittasalo, 2006^81^ (IG2)
Low intensity (≤30 min) 41 arms (29 trials) | Marsaux, 2015^169^ (IG1)^§^ | Fries, 2005^116^ (IG1) | Bryan, 2013^98^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | Marsaux, 2015^169^ (IG2)^§^ | Kerr, 2016^149^ (IG1)^§^ | Carroll, 2010^102^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | Marsaux, 2015^169^ (IG3)^§^ | Kerr, 2016^149^ (IG2)^§^ | de Vet, 2009^108^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | Parekh, 2014^181^ (IG1)^§^ | Kristal, 2000^156^ (IG1) | de Vet, 2009^108^ (IG2)
Low intensity (≤30 min) 41 arms (29 trials) | Parekh, 2014^181^ (IG2)^§^ | Lutz, 1999^162^ (IG1) | de Vet, 2009^108^ (IG3)
Low intensity (≤30 min) 41 arms (29 trials) | Ruffin, 2011^189^ (IG1)^§^ | Lutz, 1999^162^ (IG2) | Gell, 2015^119^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | Tokunaga-Nakawatase, 2014^210^ (IG1)^§^ | Lutz, 1999^162^ (IG3) | Goldstein, 1999^120^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | | Sacerdote, 2006^190^ (IG1) | Grandes, 2009^122^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | | | Hellenius, 1993^135^ (IG2)
Low intensity (≤30 min) 41 arms (29 trials) | | | Lewis, 2013^161^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | | | Marcus, 2013^166^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | | | Marshall, 2003^170^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | | | Napolitano, 2006^177^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | | | Napolitano, 2006^177^ (IG2)
Low intensity (≤30 min) 41 arms (29 trials) | | | Pekmezi, 2009^184^ (IG1)
Low intensity (≤30 min) 41 arms (29 trials) | | | Van Hoecke, 2014^212^ (IG2)^§^
Low intensity (≤30 min) 41 arms (29 trials) | | | Van Stralen, 2010^214^ (IG1)^§^
Low intensity (≤30 min) 41 arms (29 trials) | | | Van Stralen, 2010^214^ (IG2)^§^
Low intensity (≤30 min) 41 arms (29 trials) | | | Wadsworth, 2010^219^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | 13 arms (10 trials) | 10 arms (8 trials) | 32 arms (25 trials)
Medium intensity (31–360 min) 55 arms (42 trials) | Burke, 2013^100^ (IG1)^§^ | Alexander, 2010^86^ (IG1)^§^ | Aadahl, 2014^80^ (IG1)^†§^
Medium intensity (31–360 min) 55 arms (42 trials) | Franko, 2008^115^ (IG1) | Alexander, 2010^86^ (IG2)^§^ | Albright, 2014^83^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Franko, 2008^115^ (IG2) | Baron, 1990^90^ (IG1) | Bickmore, 2013^94^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Hellenius, 1993^135^ (IG3) | Delichatsios, 2001^109^ (IG1) | Castro, 2011^103^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Kattelmann, 2014^147^ (IG1)^§^ | Greene, 2008^125^ (IG1) | Castro, 2011^103^ (IG2)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | King, 2013^152^ (IG1)^§^ | Hellenius, 1993^135^ (IG1) | Elley, 2003^111^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | Mosca, 2008^176^ (IG1) | John, 2002^144^ (IG1) | Estabrooks, 2011^112^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Smith, 2014^197^ (IG1)^§^ | Roderick, 1997^188^ (IG1) | Fjeldsoe, 2015^113^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Valve, 2013^211^ (IG1)^§^ | Springvloet, 2015^198^ (IG1)^§^ | Gao, 2016^117^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Vandelanotte, 2005^217^ (IG1) | Springvloet, 2015^198^ (IG2)^§^ | Green, 2002^123^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | Vandelanotte, 2005^217^ (IG2) | | Halbert, 2000^128^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | Vandelanotte, 2005^217^ (IG3) | | Hargreaves, 2016^130^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | Vrdoljak, 2013^218^ (IG1)^‡§^ | | Harland, 1999^131^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Harland, 1999^131^ (IG2)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Harland, 1999^131^ (IG3)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Harland, 1999^131^ (IG4)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Harris, 2015^132^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | | | Kallings, 2009^146^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | King, 2007^153^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | King, 2007^153^ (IG2)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Kinmonth, 2008^154^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Kolt, 2007^155^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Lawton, 2008^160^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Mailey, 2014^164^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | | | Marcus, 2007^167^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Marcus, 2007^167^ (IG2)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Norris, 2000^179^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Pinto, 2002^185^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Pinto, 2005^186^ (IG1)
Medium intensity (31–360 min) 55 arms (42 trials) | | | Van Hoecke, 2014^212^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | | | Warner, 2016^220^ (IG1)^§^
Medium intensity (31–360 min) 55 arms (42 trials) | | | Warner, 2016^220^ (IG2)^§^
High intensity (>360 min) 26 arms (23 trials) | 10 arms (9 trials) | 11 arms (10 trials) | 5 arms (5 trials)
High intensity (>360 min) 26 arms (23 trials) | Aldana, 2006^85^ (IG1) | Bernstein, 2002^93^ (IG1) | Katz, 2008^148^ (IG1)^‡^
High intensity (>360 min) 26 arms (23 trials) | Aldana, 2006^85^ (IG1) | Brekke, 2005^97^ (IG1) | Kinmonth, 2008^154^ (IG2)
High intensity (>360 min) 26 arms (23 trials) | Bennett, 2013^91^ (IG1)^§^ | Carpenter, 2004^101^ (IG1) | Martinson, 2008^172^ (IG1)
High intensity (>360 min) 26 arms (23 trials) | Brekke, 2005^97^ (IG2) | Coates, 1999^106^ (IG1) | Stewart, 2001^201^ (IG1)
High intensity (>360 min) 26 arms (23 trials) | Hivert, 2007^72^ (IG1) | Hinderliter, 2014^137^ (IG1)^§^ | Thompson, 2014^208^ (IG1)^§^
High intensity (>360 min) 26 arms (23 trials) | Jacobs, 2011^141^ (IG1)^§^ | HPT, 1990^140^ (IG1)
High intensity (>360 min) 26 arms (23 trials) | King, 2013^152^ (IG2)^§^ | HPT, 1990^140^ (IG2)
High intensity (>360 min) 26 arms (23 trials) | King, 2013^152^ (IG3)^§^ | Greenlee, 2015^126^ (IG1)^§^
High intensity (>360 min) 26 arms (23 trials) | Simkin-Silverman, 1995^194^ (IG1) | Tinker, 2008^209^ (IG1)
High intensity (>360 min) 26 arms (23 trials) | Taveras, 2011^203^ (IG1)^§^ | TOHP I, 1992^204^ (IG1)
High intensity (>360 min) 26 arms (23 trials) | Thompson, 2008^207^ (IG1) | TOHP II, 1997^205^ (IG1)

* 25 trials had more than one intervention arm (Aittasalo, Alexander, Brekke, Carpenter, Castro, De Vet, Franko, Harland, Hellenius, HPT, Jeffery, Kerr, King 2007, King 2013, Kinmonth, Lutz, Marcus, Marsaux, Napolitano, Parekh, Springvloet, Van Hoecke, Van Stralen, Vandelotte, Warner).

† Intervention focused on reducing sedentary time (Aadahl).

‡ Intervention focused on provider training (Katz and Vrdoljak).

§ Trial identified in update.

Abbreviations: IG=intervention group; min=minute.

Figure 2 Estimated Intervention Intensity for Each Included Trial, by Intervention Focus

Abbreviations: HD=healthful diet; HD+PA=healthful diet and physical activity; PA=physical activity.

This figure shows the estimated intervention intensity (minutes of contact) for each included trial, by intervention focus, illustrating that the majority of diet interventions are high intensity (>360 min) when compared to physical activity interventions.

Table 4 Intervention Characteristics for All Studies, by Author

Author, year | Int focus Intensity | Grp | Name | Brief description | Diet focus | Dur (wks) | No. sess | Length sess (min) | Est total intensity (min) | Setting | In person | Phone | Elec | Print | Grp sess | Provider | CG
Aadahl, 2014^80^ | PA^*^ M | IG1 | Counseling | Four 30- to 45-min individual theory-based face-to-face sessions and written materials summarizing the sessions and reiterating key messages. | | 26 | 4 | 40 | 160 | Research clinic | X | | | X | | Research nurse | None
Aittasalo, 2006^81^ | PA L | IG1 | Brief counseling | One 5- to 10-min PCP prescription-based counseling session. Optional self-monitoring with PA log and referral to PA expert. | | 0.14 | 1 | 10 | 10 | Primary care | X | | | | | PCP | UC
Aittasalo, 2006^81^ | PA L | IG2 | Self-monitoring | Pedometer and PA log for self-monitoring and tailored feedback via mail. | | 1 | NA | NA | NA | Primary care | | | | X | | NA | UC
Albright, 2014^83^ | PA M | IG1 | Tailored phone counseling plus web site | 17 15-min phone counseling calls plus a tailored web site addressing key mediators of PA. | | 52 | 17 | 15 | 255 | Home | | X | X | | | Health educator/counselor | MI
Aldana, 2006^85^ | HD+PA H | IG1 | Group counseling | 16 2-hr group education sessions. | G | 4 | 16 | 120 | 1920 | NR | X | | | X | X | Dietetic and medical professional | W
Alexander, 2010^86^ | HD M | IG1 | Tailored web-based + email counseling | 4 tailored web sessions and 4 email counseling sessions aimed at increasing fruit and vegetable intake. | F&V | 52 | 8 | Web: 30 Email: 15 | 180 | Home | | | X | | | Research assistant | MI
Alexander, 2010^86^ | HD M | IG2 | Tailored web-based counseling | 4 tailored web sessions (no email sessions) aimed at increasing fruit and vegetable intake. | F&V | 52 | 4 | 30 | 120 | Home | | | X | | | NA | MI
Baron, 1990^90^ | HD M | IG1 | Counseling | One 30-min individual or small-group dietary counseling session with 2 followup visits and print materials. | G | 12 | 3 | Initial sess: 30 FU sess: NR | 60 | Primary care | X | | | X | X | Nurse | UC
Bennett, 2013^91^ | HD+PA H | IG1 | Counseling, tailored print materials and self-monitoring | Behavior change goals assigned at baseline and months 2 and 4, with pedometers and logs to track daily activity, brief 5-min weekly calls with interactive phone system, 12 monthly 20-min counseling calls with RD, and 12-month membership to YMCA. | G | 52 | 64 | IVR calls: 5 RD calls: 20 | 500 | Primary care | X | X | | X | | RD | UC
Beresford, 1997^92^ | HD L | IG1 | Brief counseling and self-help material | Self-help booklet and a 3-min motivational endorsement from PCP. | LF | 2 | 1 | 3 | 3 | Primary care | X | | | X | | PCP | UC
Bernstein, 2002^93^ | HD H | IG1 | Home-based education | Home-based nutrition education including 8 home visits, 12 phone calls, and monthly print materials. | F&V | 26 | 20 | NR | 420 | Home | X | X | | X | | NR | AC
Bickmore, 2013^94^ | PA M | IG1 | Computer-based counseling | Daily 5-min conversations with virtual coach on home computer tablet for 2 months and continued use of electronic counseling interface at clinic kiosk when attending routine appointments over remaining 10 months. | | 52 | 61 | 5 | 305 | Home | | | X | | | Computer | MI
Brekke, 2005^97^ | HD H | IG1 | Group counseling (diet) | 2 60- to 120-min initial group education sessions, 8 followup phone calls in first 4 months, and then every 10 weeks for 2 years. | F&V, LF | 104 | 18 | Group sess: 90 Calls: 15 | 420 | NR | X | X | | | X | Dietician | MI
Brekke, 2005^97^ | HD+PA H | IG2 | Group counseling (diet and PA) | 2 60- to 120-min initial group education sessions, 8 followup phone calls in first 4 months, and then every 10 weeks for 2 years. | F&V, LF | 104 | 18 | Group sess: 90 Calls: 15 | 420 | NR | X | X | | | X | Dietician | MI
Bryan, 2013^98^ | PA L | IG1 | Tailored print mailings | 14 individually-tailored mailings with information on increasing PA delivered at varying frequencies over 12 months, with self-help manual and series of tip sheets. | | 52 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Burke, 2013^100^ | HD+PA M | IG1 | Self-help booklet and phone and email counseling | Booklet designed to motivate and improve PA and nutrition, 6 to 10 phone calls, 2 to 5 email contacts, bimonthly newsletters, resistance band and pedometer. | G | 26 | 8 | 15 | 120 | Home | | X | X | X | | Senior university health science student | None
Carpenter, 2004^101^ | HD H | IG1 | Group counseling | 20 75-min group counseling sessions. | F&V, LF, S | 24 | 20 | 75 | 1500 | Research clinic | X | | | X | X | Research staff | MI
Carpenter, 2004^101^ | HD L | IG2 | Mailed materials and web site | Mailed curriculum and access to web site for posting questions and weekly online chat session. | F&V, LF, S | 24 | NA | NA | NA | Home | | | X | X | | NA | MI
Carroll, 2010^102^ | PA L | IG1 | Tailored print mailings | 4 tailored feedback reports based on preceding PA survey mailed to participants over 6 months. | | 26 | NA | NA | NA | Home | | | | X | | NA | AC
Castro, 2011^103^ | PA M | IG1 | Counseling | 1 in-person session with professional followed by 14 phone counseling calls, supplemented with monthly newsletter mailings and tip sheets. | | 52 | 15 | Initial sess: 30 Calls: 15 | 240 | Home | X | X | | X | | Professional staff member | AC
Castro, 2011^103^ | PA M | IG2 | Peer counseling | 1 in-person session with peer mentor followed by 14 phone counseling calls, supplemented with monthly newsletter mailings and tip sheets. | | 52 | 15 | Initial sess: 30 Calls: 15 | 240 | Home | X | X | | X | | Peer mentor | AC
Coates, 1999^106^ | HD H | IG1 | Group counseling | Up to 18 group counseling sessions. | LF | 52 | 18 | 60 | 1080 | Research clinic | X | | | | X | Nutritionist | MI
de Vet, 2009^108^ | PA L | IG1 | Self-directed and self-selected activity plan (with repeat planning) | Self-directed written plan for increasing self-selected PA by 2 hr/week, written at 3 different time points over 6 months. | | 26 | NA | NA | NA | Home | | | | X | | NA | MI
de Vet, 2009^108^ | PA L | IG2 | Self-directed and self-selected activity plan (1-time plan) | Self-directed written plan for increasing self-selected PA by 2 hr/week. | | 26 | NA | NA | NA | Home | | | | X | | NA | MI
de Vet, 2009^108^ | PA L | IG3 | Self-directed walking plan (1-time plan) | Self-directed written plan for increasing walking by 2 hr/week. | | 26 | NA | NA | NA | Home | | | | X | | NA | MI
Delichatsios, 2001^109^ | HD M | IG1 | Automated phone counseling | 26 5- to 7-min calls with an automated phone-linked communication system providing dietary counseling, advice, and feedback over 6 months, with additional written reports to supplement calls. | G | 26 | 26 | 5 | 130 | Other | | X | | | | Expert system with digitized human speech | AC
Elley, 2003^111^ | PA M | IG1 | Counseling with tailored prescription | One 10-min PCP prescription-based counseling session with three 15-min followup phone calls from exercise physiologists over 3 months and 4 newsletters over 12 months. | | 52 | 4 | Initial sess: 10 Calls: 15 | 55 | Primary care | X | X | | X | | PCP, Exercise physiologists | UC
Estabrooks, 2011^112^ | PA M | IG1 | Group counseling | Two 2-hr group sessions, 1 phone contact, and handouts on how to complete a PA plan. | | 12 | 3 | Group sess: 120 Calls: 15 | 255 | Research clinic | X | X | | X | X | Health educator | MI
Fjeldsoe, 2015^113^ | PA M | IG1 | Counseling and regular text messages | 1 face-to-face counseling session, 12 weeks of tailored text messages, and 1 followup phone call. | | 12 | 2 | 35 | 50 | Home | X | X | X | X | | Behavioral counselor | MI
Franko, 2008^115^ | HD+PA M | IG1 | Web-based intervention + booster session | Two 45-min computer-based interactive sessions plus 1 booster session. | G | 5 | 3 | 45 | 135 | University computer lab and home | | | X | | | Research assistant: oversaw web sessions + answered questions | AC
Franko, 2008^115^ | HD+PA M | IG2 | Web-based intervention | Two 45-min computer-based interactive sessions. | G | 2 | 2 | 45 | 90 | University computer lab | | | X | | | Research assistant: oversaw web sessions + answered questions | AC
Fries, 2005^116^ | HD L | IG1 | Tailored print mailing and brief counseling call | 1 mailing of individually-tailored fat + fiber feedback with physician endorsement, minimal brief counseling call, and 5 low-literacy self-help booklets. | LF | 6 | 1 | NR | 15 | Home | | X | | X | | Research staff | WL
Gao, 2016^117^ | PA M | IG1 | Individual counseling and tailored print materials | Initial 60-min counseling session followed by 14 expert computer-tailored print mailings. | | 52 | 1 | 60 | 60 | Home | X | | X | | | PCP, expert computer system | AC
Gell, 2015^119^ | PA L | IG1 | Targeted text messages | 3 targeted text messages per week for 24 weeks plus walking maps and informational web site. | | 24 | NA | NA | NA | Other | | X | X | | | NA | MI
Goldstein, 1999^120^ | PA L | IG1 | Brief counseling with tailored prescription | One 5-min PCP prescription-based counseling session with one 5-min followup session over 4 weeks plus 9 mailings over 26 weeks. | | 26 | 2 | 5 | 10 | Primary care | X | | | X | | PCP | UC
Grandes, 2009^122^ | PA L | IG1 | Brief counseling | 1 brief (assumed <15 min) counseling session with PCP using web-based software + optional 15-min followup session to develop a prescription-based action plan, plus a 4-page pamphlet. | | NR | 2 | 15 | 30 | Primary care | X | | | X | | PCP | UC
Green, 2002^123^ | PA M | IG1 | Phone counseling | Mailed self-help workbook and three 20- to 30-min counseling phone calls.^†^ | | 12 | 3 | 25 | 75 | Home | | X | | X | | Behavioral health specialists | MI
Greene, 2008^125^ | HD M | IG1 | Tailored print mailings and counseling phone calls | 12 monthly tailored mailings and three 15-min coaching phone calls. | F&V | 52 | 3 | 15 | 45 | Home | | X | | X | | Counselor, Computer expert system | AC
Greenlee, 2015^126^ | HD H | IG | Group counseling | Nine 1.5- to 3.5-hr group sessions. | F&V, L | 12 | 9 | 160 | 1440 | Research clinic | X | | | X | X | Registered dietitican | MI
Halbert, 2000^128^ | PA M | IG1 | Counseling | One 20-min counseling session and print materials on increasing PA at intial visit and two 15-min followup visits. | | 26 | 3 | 20 | 50 | Primary care | X | | | X | | Exercise physiologist | AC
Hargreaves, 2016^130^ | PA M | IG1 | Tailored walking program | Tailored pedometer- and web-based walking program. | | 12 | 13 | Initial sess: 30 Web sess: 10 | 150 | Home | X | | X | | | NR | MI
Harland, 1999^131^ | PA M | IG1 | Counseling and PA vouchers | 1 brief informational and advice session followed by six 40-min motivational interviews plus 30 vouchers for PA facilities. | | 12 | 7 | Initial sess: 15 MI: 40 | 255 | Primary care | X | | | X | | Health visitor | MI
Harland, 1999^131^ | PA M | IG2 | Counseling | 1 brief informational and advice session followed by six 40-min motivational interviews. | | 12 | 7 | Initial sess: 15 MI: 40 | 255 | Primary care | X | | | X | | Health visitor | MI
Harland, 1999^131^ | PA M | IG3 | Brief counseling and PA vouchers | 1 brief informational and advice session followed by one 40-min motivational interview plus 30 vouchers for PA facilities. | | 2 | 2 | Initial sess: 15 MI: 40 | 55 | Primary care | X | | | X | | Health visitor | MI
Harland, 1999^131^ | PA M | IG4 | Brief counseling | 1 brief informational and advice session followed by one 40-min motivational interview. | | 2 | 2 | Initial sess: 15 MI: 40 | 55 | Primary care | X | | | X | | Health visitor | MI
Harris, 2015^132^ | PA M | IG1 | Counseling and self-monitoring | 1 initial 45-min PA consultation session followed by three 30-min sessions with pedometers, accelerometers, and a PA log to track activity. | | 52 | 4 | Initial sess: 45 FU sess: 30 | 135 | Primary care | X | | | | | Nurse | UC
Hellenius, 1993^135^ | HD M | IG1 | Counseling (diet) | 1 dietary advice session with physician (assumed 30-min) followed by 1 advice session 2 weeks later with dietitian. | G | 2 | 2 | 30 | 60 | Primary care | X | | | X | | PCP, Dietician | UC
Hellenius, 1993^135^ | PA L | IG2 | Brief counseling (PA) | 1 PA advice session with physician (assumed 30-min). | | 0.14 | 1 | 30 | 30 | Primary care | X | | | | | PCP | UC
Hellenius, 1993^135^ | HD+PA M | IG3 | Counseling (diet + PA) | 1 dietary and PA advice session with physician (assumed 30-min) followed by 1 advice session 2 weeks later with dietitian. | G | 2 | 2 | 30 | 60 | Primary care | X | | | | | Dietician, PCP | UC
Hinderliter, 2014^137^ | HD H | IG1 | Group counseling on DASH diet | 2 weeks of a DASH-controlled feeding period with 4 counseling sessions followed by 14 weekly 30- to 45-min small group sessions with nutritionist; participants were asked not to exercise or attempt to lose weight. | G | 16 | 18 | Indiv sess: NR Group sess: 30–45 | 620 | Research clinic | X | | | | X | Nutritionist | MI
Hivert, 2007^72^ | HD+PA H | IG1 | Group counseling | 23 45-min small-group interactive seminars over 2 years. | G | 104 | 23 | 45 | 1035 | Other | X | | | | X | Endocrinology resident and physical education graduate student | None
HPT, 1990^140^ | HD H | IG1 | Group counseling (potassium and sodium focus) | 12 weekly 60-min group counseling sessions in first 4 months followed by 16 group counseling sessions for up to 3 years in maintenance phase to increase potassium and reduce sodium intake. | S | 156 | 28 | 60 | 1680 | Research clinic | X | X | | X | X | Nutiritionists and behavioral specialists | None
HPT, 1990^140^ | HD H | IG2 | Group counseling (sodium focus) | 12 weekly 60-min group counseling sessions in first 4 months followed by 16 group counseling sessions for up to 3 years in maintenance phase to reduce sodium intake (potassium intake not discussed) | S | 156 | 28 | 60 | 1680 | Research clinic | X | X | | X | X | Nutiritionists and behavioral specialists | None
Jacobs, 2011^141^ | HD+PA H | IG1 | Counseling | Received individually tailored PA + diet counseling via delivery mode of participant’s choice, including email, phone, or face-to-face sessions over 1 year. | LF | 52 | 15 | 30 | 380^‡^ | Research clinic | X | X | X | | | Health psychologist | UC
Jeffery, 1999^143^ | HD+PA L | IG1 | Nontailored print mailings | 36 monthly newsletters mailed to encourage paying attention to weight, diet, and exercise habits plus optional intervention sessions every 6 months up to 3 years. | F&V, LF | 156 | NA | NA | NA | Home | | | | X | | NA | None
Jeffery, 1999^143^ | HD+PA L | IG2 | Nontailored print mailings plus incentives | 36 monthly newsletters mailed to encourage paying attention to weight, diet, and exercise habits plus optional intervention sessions every 6 months up to 3 years, plus an incentive lottery to encourage reading the newsletters. | F&V, LF | 156 | NA | NA | NA | Home | | | | X | | NA | None
John, 2002^144^ | HD M | IG1 | Counseling | One 25-min counseling session and one 15-min followup call to encourage increased consumption of fruits and vegetables and recipe book, portion guide, and record book. | F&V | 12 | 2 | 25 | 40 | Research clinic | X | X | | X | | Research nurse | WL
Kallings, 2009^146^ | PA M | IG1 | Counseling with tailored prescription | Two 30-min individualized patient-centered counseling sessions and PA prescriptions delivered at baseline and 6 months, with one 60-min group session at 1 month focused on PA and health and 3 to 5 short followup calls. | | NR | 3 | Individ sess: 30 Group sess: 60 | 120 | Primary care | X | | | X | X | Health care professional, PCP | UC
Kattelmann, 2014^147^ | HD+PA M | IG1 | Web-based intervention | Tailored emails 4 times per week plus weekly web-based sessions. | F&V | 64 | 21 | NR | 150 | Home | | | X | | | NA | WL
Katz, 2008^148^ | PA H | IG1 | Provider training | Physicians participated in 5 interactive group sessions and were trained in how to apply the Pressure System Model to overcome common PA barriers, identify opportunities for PA, and specify a plan for followup during existing appointments. | | 26 | 5 | 75 | 375 | Primary care | X | | | | | PA and preventive medicine specialist | UC
Kerr, 2016^149^ | HD L | IG1 | Tailored text messages (with booster messages) | 2 tailored text messages over 1 week and weekly text messages for 6 months. | F&V | 24 | 32 | NR | 30 | Other | | | X | | | NA | None
Kerr, 2016^149^ | HD L | IG2 | Tailored text messages | 2 tailored text messages. | F&V | 1 | 2 | NR | 2 | Other | | | X | | | NA | None
King, 2007^153^ | PA M | IG1 | Automated phone counseling | Initial 30- to 40-min individualized session with health educator, 15 brief individualized structured calls with automated phone-linked counseling system biweekly and then monthly over 1 year, pedometer and PA log to track activity and allow feedback on progress, and supplemental mailings. | | 52 | 16 | Initial sess: 35 Calls: 15 | 260 | Home | X | X | | X | | Health educator | AC
King, 2007^153^ | PA M | IG2 | Human phone counseling | Initial 30- to 40-min individualized session with health educator, 15 brief individualized structured calls with health educator biweekly and then monthly over 1 year, pedometer and PA log to track activity and allow feedback on progress, and supplemental mailings. | | 52 | 16 | Initial sess: 35 Calls: 15 | 260 | Home | X | X | | X | | Health educator | AC
King, 2013^152^ | HD+PA M | IG1 | Phone counseling with self-monitoring (PA + diet together) | 1 individual in-person session followed by 15 30- to 40-min phone counseling sessions. PA + diet were addressed simultaneously, half of each call covered each topic; supplemental mailings and homework and pedometer for logging and reporting progress. | F&V, LF | 52 | 15 | 20 | 300^§^ | Home | X | X | | X | | Health educator | AC
King, 2013^152^ | HD+PA H | IG2 | Phone counseling with self-monitoring (diet discussions first) | 1 individual in-person session followed by 21 phone sessions; topics introduced sequentially, beginning with diet for first 4 months, then both PA + diet in the remaining 8 months; supplemental mailings and homework and pedometer for logging and reporting progress. | F&V, LF | 52 | 21 | 20 | 420^\|\|^ | Home | X | X | | X | | Health educator | AC
King, 2013^152^ | HD+PA H | IG3 | Phone counseling with self-monitoring (PA discussions first) | 1 individual in-person session followed by 21 phone sessions; topics introduced sequentially, beginning with PA for first 4 months, then both PA + diet in the remaining 8 months; supplemental mailings and homework and pedometer for logging and reporting progress. | F&V, LF | 52 | 21 | 20 | 420^¶^ | Home | X | X | | X | | Health educator | AC
Kinmonth, 2008^154^ | PA M | IG1 | Phone counseling | Initial in-home PA counseling session followed by four 45-min support calls and two 15-min support calls over 5-month intensive phase, followed by 7 monthly mailings. | | 52 | 7 | Initial sess: 30 Calls: 45 FU calls: 15 | 240 | Home | X | X | | X | | Trained facilitators from a range of health professions | MI
Kinmonth, 2008^154^ | PA H | IG2 | In-home counseling | Initial in-home PA counseling session followed by four 60-min in-home visits and two 15-min support calls over 5-month intensive phase, followed by seven 30-min monthly followup phone calls. | | 52 | 14 | Initial sess: 30 Home visit: 60 Support call: 15 FU call: 30 | 510 | Home | X | X | | X | | Trained facilitators from a range of health professions | MI
Kolt, 2007^155^ | PA M | IG1 | Phone counseling | Eight 10- to 16-min phone counseling sessions occuring weekly for 4 weeks and biweekly for 8 weeks focused on stages of behavior change in relation to increasing PA, and supplementary mailings, including an exercise log and informational pamphlets. | | 12 | 8 | 15 | 120 | Home | | X | | X | | Exercise counselor | None
Kristal, 2000^156^ | HD L | IG1 | Tailored print mailings and counseling call | Tailored self-help dietary materials and 1 followup call focused on lowered fat intake and increased fruit and vegetable intake. | F&V, LF | 52 | 1 | 15 | 15 | Home | | X | | X | | Health educator | None
Lawton, 2008^160^ | PA M | IG1 | Counseling with tailored prescription | Brief 10-min session with primary care nurse plus green prescription to increase PA, followed by five 15-min followup calls over 9 months and one 30-min followup visit. | | 38 | 7 | Initial sess: 10 FU calls: 15 FU sess: 30 | 115 | Primary care | X | X | | | | Primary care nurse | UC
Lewis, 2013^161^ | PA L | IG1 | Tailored print mailings | 11 individually-tailored PA print mailings plus stage-matched manuals, tip sheets, and PA logs. | | 26 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Lutz, 1999^162^ | HD L | IG1 | Tailored print mailings with tailored prescription | Tailored nutrition newsletters and tailored goal-setting information for increasing fruit and vegetable intake. | F&V | 16 | NA | NA | NA | Home | | | | X | | Computer expert system | None
Lutz, 1999^162^ | HD L | IG2 | Tailored print mailings | Tailored newsletters with nutrition information for increasing fruit and vegetable intake (no tailored goal-setting). | F&V | 16 | NA | NA | NA | Home | | | | X | | Computer expert system | None
Lutz, 1999^162^ | HD L | IG3 | Nontailored print mailings | Nontailored newsletters about increasing fruit and vegetable intake (no tailored newsletters or tailored goal-setting). | F&V | 16 | NA | NA | NA | Home | | | | X | | NA | None
Mailey, 2014^164^ | PA | IG1 | Group counseling | Two 90- to 120-min group counseling sessions, one 60-min personal training session, and five 5-min followup phone calls. | | 26 | 7 | Group: 105 Trainer: 60 Calls: 5 | 295 | NR | X | X | | | X | Research staff | WL
Marcus, 2007^167^ | PA M | IG1 | Phone counseling | Initial 45-min session followed by fourteen 13-min phone calls at decreasing frequency over 12 months and supplemented with a monthly PA log and brief questionnaire. | | 52 | 14 | 10 | 185 | Home | | X | | | | Health educator | AC
Marcus, 2007^167^ | PA M | IG2 | Tailored print materials | Initial 45-min session followed by fourteen individually-tailored printed reports with decreasing frequency over 12 months and supplemented with a monthly PA log and brief questionnaire. | | 52 | 1 | 45 | 45 | Home | | | | X | | Computer expert system | AC
Marcus, 2013^166^ | PA L | IG1 | Tailored print mailings and self-monitoring | 14 culturally adapted, Spanish-language, individually-tailored PA print mailings and pedometers and PA logs for self-monitoring. | | 52 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Marsaux, 2015^169^ | HD+PA L | IG1 | Tailored web-based advice (diet, PA, and phenotype) | Tailored web-based advice based on diet, PA, and phenotype. | F&V | 26 | NR | NR | NA | NR | | | X | | | NA | MI
Marsaux, 2015^169^ | HD+PA L | IG2 | Tailored web-based advice (diet + PA) | Tailored web-based advice based on diet and PA. | F&V | 26 | NR | NR | NA | NR | | | X | | | NA | MI
Marsaux, 2015^169^ | HD+PA L | IG3 | Tailored web-based advice (diet, PA, phenotype, and genotype) | Tailored web-based advice based on diet, PA, phenotype, and genotype. | F&V | 26 | NR | NR | NA | NR | | | X | | | NA | MI
Marshall, 2003^170^ | PA L | IG1 | Tailored print mailing | 1-time mailing of letter tailored to individual stage of change and Active Living booklets corresponding to stage of change, and additional booklets aimed at higher stages of change. | | 0.14 | NA | NA | NA | Home | | | | X | | NA | None
Martinson, 2008^172^ | PA H | IG1 | Counseling | One 60-min in-person group orientation session, followed by seven 20-min individualized sessions occurring twice a month with activity coach, and monthly followup calls for 8 months and bimonthly for subsequent year. Additional materials included a PA log, course workbook, and pedometer, with optional library of PA informational resources and 4 in-person support sessions held over 2-year intervention period. | | 104 | 26 | Initial group sess: 60 Indiv sess: 20 Calls: 20 | 450 | Home | | X | | X | | Activity coaches | MI
Mosca, 2008^176^ | HD+PA M | IG1 | Counseling | Five 30- to 60-min individual education and lifestyle counseling sessions to reduce LDL-C and change diet, lifestyle, and other CVD risk factors. | G | 38 | 5 | 45 | 225 | Research clinic | X | X | | X | | Health educator, registered dietician, + physician specializing in CVD prevention | MI
Napolitano, 2006 | PA L | IG1 | Tailored print mailings | 4 individually-tailored feedback letters based on PA readiness plus 1 stage-matched booklet and letter explaining how to use materials. | | 26 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Napolitano, 2006 | PA L | IG2 | Nontailored print mailings | 1-time mailing of AHA Choose to Move booklet and letter explaining how to use materials. | | 12 | NA | NA | NA | Home | | | | X | | NA | AC
Norris, 2000 | PA M | IG1 | Counseling | 1-time individually-tailored counseling session with PCP based on PACE questionnaire responses and relevant to stage of change, followed by ≥1 followup calls and optional 1-time educational mailing. | | 20 | 4 | Initial sess: 30 FU calls: 15 | 60 | Primary care | X | X | | X | | PCP | UC
Parekh, 2014 | HD+PA L | IG1 | Computer-tailored print mailings (2 contacts) | 2 mailed personalized, computer-tailored feedback letters and health promotion information sheets at baseline and 3 months. | F&V, LF | 12 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Parekh, 2014 | HD+PA | IG2 | Computer-tailored print mailing (1 contact) | 1 mailed personalized, computer-tailored feedback letter and health promotion information sheets at baseline. | F&V, LF | 0.14 | NA | NA | NA | Home | | | | X | | Computer expert system | AC
Pekmezi, 2009 | PA L | IG1 | Tailored print mailings and self-monitoring | 6 monthly mailings of individually-tailored PA manuals on increasing PA, with activity logs and pedometers to track and monitor progress toward PA goals, plus tip sheets on related topics. | | 26 | NA | NA | NA | Home | | | | X | | NA | AC
Pinto, 2002^185^ | PA M | IG1 | Automated phone counseling | Weekly 10-min counseling calls with phone-linked communication system for 12 weeks and then biweekly for 3 months, and 7 monthly reports providing feedback and advice toward PA goals, with activity logs and pedometers to track and monitor progress. | | 26 | 18 | 10 | 180 | Other | | X | | | | Expert system with digitized human speech | AC
Pinto, 2005^186^ | PA M | IG1 | Counseling with tailored prescription | Three 30- to 40-min face-to-face counseling sessions in first 3 months, with twelve 10- to 15-min counseling phone calls weekly for 3 months and then biweekly for 3 months, and 12 tip sheets mailed at same time phone calls occurred. | | 26 | 15 | Individ sess: 35 Calls: 15 | 285 | Primary care | X | X | | X | | PCP, Health educator | MI
Roderick, 1997^188^ | HD M | IG1 | Counseling | 1 dietary advice session (assumed 30-min) and 1 followup session aimed at changing serum cholesterol, weight, and diet plus print materials. | G | 5 | 2 | 30 | 60 | Primary care | X | | | | | Research nurse | MI
Ruffin, 2011^189^ | HD+PA L | IG1 | Computer-tailored web-based intervention | Family Healthware tool and surveys completed online that provided personalized familial risk assessment and tailored prevention messages via computer or print. Could be completed in 1 or multiple sessions (assumed 30 min total). | F&V | 26 | 1 | NR | 30 | Home | | | X | X | | Computer expert system | UC
Sacerdote, 2006^190^ | HD L | IG1 | Brief counseling | One 15-min counseling session with PCP to encourage increased fruit and vegetable intake and improve dietary habits. | G | 1 | 1 | 15 | 15 | Primary care | X | | | X | | PCP | UC
Simkin-Silverman, 1995^194^ | HD+PA H | IG1 | Group counseling | 15 group sessions (assumed 60-min) over 20 weeks followed by 6 booster group sessions. Then contacted via group, mail, and phone on average every 2 to 3 months over 4.5 years. | G | 234 | 21 | 60 | 1260 | Other | X | X | | X | X | Behavioral and nutritional interventionists | None
Smith, 2014^197^ | HD+PA M | IG1 | Counseling | Two 60-min face-to-face counseling sessions and 1 phone session in first month followed by 4 monthly booster calls and text messages in months 2 through 6. | G | 26 | 7 | Individ sess: 60 Calls: 5 min | 145 | Research clinic | X | X | | | | NR | None
Springvloet, 2015^198^ | HD M | IG1 | Web-based tailored education plus feedback | 4 web-based, tailored nutrition modules plus environmental-level feedback on the availability and prices of healthy foods nearby. | F&V, L | 6 | 12 | 15 | 180 | Home | | | X | | | NA | MI
Springvloet, 2015^198^ | HD M | IG2 | Web-based tailored education | 4 web-based computer-tailored nutrition education modules. | F&V, L | 6 | 12 | 15 | 180 | Home | | | X | | | NA | MI
Stewart, 2001^201^ | PA H | IG1 | Group counseling | 1 group informational meeting, 1 individual planning session, and 10 monthly group workshops, with PA diaries, monthly newsletters, functional fitness assessments, and 2 booklets focused on PA and benefits of PA. | | 52 | 12 | NR | 690 | Research clinic | X | X | | X | X | Program staff | WL
Taveras 2011^203^ | HD+PA H | IG1 | Postpartum counseling | 5 brief sessions (assumed 15-min) with pediatric PCP, four 15- to 20-min individualized sessions with health educator at 3, 6, 12, and 20 weeks postpartum, invitation to 4 group sessions, and comprehensive educational materials delivered over 6 months. | G | 26 | 13 | Brief sess: 15 Calls: 15 Group sess: 60 | 375 | Primary care | X | X | | X | X | PCP, Health educator | UC
Thompson, 2008^207^ | HD+PA H | IG1 | Group counseling | 5 monthly 2- to 2.5- hr group sessions on decreasing dietary fat, increasing fruit and vegetable intake, and increasing PA. | F&V, LF | 20 | 5 | 135 | 675 | NR | X | | | X | X | American Indian health educators | WL
Thompson, 2014^208^ | PA H | IG1 | Counseling and self-monitoring | Participants wore Fitbit accelerometers for 24 weeks with feedback from the device and 24 weekly counseling calls, with 3 face-to-face counseling sessions with a counselor every 2 months. | | 24 | 27 | Calls: 15 Indiv sess: 30 | 450 | Home | X | X | | | | Counselor | WL
Tinker, 2008^209^ | HD H | IG1 | Group counseling | 18 group sessions (assumed 60-min) and 1 individual session during first year focused on decreasing fat and increasing fruit and vegetable intake, followed by up to 20 group sessions, including optional peer-led sessions, over 6 years. | F&V, LF | 312 | 39 | 60 | 2310 | Research clinic | X | | | | X | Nutritionist and peers (optional) | MI
TOHP I, 1992^204^ | HD H | IG1 | Group counseling | Ten 90-min initial sessions (8 group and 2 individual) in first 3 months and subsequent monthly in-person group or individual meetings up to 1.5 years. | S | 78 | 26 | 90 | 2340 | Research clinic | X | X | | X | X | Nutritionist, psychologist, or experienced counselor | None
TOHP II, 1997^205^ | HD H | IG1 | Group counseling | Ten 60- to 90-min individual and group counseling sessions in first 3 months and subsequent monthly meetings for 4 months and 3 to 6 refresher sessions over up to 3 years. | S | 156 | 20 | 75 | 1500 | Research clinic | X | X | | | X | Centrally trained staff (dietitians, psychologist or health counselors) | None
Tokunaga-Nakawatase, 2014^210^ | HD+PA L | IG1 | Computer-tailored print mailings | 3 computer-tailored print mailings with dietary and PA recommendations. | G | 26 | NA | NA | NA | Home | | | X | X | | Computer expert system | UC
Valve, 2013^211^ | HD+PA M | IG1 | Counseling | 1 initial 20-min counseling session with 3 to 5 followup sessions plus print materials. | G | 104 | 5 | 20 | 100 | NR | X | | | X | | Research nurse | None
Van Hoecke, 2014^212^ | PA M | IG1 | Counseling | One 60-min PA coaching session and six 30-min booster contacts or phone calls. | | 10 | 7 | Initial sess: 60 FU sess: 30 | 240 | NR | X | X | | X | | Coach | MI
Van Hoecke, 2014^212^ | PA L | IG2 | Tailored prescription | One 15-min contact with coach, self-help booklet, and individualized, written walking program. | | 10 | 1 | 15 | 15 | NR | X | | | X | | Coach | MI
Van Stralen, 2010^214^ | PA L | IG1 | Tailored print mailings with environmental focus | 3 mailed computer-tailored letters targeting psychosocial and environmental mediators of PA, plus web site access to induce changes in PA. | | 14 | NA | NA | NA | Home | | | X | X | | Computer expert system | WL
Van Stralen, 2010^214^ | PA L | IG2 | Tailored print mailings | 3 mailed computer-tailored letters targeting psychosocial mediators to induce changes in PA. | | 14 | NA | NA | NA | Home | | | | X | | Computer expert system | WL
Vandelanotte, 2005^217^ | HD+PA M | IG1 | Computer-based sessions with tailored feedback (PA + diet together) | One 100-min session completing 2 computer-tailored interventions. | LF | 0.14 | 1 | 100 | 100 | Research clinic | | | X | | | Computer | WL
Vandelanotte, 2005^217^ | HD+PA M | IG2 | Computer-based sessions with tailored feedback (PA first) | Two 50-min individual interactive computer-tailored intervention sessions (PA first, diet second). | LF | 12 | 2 | 50 | 100 | Research clinic | | | X | | | Computer | WL
Vandelanotte, 2005^217^ | HD+PA M | IG3 | Computer-based sessions with tailored feedback (diet first) | Two 50-min individual interactive computer-tailored intervention sessions (diet first, PA second). | LF | 12 | 2 | 50 | 100 | Research clinic | | | X | | | Computer | WL
Vrdoljak, 2013^218^ | HD+PA M | IG1 | Provider training | Provider training (assumed two 60-min sessions) on counseling patients on healthy lifestyle over 1 year with use of intervention booklet, patient education flyers, and protocol monitoring. | G | 52 | 2 | 60 | 120 | Primary care | X | | | | X | NR | None
Wadsworth, 2010^219^ | PA L | IG1 | Web-based intervention | 1 orientation session, 6 weekly emails, web site, access to an e-counselor, and access to computer-mediated exercise materials and 4 monthly booster emails. | | 26 | 1 | 30 | 30 | Other | X | | X | X | | Exercise physiologist | MI
Warner, 2016^220^ | PA M | IG1 | Group counseling with views-on-aging component | One 2.75-hr group session focused on increasing PA plus focus on aging. | | 0.14 | 1 | 166 | 166 | NR | X | | | | X | Psychologist | AC
Warner, 2016^220^ | PA M | IG2 | Group counseling | One 2.75-hr group session focused on increasing PA. | | 0.14 | 1 | 170 | 170 | NR | X | | | | X | Psychologist | AC

* Intervention focused on reducing sedentary time.

† Only 38% of IG received the intervention as planned.

‡ Weighted mean intensity based on self-selected dose of intervention.

§ Actual=244 mins.

|| Actual=278 mins.

¶ Actual=270 mins.

Abbreviations: AC=attention control; AHA=American Heart Association; CG=control group; CVD=cardiovascular disease; Dur=duration; Elec=electronic; Est=estimated; FU=followup; Grp=group; H=high; HD=healthful diet; hr=hour; IG=intervention group; Indiv=individual; Int=intervention; IVR=interactive voice response; L=low; LDL-C=low-density lipoprotein cholesterol; LF=low fat; M=medium; MI=motivational interviewing; min=minute; NR=not reported; PA=physical activity; PACE=Physician-based Assessment & Counseling for Exercise; PCP=primary care provider; RD=registered dietician; SD=standard deviation; sess=session; UC=usual care; YMCA=Young Men’s Christian Association.

Within the low-intensity interventions (40 arms), the majority were mailed, print-based interventions in which participants received tailored feedback regarding their dietary and/or physical activity behaviors and specific recommendations and tools for behavior change. A higher proportion of the low-intensity trials focused on physical activity only (k=16) as opposed to healthful diet (k=7) or healthful diet and physical activity (k=5). Frequency of mailings ranged from once to 36 monthly mailings over 3 years. Many of these interventions involved individually tailored print materials that were generated by a computer expert system and often included self-help materials or a self-directed written plan for increasing physical activity and/or changing eating patterns. A minority of the low-intensity interventions (k=7) included brief in-person or telephone counseling or “endorsements” on behalf of the primary care provider^81, 92, 120, 122, 135, 190^ or “coach.”^212^ Counseling ranged from 3 to 15 minutes and generally included individualized prescriptions for changing behavior or encouragement to use self-help materials. Five low-intensity interventions relied on Web- or text-based messages for intervention delivery.^119, 149, 169, 189, 219^

The medium-intensity interventions (55 arms) were more variable than the low- and high-intensity interventions in terms of the number of sessions and modes of delivery. The duration of the interventions ranged from 1 day to 2 years, with most taking place over the course of 6 to 12 months. The total intensity of the interventions ranged from 40 minutes to approximately 5 hours of contact time (median, 2.25 hours). In general, most of the medium-intensity interventions consisted of at least one face-to-face individual counseling session lasting from 20 to 60 minutes followed by booster telephone counseling calls, emails, or text messages. Several of the medium-intensity physical activity–only inventions consisted solely of telephone-based counseling and involved no face-to-face sessions. The majority of counseling sessions and telephone calls were provided by research staff (i.e., study personnel), health educators, dietitians or nutritionists, or exercise specialists; nine trials (10 arms)^90, 111, 117, 132, 135, 146, 160, 179, 186^ included intervention components delivered by a primary care provider.

Within the high-intensity interventions (26 arms), most provided healthful diet counseling, with or without physical activity messages; only five high-intensity interventions focused solely on increasing physical activity with no healthful diet messages. The high-intensity interventions were typically provided through group sessions ranging from 45 minutes to 2.5 hours in length, with more than 15 group sessions in most studies. Interventions spanned 4 weeks to 6 years in total duration, with the bulk of the active (vs. maintenance) phase of the intervention lasting around 6 months. The high-intensity physical activity interventions were quite variable and included physician training,^148^ individual face-to-face and telephone counseling,^154, 172, 208^ and group workshops.^201^ With the exception of one study,^203^ the high-intensity interventions did not involve primary care staff. Most of the interventions were delivered by dietitians or nutritionists, behavioral health specialists, or research staff. As such, very few took place in primary care and were instead usually conducted in research clinics or at home, or the setting was not described. The one intervention delivered by primary care staff targeted women at 0 to 1 months postpartum; diet and physical activity counseling was provided by a pediatric primary care provider and a health educator through individualized counseling calls and included optional group sessions on parenting skills.^203^

Similar messages and behavior change techniques were used across all of the interventions (Appendix E Table 1). Diet messages typically focused on general heart-healthy eating patterns, including increased fruit and vegetable intake (specifically 5 to 9 servings/day), decreased fat consumption and salt intake, and increased fiber consumption; fewer mentioned specific messages about increasing intake of whole grains, reducing consumption of red and processed meats, or increasing intake of calcium-rich foods. Two studies specifically encouraged the Dietary Approaches to Stop Hypertension (DASH) diet,^101, 137^ and three studies (the Hypertension Prevention Trial^140^ and the Trials of Hypertension Prevention [TOHP] phases I^204^ and II^205^) focused exclusively on decreasing sodium intake to approximately 1,400 to 1,600 mg or less per day, with or without a simultaneous increase in potassium intake of 3,900 mg or more per day. Four of these five studies were conducted among adults with high-normal blood pressure (i.e., SBP of 130 to 159 mm Hg, DBP of 80 to 99 mm Hg).^137, 140, 204, 205^ The largest trial, the Women’s Health Initiative (WHI) Dietary Modification Trial (n=48,835), focused on a 20-percent low-fat dietary pattern with no focus on specific subtypes of fat. Only three studies specifically mentioned encouraging an energy deficit (e.g., reducing total energy intake by 200 kcal each day, following a 1,300- or 1,500-kcal meal plan) to prevent weight gain^91, 194^ or to help those who were overweight to lose weight.^188^ One study included regular weigh-ins to monitor participants’ weight and suggested dietary adjustments to maintain weight.^137^

Physical activity messages emphasized gradually increasing aerobic activities to recommended levels (i.e., 150 minutes of moderate-intensity physical activity per week), with many interventions emphasizing walking. Only one study focused on decreasing sedentary behavior (e.g., reducing television viewing, substituting sitting with standing).^80^

Many interventions provided counseling related to reading food labels; planning, purchasing, and preparing foods and meals; finding local physical activity opportunities; and overcoming barriers related to desired behavior changes. Optional activities included group exercise classes, free memberships to community exercise facilities, weight loss materials or courses, grocery shopping trips with a dietitian, and cooking demonstrations. Additionally, many interventions included tangible tools to facilitate behavior change, such as pedometers, resistance bands, and log books or diaries for self-monitoring. Almost all of the interventions distributed print materials to participants; some materials were standard educational information only while others were tailored with normative or motivational feedback. Thirteen of the interventions, regardless of intervention focus or intensity, relied on computer-based counseling or included email or other mobile health technology to deliver the main components of the intervention.^86, 94, 113, 115, 119, 141, 147, 169, 189, 198, 217, 219^ Only one study incorporated ongoing measurement and feedback regarding specific CVD risk factors, such as lipid levels.^176^

Of those trials that reported the theoretical basis of the intervention, the majority were based on principles of the transtheoretical model (i.e., stages of change), social cognitive theory, or both (Appendix E Table 1). As such, most interventions included behavior change techniques focused on the broad areas of goals and planning, monitoring and feedback (e.g., through the use of food logs, dietary analysis with feedback, pedometers, and activity logs), increasing efficacy and motivation for healthy eating or physical activity, improving social support, and general education and advice regarding the benefits of specific behavioral changes. Eleven studies specifically mentioned using principles of motivational interviewing^80, 83, 86, 91, 125, 146, 148, 149, 155, 203, 212^ and five studies based their counseling, at least in part, on the “5 A’s” model (assess, advise, agree, assist, and arrange).^81, 112, 120, 146, 176^

#### Intervention Fidelity and Participant Adherence

Most of the studies reported some minimal information on participant adherence to the planned interventions (Appendix E Table 1). For those that reported adherence, rates of participation were generally high, particularly for the low- and medium-intensity interventions. Across these studies, approximately 70 to 98 percent of participants reported reading most of the print materials provided, taking part in face-to-face individual counseling sessions, or participating in most or all planned counseling telephone calls. There did not appear to be any differences in the level of adherence between the healthful diet and physical activity versus healthful diet–only or physical activity–only interventions. Only one study had exceptionally low intervention adherence; in one medium-intensity physical activity intervention, only 38 percent of participants randomized to receive the intervention took part in the intervention, which consisted of three monthly telephone counseling calls and mailed print materials.^123^ As is shown later, despite the low participation rate, this study reported a statistically significant between-group difference in levels of self-reported physical activity at 6 months, after controlling for baseline levels of physical activity among both the full randomized sample and the reduced sample of only those who participated in the intervention.

Adherence to high-intensity interventions, especially the group-based interventions, was generally a little lower than adherence to the low- and medium-intensity interventions. For example, in one study, only 61.5 percent of participants attended all 12 planned weekly group sessions.^140^ Similarly, in a study that offered five 2- to 2.5-hour group sessions, half of all participants attended three sessions or fewer.^207^

Very few studies reported adherence to optional activities such as group exercise classes. For example, in a study that offered supervised exercise, only 26 percent of trial participants reported participating in an exercise class each week.^135^ In another study, 70.3 percent of intervention participants activated their free membership to a community exercise facility, of which only 40.7 percent visited more than once over the course of the year-long intervention.^91^

#### Control Arms

Just more than half of the studies (k=44) employed a no-intervention, usual care, or waitlist control arm for the control group. Usual care was generally described as “routine” or “standard” care that included standard prevention messages or generic print materials or was otherwise not described. In one study,^135^ the usual care control group participants were specifically told to maintain their normal diet and physical activity levels. The remaining studies employed minimal intervention (k=25) or attention control groups (k=19). Minimal intervention groups typically consisted of brief print materials regarding the benefits and recommendations of healthful diet and/or physical activity, such as the “Dietary Guidelines for Americans.” A few of the minimal intervention groups were more intensive and provided specific recommendations (e.g., increase physical activity by 2 hours a week) or self-help materials, including pedometers and tracking logs, although these were still less intensive than interventions categorized as low intensity. The attention control groups usually followed the same intervention schedule as the study’s intervention group but focused on a different health topic (e.g., stress management, general health and wellness, women’s health).

### Study Quality

We rated 19 of the 88 trials as good quality and the remaining 69 as fair quality (Table 2). Twenty trials were excluded for poor quality (Appendix D). Common threats to internal validity of these poor-quality studies included very high attrition (generally >40%), with differential attrition between intervention arms (>20%); lack of baseline comparability between groups without adjustment; and issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, questionable validity of randomization and allocation concealment procedures). In general, the 19 trials rated as good quality were characterized by appropriate randomization procedures; comparable groups at baseline (or adequate adjustment for known baseline differences in the analysis); high followup rate (i.e., ≥85% retention at 6 months); the use of reliable and valid measurement instruments applied equally across arms and blinding of outcome assessors for nonobjective measures; well-described interventions with high fidelity and good adherence to the intervention; no evidence of selective reporting; and appropriate analyses, including intention-to-treat principles using multiple imputation or other conservative data imputation procedures for missing data. Some common limitations of the fair-quality studies included lack of reporting details about allocation concealment, small differences in baseline characteristics between treatment arms, no or unclear blinding for outcomes assessment (particularly for interviewer-administered questionnaires), relatively higher attrition (i.e., >20%) and differential attrition between groups, and no attempt (or lack of reporting) to account for missing data or conducting completers-only analyses.

## KQ 1 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Health Outcomes in Adults?

### Summary of Results

Twelve of the 88 included trials reported health outcomes.^111, 122, 128, 135, 140, 154, 155, 179, 204, 205, 209, 212^ Only two of these trials^121, 212^ were newly identified as part of our update, and both reported quality-of-life outcomes (Table 2). Four trials reported all-cause or CVD-related mortality,^140, 204, 205, 209^ of which three also reported CVD-related events.^204, 205, 209^ All four of these trials were high-intensity diet-focused trials. Overall, few deaths were reported, and no differences were observed between treatment and control groups over 3 to 15 years of followup. Trials reporting cardiovascular events and composite CVD outcomes showed some beneficial results, although results were mixed. Ten trials (of which seven were physical activity–only interventions) reported HrQOL outcomes, with the majority using the 36-Item Short-Form Health Survey (SF-36) to measure quality of life.^89, 111, 121, 128, 135, 154, 155, 179, 204, 213^ Results showed general improvements in quality of life at 6 and 12 months among intervention participants, although there was no consistent benefit of the intervention compared with control conditions.

### Detailed Results by Outcome

#### CVD and Mortality

Four trials (n=51,356) of high-intensity diet-only interventions reported CVD-related health outcomes; three were good quality and one was fair quality (Appendix F Table 1).^140, 204, 205, 209^ All of these trials reported all-cause mortality. Two additionally reported CVD deaths^205, 209^ and three reported CVD events.^204, 205, 209^

Overall, few deaths occurred in each trial, and mortality was comparable between the intervention and control groups. In the WHI Dietary Modification Trial (n=48,835), postmenopausal women randomized to intensive low-fat dietary counseling showed no difference in deaths from all causes (hazard ratio [HR], 0.98 [95% confidence interval [CI], 0.91 to 1.07) or CVD (HR, 1.01 [95% CI, 0.81 to 1.27) compared with women randomized to the usual diet group after approximately 8.1 years of followup.^209^ Similarly, long-term observational followup combining the results from two hypertension prevention trials, TOHP phases I and II (n=3,126), which randomized persons with high-normal blood pressure to intensive sodium restriction counseling or usual care, found no difference in all-cause mortality (HR, 0.80 [95% CI, 0.51 to 1.26]) or deaths from cardiovascular causes (HR, 0.62 [95% CI, 0.28 to 1.40]) after 10 to 15 years of followup.^107^ Lastly, a trial of 587 participants aimed at preventing hypertension among adults with high-normal DBP found no difference in all-cause mortality among those randomized to intensive diet counseling focused on either increased potassium intake and decreased sodium intake or decreased sodium intake alone compared with usual care, with each group experiencing a single death over 3 years of followup.^140^

Results for cardiovascular events reported in three trials were mixed.^204, 205, 209^ The WHI Dietary Modification Trial (n=48,835) showed no difference in major coronary heart disease events (i.e., nonfatal MI or coronary heart disease death) (adjusted HR, 0.93 [95% CI, 0.83 to 1.05]) or fatal and nonfatal stroke (adjusted HR, 1.02 [95% CI, 0.90 to 1.17]) among women without a history of CVD who were randomized to low-fat diet counseling or the usual diet group over 8.1 years of followup.^139^ Similarly, a broader composite CVD outcome comprised of nonfatal MI, coronary heart disease death, and coronary artery bypass/percutaneous coronary interventions showed no significant difference between treatment groups (adjusted HR, 0.94 [95% CI, 0.86 to 1.02]).^139^ In contrast to the results from the WHI Dietary Modification Trial, long-term observational followup from the TOHP phase I and II trials (n=2,415) showed a significant difference in CVD (defined as MI, stroke, revascularization, or CVD death) between treatment groups over 10 to 15 years of followup (HR, 0.70 [95% CI, 0.53 to 0.94]).^107^ When revascularization was excluded from the definition, however, significance was lost (adjusted HR, 0.72 [95% CI, 0.50 to 1.03]). Exploratory subgroup analyses of demographic and clinical characteristics in these three trials showed no evidence of effect modification.^107, 138^

#### HrQOL

Ten fair- to good-quality trials (n=52,423) reported the effect of a healthful diet and/or physical activity intervention on HrQOL,^89, 111, 121, 128, 135, 154, 155, 179, 204, 213^ of which seven focused on physical activity only. The SF-36 was used to measure HrQOL in seven of the 10 trials; the Louvain Well-Being scale,^213^ the Psychological General Well-Being scale,^204^ and the Minor Symptoms Evaluation survey^135^ were used in the other three trials.

Overall, self-reported measures of HrQOL appeared to generally improve more among intervention than control participants over 6 to 12 months, although the specific HrQOL domains that were measured and the results of the individual trials were mixed. In the WHI Dietary Modification Trial, global quality of life (as measured by a single item) improved by a small but statistically significant amount in the intervention group compared with the control group at 1 year. On a 10-point scale, the mean score in the intervention group decreased from 8.20 to 8.19 (−0.01) and from 8.18 to 8.11 (−0.07) in the control group (p<0.001). Similarly, small statistically significant differences in favor of the intervention group were seen on seven of the eight SF-36 subscales.^89^ Only one low-intensity physical activity trial reported results according to the two summary scores of the SF-36 (mental health component and physical component) rather than the eight individual subscales, finding small improvements in the mental health component scores for both groups over 24 months but no differences between groups at any time point.^121^ The remaining five physical activity trials^111, 128, 154, 155, 179^ that used the SF-36 instrument to measure HrQOL reported results according to the eight domain-specific subscales; three of these trials focused specifically on older adults.^128, 155, 179^ While self-reported improvements were generally seen for one or more of the HrQOL subscales for intervention participants, there was no consistent effect of the interventions on any subscale. Similarly, the remaining three trials that used other measures of HrQOL reported no consistent effect of the interventions on HrQOL or well-being.^135, 204, 213^

## KQ 2 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Intermediate Outcomes Associated With CVD in Adults?

### Summary of Results

Thirty-four of the included studies reported the effects of behavioral interventions on at least one intermediate outcome; nearly half were of good quality (Table 2).^72, 80, 85, 90, 91, 97, 98, 106, 111, 122, 126, 130, 135, 137, 140, 143, 144, 146, 147, 149, 154, 156, 160, 176, 188, 190, 194, 204, 205, 207–209, 211, 219^ Only 10 of the 34 studies were newly identified as part of our update;^80, 91, 98, 126, 130, 137, 147, 149, 208, 211, 219^ the remaining 24 were included in our original review.^40^ Most of these 34 studies were of medium- or high-intensity interventions and focused on healthful diet, with or without physical activity messages. When studies of all levels of intensity were pooled, healthful diet and/or physical activity interventions were associated with small but statistically significant improvements in blood pressure, low-density lipoprotein (LDL) cholesterol, total cholesterol, and adiposity measures compared with controls at 6 months or more (Table 5). Average effects were between-group mean differences (MDs) of −1.26 mm Hg (95% CI, −1.77 to −0.75) for SBP, −0.49 mm Hg (95% CI, −0.82 to −0.16) for DBP, −2.58 mg/dL (95% CI, −4.30 to −0.85) for LDL cholesterol, and −2.85 mg/dL (95% CI, −4.95 to −0.75) for total cholesterol—all in favor of intervention versus control arms, with general followup times from 6 months or more. For adiposity outcomes, interventions were associated with improvements in BMI (MD, −0.41 kg/m^2^ [95% CI, −0.62 to −0.19]), weight (MD, −1.04 kg [95% CI, −1.56 to −0.51]), and waist circumference (MD, −1.19 cm [95% CI, −1.79 to −0.59]), although there was considerable statistical heterogeneity (I^2^>90%) in all analyses of adiposity, so the pooled results should be interpreted with caution. There was no evidence of an association between healthful diet and/or physical activity counseling and high-density lipoprotein (HDL) cholesterol, triglycerides, or fasting glucose when trials including all levels of intervention intensity were pooled (Table 5).

Table 5 Pooled Results of Intermediate Outcomes for All Interventions and by Intervention Intensity

Outcome | All interventions | | | High-intensity interventions (>360 min) | | | Medium-intensity interventions (31–360 min) | | | Low-intensity interventions (≤30 min)
Outcome | Mean difference in change (95% CI) | Trials, k | I^2^, % | Mean difference in change (95% CI) | Trials, k | I^2^, % | Mean difference in change (95% CI) | Trials, k | I^2^, % | Mean difference in change (95% CI) | Trials, k | I^2^, %
SBP, mm Hg | −1.26 (−1.77 to −0.75) | 22 | 44.5 | −1.55 (−2.21 to −0.89) | 12 | 48.1 | −1.10 (−2.38 to 0.15) | 8 | 48.7 | −0.12 (−1.08 to 0.84) | 2 | 0
DBP, mm Hg | −0.49 (−0.82 to −0.16) | 23 | 37.9 | −0.67 (−0.98 to −0.37) | 12 | 17.5 | −0.57 (−1.24 to 0.10) | 9 | 8.5 | 0.41 (−0.16 to 0.98) | 2 | 0
Low-density lipoprotein cholesterol, mg/dL^*^ | −2.58 (−4.30 to −0.85) | 13 | 19.6 | −4.51 (−6.85 to −2.16) | 6 | 0 | −1.70 (−4.64 to 1.24) | 6 | 5.0 | −0.91 (−2.90 to 1.08) | 1 | --
Total cholesterol, mg/dL^*^ | −2.85 (−4.95 to −0.75) | 19 | 50.8 | −5.32 (−8.84 to −1.81) | 7 | 36.7 | −1.64 (−3.76 to 0.48) | 11 | 13.8 | 0.87 (−1.44 to 3.18) | 1 | --
High-density lipoprotein cholesterol, mg/dL^*^ | −0.17 (−1.05 to 0.71) | 15 | 55.2 | −0.54 (−2.08 to 1.00) | 7 | 63.4 | 0.03 (−0.92 to 0.97) | 7 | 0 | 0.94 (0.08 to 1.80) | 1 | --
Triglycerides, mg/dL^†^ | −1.82 (−5.05 to 1.42) | 13 | 4.7 | −3.43 (−8.16 to 1.31) | 7 | 0 | −4.34 (−11.80 to 3.12) | 5 | 5.8 | 1.23 (−3.37 to 5.83) | 1 | --
Fasting glucose, mg/dL^‡^ | −0.36 (−1.22 to 0.5) | 13 | 42.4 | −1.35 (−2.24 to −0.45) | 7 | 0 | 0.38 (−1.30 to 2.06) | 5 | 54.7 | 0.52 (−0.61 to 1.65) | 1 | --
BMI, kg/m^2^ | −0.41 (−0.62 to −0.19) | 20 | 95.8 | −0.81 (−0.99 to −0.63) | 9 | 73.8 | −0.19 (−0.42 to 0.04) | 7 | 76.4 | −0.05 (−0.39 to 0.28) | 4 | 85.6
Weight, kg^§^ | −1.04 (−1.56 to −0.51) | 20 | 92.4 | −1.62 (−2.31 to −0.93) | 11 | 92.5 | −0.44 (−0.82 to −0.06) | 7 | 40.5 | −0.23 (−1.56 to 0.40) | 2 | 0
Waist circumference, cm^\|\|^ | −1.19 (−1.79 to −059) | 17 | 91.8 | −1.92 (−2.66 to −1.17) | 9 | 82.1 | −0.77 (−1.63 to 0.09) | 7 | 79.0 | 0.04 (−0.27 to 0.35) | 1 | --

* To convert mg/dL to mmol/L, multiply by 0.0259.

† To convert mg/dL to mmol/L, multiply by 0.0113.

‡ To convert mg/dL to mmol/L, multiply by 0.0555.

§ To convert kg to lb, multiply by 2.205.

|| To convert cm to in, multiply by 0.394.

Abbreviations: BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; min=minute(s); SBP=systolic blood pressure.

Among the intermediate outcomes showing a positive association, dose-response effects were evident, with increasing intervention intensity associated with larger improvements in intermediate outcomes. High-intensity interventions (i.e., ≥6 hours total) were consistently associated with statistically significant benefit on intermediate outcomes, and the effect sizes were slightly higher in analyses limited to the subset of high-intensity interventions compared with the results of combining trials of all level of intensity (Table 5). The effects of medium-intensity interventions (i.e., 31 minutes to 6 hours total) on intermediate outcomes were less consistent and generally showed no benefit, with the exception of the outcome of weight. There was insufficient evidence (only one to four trials per outcome) to assess the effects of low-intensity interventions (i.e., ≤30 minutes total) on intermediate outcomes. When we stratified meta-analyses by a focus on diet and/or physical activity, results were consistent with those seen in analyses stratified by intensity (Appendix F Table 2). That is, healthful diet interventions (with or without physical activity messages), which were mostly high-intensity interventions, consistently showed statistically significant favorable associations with intermediate outcomes. No such benefit was seen when limiting the analyses to physical activity–only trials, which were largely of low intensity, although there were far fewer trials included in these analyses (four to eight trials per outcome), and results should be interpreted accordingly.

Just more than half of the 34 trials that reported intermediate outcomes took place in the United States.^85, 91, 98, 106, 126, 137, 140, 143, 147, 156, 176, 194, 204, 205, 207–209, 219^ Ten of the trials were limited to populations with elevated CVD risk, including persons with high-normal blood pressure;^137, 140, 204, 205^ persons with a family history of type 2 diabetes^97, 154^ or CVD;^176^ men with moderately elevated DBP, cholesterol, and glucose levels;^135^ older adults who were overweight;^146^ and black women who were overweight.^91^ Two of the trials were limited to older adults (age ≥60 years);^146, 208^ in one of these trials, the mean age of the sample was 79.5 years. Only 14 of the 34 trials took place in or recruited from primary care; of those, four took place in the United States.^91, 137, 156, 176^ The remaining 20 trials recruited volunteers through community venues (e.g., advertising, community events) or other convenience or random samples (e.g., existing research cohorts or databases, registered voters). These studies evaluated almost exclusively high-intensity interventions and showed concordant findings with the analysis that was limited strictly to high-intensity interventions. That is, subgroup analyses that included only trials that did not recruit from or occur in the primary care setting found similarly statistically significant positive associations with blood pressure, LDL cholesterol, total cholesterol, fasting blood glucose, and waist circumference, but no association was seen with these outcomes in the subgroup of trials that were conducted in or recruited from primary care, which were primarily of medium and low intensity (data not shown). Pooled results were statistically significant for both subgroups of studies (those conducted in and not conducted in primary care) for BMI and weight measures. Meta-regression results showed a statistically significant difference between trials conducted in and not conducted in primary care for DBP and total cholesterol in bivariate analyses, but significance was lost after controlling for intervention intensity. Given the confounding of intervention intensity and the statistically significant dose-response relationship with intensity, differences seen between trials conducted in and not conducted in primary care could be a reflection of intensity rather than the recruitment or intervention setting.

On the basis of the Egger’s test and visual inspection of funnel plots, we found no evidence of small-study effects (an indicator of publication bias) for any of the intermediate outcomes.

### Detailed Results by Outcome

#### Blood Pressure

Meta-analyses from more than 20 trials of mostly good quality found that healthful diet and physical activity counseling interventions were associated with a decrease in SBP and DBP of −1.26 mm Hg (95% CI, −1.77 to −0.75; k=22; n=57,953) (Figure 3) and −0.49 mm Hg (95% CI, −0.82 to −0.16; k=23; n=58,022) (Figure 4), respectively, at approximately 6 to 12 months compared with controls (Table 5). We were able to pool all 23 trials that reported a blood pressure outcome.^72, 85, 91, 106, 111, 122, 130, 135, 137, 140, 144, 146, 154, 160, 176, 188, 190, 194, 204, 205, 207–209^ Within these 23 trials, most participants were normotensive or had high-normal blood pressure; mean blood pressure across trials was 127/78 mm Hg. The largest reductions in blood pressure were seen in the 12 high-intensity interventions (MD in change for SBP, −1.55 mm Hg [95% CI, −2.21 to −0.89; n=47,630; I^2^=48.1%]; MD in change for DBP, −0.67 mm Hg [95% CI, −0.98 to −0.37; n=47,625; I^2^=17.5%]) (Appendix F Table 3). These high-intensity interventions included four trials enrolling persons with high-normal blood pressure (DBP, approximately 80 to 89 mm Hg), which focused on decreasing dietary salt intake and resulted in intervention group reductions ranging from −3.4 to −9.5 mm Hg for SBP and from −3.7 to −4.6 mm Hg for DBP at 6 to 18 months of followup.^137, 140, 204, 205^ A sensitivity analysis in which we removed the two studies conducted among older adults^146, 208^ showed no appreciable difference in the average intervention effect for DBP overall or within intensity subgroups. For SBP, however, the pooled result for medium-intensity interventions showed a small improvement (MD, −1.34 [95% CI, −2.48 to −0.20]; k=7; I^2^=39.5%), which was not significant in analyses that included one trial that recruited older adults exclusively (MD, −1.10 [95% CI, −2.38 to 0.15]; k=8; I^2^=48.7%).

Figure 3 Pooled Analysis of Change in Systolic Blood Pressure in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in systolic blood pressure (mm Hg) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Figure 4 Pooled Analysis of Change in Diastolic Blood Pressure in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in diastolic blood pressure (mm Hg) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Within the 23 trials that were pooled, 16 included healthful diet messages with (k=7) or without (k=9) physical activity messages and seven focused exclusively on physical activity messages. When we stratified the meta-analyses by a focus on diet, physical activity, or both, the results were consistent with those seen in analyses stratified by intensity (Appendix F Table 2). That is, healthful diet interventions (with or without physical activity messages), which were mostly high-intensity interventions, consistently showed statistically significant favorable associations with blood pressure. No such benefit was seen when limiting the analyses to physical activity–only trials, which were generally of medium intensity. For example, the MD in change for SBP for healthful diet interventions, with or without physical activity interventions, was −1.53 mm Hg ([95% CI, −2.14 to −0.93]) in favor of the intervention, whereas it was −0.36 mm Hg (95% CI, −1.17 to 0.44) for the physical activity–only trials.

There was no consistent pattern in the effects of the interventions on blood pressure over time (Appendix F Table 3). Eight studies reported additional measures of SBP and DBP after 1 year of followup.^91, 160, 194, 204, 205, 207, 209^ Mean between-group reductions in blood pressure remained statistically significant in the TOHP phase I and II trials from 6 months to 1.5 years^204^ and 2.5 years,^205^ respectively, whereas they attenuated and lost significance in two other long-term trials of 1.5^194^ and 6 years.^209^ In the U.S.-based good-quality Women’s Healthy Lifestyle Project, women (mean age, 47.1 years) in the intervention group took part in 15 healthful diet and physical activity group counseling sessions in the first 5 months of the intervention, which was followed by six booster group sessions and followup telephone calls and mailings for 4.5 years.^194^ Statistically significant reductions in both SBP (MD, −2.00 mm Hg [95% CI, −3.86 to −0.14]) and DBP (MD, −2.20 mm Hg [95% CI, −3.39 to −1.10]) were seen at 6 months. The effects remained statistically significant for SBP but not DBP at 1.5 years and were attenuated by the end of the intervention at 4.5 years (MD for SBP, −0.32 mm Hg; MD for DBP, −0.70 mm Hg [significance level not reported]). Likewise, in the largest trial, the good-quality WHI Dietary Modification Trial (n=48,435), significant effects on blood pressure were found at 1 year, after the most intensive phase of the intervention (i.e., 18 group sessions), but were no longer evident at 6 years when the intervention was less intensive (approximately four group sessions per year).^209^

Five studies reported the prevalence or incidence of hypertension in addition to continuous measures of blood pressure (Appendix F Table 3).^85, 88, 140, 204, 205^ The findings were mixed. In the TOHP phase I^204^ and II^205^ trials (which enrolled persons with high-normal blood pressure), despite small statistically significant differences in the improvement of continuous measures of SBP and DBP among participants receiving low-sodium dietary counseling versus control participants at up to 1.5 and 2.5 years, respectively, there was no statistically significant difference in incident hypertension (defined as average DPB ≥90 mm Hg or average SBP of 140 mm Hg) and no significant difference in diagnosis and drug treatment of hypertension over the course of 1.5 to 3 years. In the TOHP phase I trial, 8.6 percent of intervention participants and 11.3 percent of control participants developed hypertension (risk ratio [RR], 0.84 [95% CI, 0.62 to 1.13]) over 1.5 years.^204^ In the TOHP phase II trial, in which participants were overweight in addition to having high-normal blood pressure, a small statistically significant relative effect was seen for incident hypertension at 6 months. Incident hypertension was present in 4.5 and 7.3 percent of intervention and control participants, respectively, at 6 months (RR, 0.61 [95% CI, 0.38 to 0.98]); however, the relative risk diminished over time. At 3 years, 34.4 and 39.2 percent of intervention and control participants, respectively, had incident hypertension (RR, 0.88 [95% CI, 0.75 to 1.02]) at 3 years. In contrast to the TOHP phase I and II trials, the earlier Hypertension Prevention Trial, which also enrolled persons with high-normal blood pressure, showed no statistically significant differences in continuous SBP and DBP between the intervention and control groups; however, a statistically significant difference in the incidence of hypertension was found between the sodium plus potassium arm and the control arm. During 3 years of followup, 24.6 percent of the intervention participants randomized to a sodium-only arm and 21.7 percent randomized to a sodium plus potassium arm developed hypertension compared with 33.5 percent of control participants (RR for sodium-only group vs. control, 0.73 [95% CI, 0.53 to 1.01]; RR for sodium plus potassium, 0.65 [95% CI, 0.46 to 0.90]).^140^ In the WHI Dietary Modification Trial, women in the intervention group had a 4 percent lower overall risk of developing incident hypertension than women in the control group (HR, 0.96 [95% CI, 0.93 to 0.99]) over 8 years of followup. This effect, however, diminished over time and showed no reduced risk after 5 years.^88^ The final trial, among generally normotensive adults (mean blood pressure, 129/77 mm Hg), reported slight improvements in continuous measures of blood pressure and a decrease in the prevalence of high blood pressure among both intervention and control groups at 6 months, but no statistically significant difference between groups.^85^

#### Lipids

Nineteen trials reported at least one lipid measure, including LDL, total, and HDL cholesterol and triglyceride levels (Appendix F Table 4).^72, 80, 85, 90, 91, 97, 111, 122, 130, 135, 144, 146, 154, 160, 176, 188, 194, 207, 208^ We were able to pool all 19 trials in at least one meta-analysis for these respective outcomes. Baseline levels of cholesterol were generally optimal or near-optimal among these samples; mean LDL and total cholesterol levels were 127 and 201 mg/dL, respectively. For LDL cholesterol, meta-analysis of 13 trials (seven of good quality) resulted in a statistically significant decrease in LDL cholesterol level (MD, −2.58 mg/dL [approximately 0.067 mmol/L]) at 6 to 12 months of followup (95% CI, −4.30 to −0.85; n=5,554; I^2^=19.6%) (Figure 5). When stratified by intervention intensity, this decrease was significant only among the six high-intensity interventions, with an average effect of −4.51 mg/dL (95% CI, −6.85 to −2.16; n=1,381; I^2^=0%) (Table 5); results from meta-regression confirmed a statistically significant dose-response effect with more benefit seen as intensity increased (p=0.036).

Figure 5 Pooled Analysis of Change in Low-Density Lipoprotein Cholesterol in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in low-density lipoprotein cholesterol (mg/dL) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Results for total cholesterol were concordant with findings for LDL cholesterol. A pooled analysis of 19 trials (n=9,325) showed an average intervention effect of a decrease in total cholesterol level of −2.85 mg/dL (0.074 mmol/L) (95% CI, −4.95 to −0.75), with substantial statistical heterogeneity (I^2^=50.8%) (Figure 6). A larger effect was seen among the high-intensity interventions (MD, −5.32 mg/dL [95% CI, −8.84 to −1.81]; k=7; n=1,429; I^2^=36.7%) (Figure 6; Table 5), and a dose-response effect was present, with increasing intensity related to larger reductions (p=0.017). All but one of the high-intensity interventions focused on both dietary and physical activity messages. Dietary goals within these interventions focused on reducing total energy intake in addition to a specific emphasis on decreasing total and saturated fat intake and, in some cases, dietary cholesterol level. The remaining trial focused on increasing physical activity among older adults. After we limited the analysis to the eight trials that had combined diet and physical activity messages, a similarly large effect was seen (MD, −4.00 mg/dL [95% CI, −7.94 to −0.63]), although substantial heterogeneity remained (I^2^=54.8%) (Appendix F Table 2).

Figure 6 Pooled Analysis of Change in Total Cholesterol in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in total cholesterol (mg/dL) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

One trial showed consistent beneficial effects of the intervention for both LDL and total cholesterol (Appendix F Table 4). In the good-quality Women’s Healthy Lifestyle Project by Simkin-Silverman et al,^194^ relatively large statistically significant differences in changes in LDL and total cholesterol levels were seen between women receiving the high-intensity group counseling intervention and women in the control group at 6 months and 1.5 years, as well as 4.5 years for LDL cholesterol. For example, at 6 months, LDL cholesterol level declined by −11.3 mg/dL among women in the intervention group but by only −0.1 mg/dL among women in the control group, resulting in an MD in change of −11.20 mg/dL (95% CI, −14.75 to −7.65) in favor of the intervention group.^194^ For HDL cholesterol, a statistically significant larger benefit was seen for the control group compared with the intervention group. MDs in change in LDL cholesterol level were slightly attenuated but remained statistically significant at 1.5 and 4.5 years of followup. Three other trials reported followup beyond 12 months for one or more lipid outcomes; none found an effect of the intervention on lipid outcomes at 6 months to 2 years.^91, 160, 207^ In addition, none of the included trials reported the between-group difference in the proportion of participants with high cholesterol after the intervention.

There was no evidence of an association between healthful diet and/or physical activity interventions and levels of HDL cholesterol (Figure 7) or triglycerides (Figure 8) in pooled analyses. Mean between-group differences in change in HDL cholesterol level were generally inconsistent, ranging from absolute differences of 2.7 mg/dL in favor of the control group to 5.8 mg/dL in favor of the intervention group at 6 months to 2 years of followup (mean HDL cholesterol level at baseline, 56 mg/dL). Only three studies reported effect estimates indicating potential benefit of interventions on HDL cholesterol,^97, 122, 176^ although only two of them were statistically significant. Large variation was also seen in the effects of the intervention on triglyceride levels; only one small study (n=115) among college students (mean age, 19.7 years) in Canada reported a borderline statistically significant effect of a high-intensity intervention on triglyceride levels.^72^

Figure 7 Pooled Analysis of Change in High-Density Lipoprotein Cholesterol in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in high-density lipoprotein (mg/dL) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Figure 8 Pooled Analysis of Change in Triglycerides in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in triglycerides (mg/dL) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

#### Fasting Glucose Level

Fourteen trials reported the effect of a counseling intervention on one or more indicators of diabetes, including fasting blood glucose level, hemoglobin A1c (HbA1c) level, and incident diabetes.^80, 85, 91, 97, 106, 122, 146, 154, 160, 176, 194, 207–209^ There were inconsistent results across studies that reported MDs in changes in fasting glucose (Appendix F Table 5). Our meta-analysis of 13 trials (n=7,274) found no evidence of an effect on fasting glucose at 6 months to 1.5 years (MD, −0.36 mg/dL [0.02 mmol/L] [95% CI, −1.22 to 0.50]; I^2^=42.4%). There was, however, evidence of a beneficial association when looking only at the high-intensity interventions (MD, −1.35 mg/dL [95% CI, −2.24 to −0.45]; k=7; n=2,381), and statistical heterogeneity was reduced to zero (Figure 9; Table 5). All but two of these seven high-intensity interventions included both healthful diet and physical activity messages; the remaining trial focused only on healthful diet. Consistent with the results for blood pressure and LDL cholesterol, the Women’s Healthy Lifestyle Project again showed a statistically significant benefit of the high-intensity intervention on fasting glucose at both 6 months and 1.5 years, with a slight attenuation in the effect over time.^194^ No other individual trial reported a statistically significant benefit of the intervention (Figure 9).

Figure 9 Pooled Analysis of Change in Fasting Glucose in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in fasting glucose (mg/dL) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Across all trials, mean baseline fasting glucose level generally ranged from 87.3 to 104.4 mg/dL (mean, 97.3 mg/dL). The largest changes in fasting glucose level were seen in a small trial of adults with a family history of type 2 diabetes.^97^ Participants randomized to a high-intensity counseling intervention focused on healthful diet plus physical activity (n=24) or to a high-intensity healthful diet–only intervention (n=25) experienced larger reductions in fasting glucose levels at 1 year than the minimal intervention group (n=19) (reductions of −7.7, −5.9, and −3.8 mg/dL, respectively). However, there were no statistically significant differences between groups.

Five of these trials also reported the effects of the interventions on HbA1c (not pooled).^80, 146, 154, 160, 208^ Results were similarly inconsistent, with only one trial among older adults who were overweight suggesting a benefit of the intervention on HbA1c level (MD, −0.25 mg/dL [95% CI, −0.37 to −0.12]) (Appendix F Table 5).^146^ Only two trials reported the prevalence or incidence of diabetes. ^85, 209^ In the U.S.-based Coronary Health Improvement Project, small improvements in continuous fasting glucose were seen in both the counseling intervention group (mean change, −3.0 mg/dL [95% CI, −5.9 to −0.1]) and the control group (mean change, −1.0 mg/dL [95% CI, −3.6 to 1.6]), and the between-group difference was not statistically significant.^85^ The proportion of participants with diabetes (defined as fasting glucose ≥126 mg/dL) decreased from 12.1 to 9.8 percent in the intervention group (p<0.0001) and increased slightly (from 4.0% to 5.2%) in the control group. Again, the between-group difference was not statistically significant. In the very large WHI Dietary Modification Trial, which focused on low-fat dietary patterns, 7.1 versus 7.4 percent of intervention and control participants, respectively, reported incident diabetes after 8.1 years of followup (HR, 0.96 [95% CI, 0.90 to 1.03]). This study did not report continuous measures of blood glucose.^209^

#### Adiposity

Thirty-one trials reported an adiposity-related outcome, such as BMI, weight, waist circumference, or percent body fat (Appendix F Table 6).^72, 80, 85, 91, 97, 98, 106, 111, 122, 126, 135, 140, 143, 144, 146, 147, 149, 154, 156, 160, 176, 188, 190, 194, 204, 205, 207–209, 211, 219^ Given the number of trials that reported each respective outcome, we were able to pool the results for BMI, weight, and waist circumference separately. Although the included trials did not address weight loss as a direct goal of the interventions (by virtue of our inclusion criteria), they were associated with small improvements in BMI, weight, and waist circumference (Table 5). The results of each meta-analysis showed small but statistically significant associations between healthful diet and/or physical activity interventions and reductions in BMI, weight, and waist circumference at approximately 6 months to 1 year (Figures 10–12). However, considerable statistical heterogeneity (I^2^>90%) was present in these analyses due to wide variation in effect estimates and precision around those estimates, which likely reflects clinical variability among the included studies, particularly in the samples’ baseline characteristics and the studies’ aims. Thus, the average intervention effects (MDs) should be interpreted with caution.

Figure 10 Pooled Analysis of Change in Body Mass Index in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in body mass index (kg/m2) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Figure 11 Pooled Analysis of Change in Weight in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in weight (kg) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Figure 12 Pooled Analysis of Change in Waist Circumference in Healthful Diet and/or Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; Elev=elevated; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in waist circumference (cm) in healthful diet and/or physical activity interventions compared with controls, organized by intervention intensity.

Thirteen trials presented both BMI and weight outcomes and were included in both meta-analyses;^72, 85, 91, 97, 106, 126, 146, 147, 149, 154, 188, 194, 209^ seven additional studies were unique to each respective plot. Thus, these two outcomes represent slightly different sets of studies. The meta-analysis of BMI measures showed a pooled MD of −0.41 kg/m^2^ (95% CI, −0.62 to −0.19; k=20; n=55,059; I^2^=95.8%) related to healthful diet and physical activity interventions (Figure 10). The range in between-group differences in change in BMI was 0.6 kg/m^2^ in favor of the control group and 2.1 kg/m^2^ in favor of the intervention group (Appendix F Table 6). The subset of nine high-intensity interventions consistently showed benefit of the interventions on BMI, with a pooled MD in change of −0.81 kg/m^2^ supporting the intervention (95% CI, −0.99 to −0.63) (Figure 10; Table 5); no such benefit was seen among the subsets of medium- or low-intensity interventions, although the number of studies contributing to these subgroups was smaller (seven and four studies for medium- and low-intensity subgroups, respectively). A dose-response effect was seen, with increasing intensity being statistically significantly associated with increasing effect estimates (p=0.004). Two trials reported large, nearly statistically significant effects in an unexpected direction (i.e., favoring the control group).^98, 154^ Sensitivity analyses excluding those trials resulted in a slightly larger pooled effect estimate for BMI (MD, −0.50 kg/m^2^ [95% CI, −0.72 to −0.27]) but did not improve the statistical heterogeneity (I^2^=96.1%). The same sensitivity analyses for weight and waist circumference showed a similar pattern.

A separate meta-analysis showed a statistically significant association with weight in favor of behavioral interventions over control conditions, although again the statistical heterogeneity was considerable (MD, −1.04 kg [95% CI, −1.56 to −0.51]; k=20; n=51,401; I^2^=92.4%) (Figure 11). This finding translates into an MD of −2.3 lb (95% CI, −3.4 to −1.1). The dose-response effect of intervention intensity with weight was also evident (meta-regression, p=0.035). ^143^ Nine trials reported adiposity outcomes over time; consistent or slightly attenuated effects were seen for BMI or weight outcomes from 6 months to 6 years of followup across trials.^72, 91, 140, 143, 160, 194, 205, 207, 209^

There was no trend in the effect estimates for BMI or weight according to the samples’ mean BMI or weight at baseline. For example, while the largest difference in BMI reduction was seen among the sample with the highest BMI at baseline—the Aldana study, in which the mean baseline BMI was 32.3 kg/m^2^ and the MD in change was −1.3 kg/m^2^ at 6 months^85^—relatively large differences were also seen among samples with a mean BMI reflecting normal or borderline overweight status (e.g., studies by Brekke,^97^ Simkin-Silverman,^194^ and Hellenius^135^). Across adiposity outcomes, only three studies required participants to be overweight or have obesity upon study entry.^91, 146, 205^

Five trials could not be included in the meta-analyses for BMI^211, 219^ or weight^156, 204, 207^ because of limitations in data reporting (e.g., no measure of dispersion). Results of these trials were mixed, with two trials generally showing no change in adiposity within or between groups,^207, 211^ two trials showing a difference in mean weight change in favor of the intervention versus control group but no estimate in the confidence of the effect,^156, 204^ and one trial showing a slightly better improvement in BMI among control group participants (−1.3 kg/m^2^) versus those participating in a Web-based intervention (−0.6 kg/m^2^).^219^

Seventeen studies (all of which also reported BMI or weight outcomes) presented a measure of waist circumference at 6 months to 2 years of followup (Appendix F Table 6). Pooled analyses suggested a reduction of approximately −1.19 cm (0.5 in) in waist circumference related to a diet and/or physical activity intervention (95% CI, −1.79 to −0.59; k=17; n=50,500; I^2^=91.8%) (Figure 12). Mean baseline waist circumference ranged considerably, from 72 cm in a sample of young adults (mean age, 19.7 years)^72^ to 105 cm among samples of older adults.^146, 208^ Eight studies also reported the percentage of body fat of participants before and after the intervention (Appendix F Table 6). Two trials suggested a benefit of the intervention on percent body fat;^85, 194^ the remaining trials were inconsistent in the direction and magnitude of effect on percent body fat.^80, 146, 154, 207, 208, 219^

There was very little evidence to indicate that interventions resulting in the greatest between-group changes in adiposity outcomes (BMI, weight, or waist circumference) were the most beneficial in affecting other intermediate outcomes. For example, in the Coronary Health Improvement Project, primarily among adults with obesity, statistically significant benefits of the healthful diet and physical activity intervention were seen for both BMI (MD, −1.30 kg/m^2^ [95% CI, −1.65 to −0.96]) and weight (MD, −3.90 kg [95% CI, −5.00 to −2.80]) outcomes at 6 months, but no such between-group differences were seen for blood pressure, lipid, or glucose outcomes.^85^ Likewise, the Shape Program, a weight gain prevention program among black women who were overweight or had obesity, reported larger 12- and 18-month weight changes among intervention versus control participants (MD at 12 months, −1.4 kg [95% CI, −2.8 to 0.1]), but reported no such differences in treatment arms for change in blood pressure, lipid, or glucose levels at any time point.^91^ Other studies that reported statistically significant benefits on adiposity outcomes reported no statistically significant benefits on other intermediate outcomes^80, 135, 190^ or only one other intermediate outcome (e.g., SBP,^106^ DBP,^209^ total cholesterol,^146, 188^ HDL cholesterol,^97^ and triglycerides^72^) and no apparent pattern in effects across trials. Only one trial, the Women’s Healthy Lifestyle Project, showed a consistent benefit of the high-intensity intervention across adiposity and other cardiometabolic intermediate outcomes.^194^ These interventions, however, were not necessarily designed to induce greater weight loss among intervention versus control group participants; rather, the goal was to prevent weight gain.

#### Cardiovascular Risk Status

Four trials used the Framingham risk equation to report the effects of a diet or physical activity intervention on multivariate cardiovascular risk status.^111, 118, 135, 176^ The results for this outcome were consistent with the results of other intermediate outcomes reported by each respective trial. Despite seeing reductions in 4- or 10-year risk of coronary heart disease among intervention group participants at 6 to 12 months, there was no statistically significant difference compared with control groups. For instance, in the U.S.-based primary care study Family Intervention Trial for Heart Health, there was no statistically significant difference in the proportion of participants with a Framingham absolute risk of less than 10 percent between the intervention and control groups (90% vs. 92%) (p=0.51).^176^ Likewise, in an older trial by Hellenius et al, a significant reduction in 10-year CVD risk was seen among all three intervention arms after 6 months (a reduced risk of 12% to 14%), but there were no differences in between-group comparisons with the control group.

### Effect Modifiers, Including Intervention Components

We explored potential differences in the effects of the interventions on intermediate outcomes as they related to specific study, population, and intervention characteristics. Specifically, we examined possible effect modification using meta-regression for five prespecified variables: study quality (good vs. fair), link to primary care (yes vs. no), intervention intensity (as a continuous variable in minutes and categorical as high- vs. medium- or low-intensity), duration of the intervention (continuous in weeks) and, for adiposity outcomes, mean baseline BMI or weight. Other prespecified variables, including population risk for CVD, number of intervention sessions, offers of group sessions, and a focus on diet (messages regarding a general heart-healthy diet, sodium reduction, increased intake of fruits and vegetables, and/or low-fat diet patterns) showed no apparent relationship with the effects on any of the intermediate outcomes after visual inspection of plots and tables. Therefore, we did not conduct meta-regression to explore effect modification for these variables.

Of all these factors, only intervention intensity (evaluated either continuously in estimated minutes or categorically as high- vs. medium- and low-intensity) and whether the studies recruited participants from or were conducted in primary care were consistently associated with pooled effect estimates across outcomes (p<0.05). Across the intermediate outcomes, larger effects were seen with increasing intensity of the intervention (Table 5). Intervention intensity, as measured by the estimated total minutes of contact, ranged from 15 to 2,340 minutes (39 hours) among the studies that reported at least one intermediate outcome. The range of estimated contact time was 40 to 240 minutes (4 hours) for medium-intensity interventions and 420 minutes (7 hours) to 2,340 minutes (39 hours) for high-intensity interventions. This estimate of intensity included only sessions that were conducted face-to-face with an interventionist, by telephone, or using a computer. Print-based materials and mailings did not contribute to the intensity value. Interventions that were solely print-based were always categorized as low intensity. Our estimates of intensity were based on the planned (vs. actual) number and length of sessions; in several cases, we made assumptions and provided estimates regarding the number and length of sessions based on details provided in each article. Our methods for estimating intensity are described in detail in Chapter 2. Intensity appears to be confounded by several factors. In general, interventions of higher intensity focused on healthful diet messages and may or may not have included physical activity messages. Very few interventions of higher intensity focused on physical activity only. In addition, higher intensity interventions were generally longer in duration (e.g., ≥1 year), although the bulk of the intensive phase of these interventions generally occurred in the first 6 months. Lastly, almost all of the high-intensity interventions relied on volunteer or other convenience samples and did not occur in a primary setting. Across the 30 studies that reported an intermediate outcome, only two studies in primary care were categorized as high intensity.

Nine studies had more than one active intervention arm designed to contrast specific approaches; four included multiple interventions of the same intensity but with different behavior change messages,^97, 135, 169, 220^ one compared diet messages,^140^ and four others tested the effects of varying intervention components and delivery modes on intermediate outcomes.^143, 149, 154, 198^ There was no consistent pattern within or across these studies that suggested that diet-only, physical activity–only, or diet plus physical activity messages (particularly behavior change techniques or dietary messages) or specific intervention strategies were preferable across intermediate outcomes.

### Subpopulations

Direct within-study analyses of particular subpopulations of interest (i.e., age, race/ethnicity, and sex) were sparse, often not prespecified, and rarely included interaction testing, so we could draw no definitive conclusions about differential effectiveness on intermediate outcomes. Only one trial reported varying effects of the intervention based on age subgroups; in the large WHI Dietary Modification Trial (n=45,887), there was no interaction between the effect of the intervention and age group (50 to 59, 60 to 69, and 70 to 79 years) for incidence of diabetes at up to 8 years of followup.^209^ Two trials reporting intermediate outcomes by race/ethnicity showed no consistent evidence of effect modification for blood pressure,^158, 159^ weight,^138^ or incidence of diabetes.^209^ Four studies reported effects by sex.^90, 149, 159, 188^ In the TOHP phase I trial (n=744), no significant differences in treatment effectiveness were found between men and women in changes in DBP, but there was a significant difference for SBP, with an adjusted treatment effect of −1.23 mm Hg (95% CI not reported) for men and −4.44 mm Hg (95% CI not reported) for women (p=0.02 for interaction).^159^ Three other studies reported the effects of the intervention on lipids^90, 188^ or adiposity outcomes^149^ for men and women separately, but they did not report interaction testing, and MDs appeared similar across subgroups.^90, 188^

Given the high potential for confounding by clinical differences in these samples and from other sources of clinical heterogeneity, such as intervention intensity, we did not perform indirect comparisons of subpopulation effects across trials (e.g., trials of women vs. men)

### Reporting Bias

Overall, there was no evidence of small-study effects for any of the intermediate outcomes based on visual inspection of funnel plots and Egger’s test.

## KQ 3 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Associated Health Behaviors in Adults?

### Summary of Results

All but two^91, 211^ of the 88 included studies reported the effects of a behavioral intervention on dietary, physical activity, and/or sedentary behavior outcomes. Of these 86 studies, we rated 18 as good quality and the remaining 68 as fair quality. More than one third of the studies that reported behavioral outcomes (36 of 86 studies) were newly identified as part of our update. Almost all of the behavioral outcomes were based on self-report; three trials measured urinary sodium excretion and 11 trials used accelerometers or pedometers to capture objective measures of physical activity. The instruments, modes of administration, and summary measures were highly variable across trials that measured behavioral outcomes through self-report.

Overall, there was evidence that behavioral interventions generally improved participants’ dietary intake and physical activity levels (Table 6). Mean between-group differences for dietary outcomes generally showed consistent benefit of the intervention versus control groups, but the precision in the magnitude of effects was quite variable across the trials that reported each respective outcome, and each meta-analysis found considerable statistical heterogeneity (I^2^=88% to 99% in each analysis). We examined a number of clinical and study characteristics across the trials (e.g., study quality, intervention intensity, intervention focus [diet messages only vs. diet plus physical activity messages], broad population characteristics, specific dietary messages, and baseline dietary intake) in an attempt to help explain the heterogeneity. We also conducted sensitivity analyses as appropriate. Although a meta-regression for continuous intensity was statistically significant for some dietary outcomes, statistical heterogeneity remained considerable within groups when stratified by intensity. Given the considerable statistical heterogeneity within each meta-analysis, we do not present the pooled effect estimate for any dietary outcome, as we do not feel confident that these effects reflect the average effects. Rather, we present forest plots to illustrate the range of effects seen across studies. In general, healthful diet interventions (with or without physical activity messages) were associated with reduced total energy, fat, saturated fat, and sodium intake and increased fiber and fruit and vegetable intake compared with control arms. Between-group differences for dietary outcomes were in the magnitude of 65 kcal/day (favoring the control group) to −500 kcal/day (favoring the intervention group) in total energy intake (k=11), 0.8 to −11 percentage points in the percent of calories from fat (k=15), and −0.3 to −4.1 percentage points in the percent of calories from saturated fat (k=9). Effects on fruit and vegetable intake ranged from between-group differences of −0.2 servings/day (favoring the control group) to 2.2 servings/day (favoring the intervention group) (k=16); between-group differences in grams of fiber per day ranged from 1 to 2.5 g/day in favor of the intervention group (k=6). Reductions in sodium ranged from −380 to −1,380 mg/day (k=6). Consistent effects of the interventions were seen over time for all dietary outcomes among studies that reported multiple time points.

Table 6 Results of Behavioral Outcomes for All Interventions

Outcome | Mean difference in change (95% CI)^*^ | Trials, k | I^2^, %
Total energy (kcal/day)^†^ | Range: 65 to −500 | 11 | NA
Fat (% of energy from fat) | Range: 0.8 to −11.0 | 23^‡^ | NA
Saturated fat (% of energy from fat) | Range: −0.3 to 4.1 | 15^§^ | NA
Fruits and vegetables (servings/day) | Range: −0.2 to 2.2 | 26^\|\|^ | NA
Fiber (g/day) | Range: 1 to 2.5 | 11^¶^ | NA
Sodium (mg/day) | Range: −380 to −1380 | 6 | NA
Physical activity (standardized mean difference) | 0.20 (0.14 to 0.26) | 46 | 60.2
Physical activity (min/week) | 34.5 (22.0 to 47.0) | 27 | 67.7
Meeting physical activity recommendations | 1.32 (1.12 to 1.56)^#^ | 16 | 70.3

* Pooled results for dietary outcomes are not presented given considerable statistical heterogeneity in all analyses (I^2^>88%). Instead, we present the range of between-group differences observed in trials reporting each respective outcome.

† To convert kcal to kJ, multiply by 0.239.

‡ 15/23 trials reported daily percent of energy from fat.

§ 9/15 trials reported daily percent of energy from saturated fat.

|| 20/26 trials reported servings/day.

¶ 6/11 trials reported g/day.

# Odds ratio (95% CI).

Abbreviations: CI=confidence interval; min=minute; NA=not applicable.

Physical activity interventions (with or without dietary messages) resulted in an approximate 35-minute increase in physical activity per week compared with controls (k=27). Additionally, intervention group participants had a 32 percent higher odds of meeting physical activity recommendations compared with those in the control group (k=16). Studies that limited enrollment to participants with suboptimal levels of physical activity at baseline (generally below the recommended level of 150 minutes per week) resulted in greater increases in physical activity compared with those that did not limit enrollment based on baseline physical activity levels. In contrast to findings for intermediate outcomes, there was no evidence of effect modification based on intervention intensity. Likewise, there was no evidence of a difference in effects for interventions focused only on physical activity messages versus those focused on both physical activity and healthful diet messages.

Among trials that reported both intermediate and behavioral outcomes (k=32), findings were generally concordant within studies (Table 7). That is, trials that reported a statistically significant benefit of the intervention on one or more intermediate outcomes also reported statistically significant benefit on dietary and/or physical activity behaviors at each given time point. Furthermore, the specific intermediate outcome showing benefit within each trial generally reflected the specific behavior changes targeted in that trial. For example, trials that reported significant reductions in measures of blood pressure as a result of the interventions generally also found significant reductions in measures of sodium intake.^137, 204, 205^ Studies finding differences in between-group mean BMI and/or weight reductions also reported large between-group reductions in total caloric intake (e.g., studies by Aldana,^85^ Coates,^106^ Simkin-Silverman,^194^ and Tinker^209^). The limited number of studies that reported a statistically significant benefit of the intervention on LDL or total cholesterol reported concordant significant between-group reductions in total fat and saturated fat intake.^188, 194^ In many instances in which trials did not find any benefit in intermediate outcomes, the trials demonstrated statistically significant improvements in dietary intake and/or physical activity.^90, 98, 111, 126, 130, 140, 147, 156, 160^ Among the physical activity–only interventions that reported increased physical activity levels as a result of the interventions, statistically significant effects on intermediate outcomes were limited to waist circumference,^80, 135^ HDL cholesterol level,^122^ or BMI or weight.^146^ There was only one trial that reported statistically significant improvements in intermediate outcomes in the absence of concurrent improvements in behaviors; in the weight gain prevention trial by Hivert et al^72^ among 115 college students, a difference of 1.4 kg in weight change was found between groups, despite no obvious differences between groups in dietary intake or physical activity levels.

Table 7 Summary of Findings Across Intermediate and Behavioral Outcomes, by Author

Author, Year | Int focus | KQ 2: Intermediate outcomes | | | | | | | | | | | KQ 3: Behavioral outcomes
Author, Year | Int focus | SBP | DBP | LDL-C | TC | HDL-C | TG | Glucose | BMI | Weight | WC | CVD Risk | Diet^*^ | PA
Aadahl, 2014^80^ | PA | | | ↑ | ↑ | ↔ | ↑ | ↔ | | ↑ | ↑↑ | | NA | ↑↑^†^
Aldana, 2006^81^ | HD+PA | ↑ | ↑ | ↑ | ↑ | ↓ | ↑ | ↑ | ↑↑ | ↑↑ | | | ↑↑ | ↑↑
Baron, 1990^90^ | HD | | | ↔ | ↔ | ↔ | | | | | | | ↑↑ | NA
Bennett, 2013^91^ | HD+PA | ↔ | ↑ | ↑ | ↑ | ↔ | ↓ | ↓ | ↑↑ | ↑↑ | ↑
Brekke, 2005^97^ | HD+PA | | | ↑ | ↓ | ↓↓ | ↓ | ↑ | ↑↑ | ↑↑ | ↑ | | ↑↑ | ↑^‡§^
Bryan, 2013^98^ | PA | | | | | | | | ↓ | | | | NA | ↑↑
Coates, 1999^106^ | HD | ↑↑ | ↔ | | | | | ↑ | ↑↑ | ↑↑ | ↑↑ | | ↑↑ | NA
Elley, 2003^111^ | PA | ↑ | ↑ | | ↔ | | | | ↔ | | | ↑ | NA | ↑↑
Grandes, 2009^122^ | PA | ↔ | ↓ | ↑ | ↔ | ↑↑ | ↓ | ↔ | ↔ | | ↔ | ↑ | NA | ↑↑
Greenlee, 2015^126^ | HD | | | | | | | | ↑ | ↑ | ↑ | | ↑↑ | NA
Hargreaves, 2016^130^ | PA | | ↑ | | ↑ | | | | | | | | NA | ↑↑
Hellenius, 1993^135^ | HD+PA | ↑ | ↑ | ↑ | ↑ | ↔ | ↑ | | ↑↑ | | ↑↑ | ↑ | ↔ | ↑↑
Hinderliter, 2014^137^ | HD | ↑↑ | ↓ | | | | | | | | | | ↑↑ | NA
Hivert, 2007^72^ | HD+PA | ↑ | ↓ | ↑ | ↑ | - | ↑↑ | | ↑↑ | ↑↑ | ↑ | | ↔ | ↑
HPT, 1990^140^ | HD | ↑ | ↑ | | | | | | | ↔ | | | ↑↑ | NA
Jeffery, 1999^143^ | HD+PA | | | | | | | | | ↔ | | | ↔ | ↔
John, 2002^144^ | HD | ↑↑ | ↑↑ | | ↔ | | | | | ↔ | | | ↑↑ | NA
Kallings, 2009^146^ | PA | ↓ | ↓ | ↑ | ↑ | ↔ | ↑ | ↑ | ↑↑ | ↑↑ | ↑ | | NA | ↑↑
Kattelmann, 2014^147^ | HD+PA | | | | | | | | ↑ | ↑ | ↔ | | ↑↑ | ↔
Kerr, 2016^149^ | HD | | | | | | | | ↑ | ↑ | | | ↔ | NA
Kinmonth, 2008^154^ | PA | ↔ | ↓ | ↓ | ↓ | ↓ | ↓ | ↓↓ | ↓ | ↓ | ↓ | | NA | ↔
Kristal, 2000^156^ | HD | | | | | | | | | ↑^‡^ | | | ↑↑ | NA
Lawton, 2008^160^ | PA | ↑ | ↔ | | ↑ | ↔ | | ↔ | | ↑ | ↑ | | NA | ↑↑^§^
Mosca, 2008^176^ | HD+PA | ↔ | ↑ | ↔ | ↓ | ↑ | ↑ | ↔ | ↔ | | ↔ | ↑ | ↔ | ↑
Roderick, 1997^188^ | HD | ↑ | ↔ | | ↑↑ | | | | ↔ | ↑↑ | | | ↑↑ | NA
Sacerdote, 2006^190^ | HD | ↔ | ↔ | | | | | | ↑↑ | | | | ↑↑ | NA
Simkin-Silverman, 1995^194^ | HD+PA | ↑↑ | ↑ | ↑↑ | ↑↑ | ↓↓ | ↑↑ | ↑↑ | ↑↑ | ↑↑ | ↑↑ | | ↑↑ | ↑↑
Thompson, 2008^207^ | HD+PA | ↑ | ↔ | ↔ | ↔ | ↔ | ↔ | ↔ | ↑ | ↔^‡^ | ↑ | | ↔ | ↑
Thompson, 2014^208^ | PA | ↑ | ↑ | | ↑ | ↓ | ↓ | ↓ | | ↔ | ↔ | | NA | ↑
Tinker, 2008^209^ | HD | ↑↑ | ↑↑ | | | | | | ↑↑ | ↑↑ | ↑↑ | | ↑↑ | NA
TOHP I, 1992^204^ | HD | ↑↑ | ↑↑ | | | | | | | ↑^‡^ | | | ↑↑ | NA
TOHP II, 1997^205^ | HD | ↑↑ | ↑↑ | | | | | | | ↔ | | | ↑↑ | NA
Valve, 2013^211^ | HD+PA | | | | | | | | ↔^‡^
Wadsworth, 2010^219^ | PA | | | | | | | | ↓^‡^ | | | | NA | ↑

Symbol Legend:

↑↑ = Statistically significant between-group difference in favor of intervention group.

↑ = Between-group difference in favor of intervention group, but not statistically significantly different.

↔ = No clear between-group difference. For blood pressure, between-group change <0.5 mm Hg. For cholesterol and glucose, between-group change of <1.0 mg/dL. For BMI, between-group change of <0.25 kg/m^2^. For weight and waist circumference, between-group change of <0.5 kg or cm, respectively. For dietary outcomes, total energy intake <100 kcal/day, percent energy from total fat and saturated fat <1%, fiber <0.10 standardized mean difference, and fruits and vegetables <0.5 serving/day. For physical activity, standardized mean difference <0.10.

↓ = Between-group difference in favor of control group, not statistically significantly different.

↓↓= Statistically significant between-group difference in favor of control group.

* For majority of reported dietary outcomes. See Appendix F Table 7 for detailed dietary outcome results.

† Self-reported sitting time.

‡ Not included in meta-analysis.

§ For percent meeting physical activity recommendations.

Abbreviations: BMI=body mass index; CVD=cardiovascular disease; CVD risk=Multivariate risk status; DBP=diastolic blood pressure; HD=healthful diet; HD+PA=healthful diet and physical activity; HDL-C=high-density lipoprotein cholesterol; Int=intervention; KQ=key question; LDL-C=low-density lipoprotein cholesterol; PA=physical activity; NA=not applicable; SBP=systolic blood pressure; TC=total cholesterol; TG=triglycerides; WC=waist circumference.

### Detailed Results by Outcomes

#### Diet

Forty-one studies reported one or more dietary outcomes, including total energy and intake of fat and saturated fat, fruits and vegetables, fiber, and sodium.^72, 85, 86, 90, 92, 93, 97, 100, 101, 106, 109, 115, 116, 125, 126, 135, 137, 140, 141, 143, 144, 147, 149, 152, 156, 162, 176, 181, 188–190, 194, 197, 198, 203–205, 207, 209, 210, 217^ Only six of the 41 studies were rated as good quality. Furthermore, only 14 were newly identified as part of our update. We limited our abstraction and analyses to these six specific dietary outcomes for consistency with the original review and to focus our results. Many trials, however, reported the effects of the interventions on other important dietary outcomes, such as intake of carbohydrates, protein, cholesterol, milk/dairy, potassium, and whole grains. With the exception of three studies that assessed sodium intake based on urine sodium excretion, the studies relied on self-reported dietary intake. The instruments to assess dietary intake were extremely heterogeneous and evidence of validity and reliability varied. Recall periods ranged from 1 to 7 days, with many studies not reporting the specific recall period.

Within these 41 studies, there were 56 unique intervention arms aimed at improving dietary intake, with or without physical activity messages. Most of the interventions were of medium or high intensity. The specific dietary aims, and the reporting of these details, varied widely across trials (Table 4; Appendix E Table 1). Most of the interventions centered dietary messages on general heart-healthy eating patterns that included limiting fat intake, decreasing intake of saturated and trans fat, eating a variety of fruits and vegetables, limiting intake of sodium, and emphasizing whole grains. Six studies specifically emphasized increasing fruit and vegetable intake^86, 93, 125, 144, 162, 189^ while another five studies focused only on reducing fat intake.^92, 106, 116, 141, 217^ The four trials focused on decreased sodium intake enrolled persons with above-normal blood pressure.^137, 140, 204, 205^ Most of the trials that reported a dietary outcome were conducted in the United States (26 of 41 trials), and nearly half of them were recruited from or took place in a primary care setting. Additional characteristics of these interventions are described above (Intervention Characteristics).

##### Total Energy

Thirteen trials reported self-reported total energy intake in terms of kilocalories per day at 6 months to 6 years of followup (n=46,955) (Appendix F Table 7).^72, 85, 93, 97, 106, 126, 135, 143, 194, 197, 207, 209, 210^ Baseline energy intake ranged from approximately 1,450 to 2,500 kcal/day among the included trials. Nearly all of the trials reported greater reductions in total energy intake among intervention versus control participants; seven of the 13 studies reported statistically significant greater benefit at 6 months to 1.5 years (Figure 13).^85, 106, 126, 194, 197, 209, 210^ Across the trials, participants in the intervention groups generally decreased their total energy intake by approximately −13 to more than −550 kcal/day, whereas the control groups ranged from a reduction of −25 to −243 kcal/day (range of between-group differences, 65 kcal/day in favor of the control group, 500 kcal/day in favor of the intervention group). For example, at 1 year in the WHI Dietary Modification Trial, women taking part in the high-intensity group counseling intervention (n=17,117) reported a decrease that was 94 kcal/day (95% CI, −106.15 to −81.85) greater than that of women in the control group (n=25,182). An even greater between-group difference was seen at the end of the 6-year intervention (MD, −115 kcal/day [95% CI, −128.28 to −101.72]).^209^ Persistent effects of the interventions on total energy intake were seen over time in all of the trials that reported multiple timepoints.^72, 143, 194, 207^

Figure 13 Change in Total Energy Intake in Healthful Diet Interventions (With or Without Physical Activity) Compared With Controls^*^ * Pooled estimate not presented given considerable statistical heterogeneity in meta-analysis.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DM=diabetes mellitus; Elev=elevated; GDM=gestational diabetes mellitus; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in total energy intake (kcal/day) in healthful diet interventions (with or without physical activity) compared with controls.

##### Fat and Saturated Fat

All but one of the studies that reported total energy intake and an additional 14 studies reported the effects of a healthful diet intervention (with or without physical activity messages) on self-reported fat and/or saturated fat intake (k=25; n=54,897 for fat and n=49,463 for saturated fat) (Appendix F Table 7).^72, 85, 92, 97, 100, 101, 106, 109, 115, 116, 126, 135, 141, 143, 147, 152, 156, 176, 188, 194, 197, 198, 207, 209, 217^ Fat intake outcomes varied across trials and included fat reported as percent of energy, grams of fat per day, or a study-defined score. There was consistent evidence of an effect of the interventions on both total fat (Figure 14) and saturated fat intake (Figure 15) at 6 months to 1.5 years of followup. Looking specifically at the 15 trials that reported the daily percent of energy from fat, the magnitude of between-group differences was generally from approximately 0.8 percentage points (favoring the control group) to −11 percentage points (favoring the intervention group) of total energy from fat, with mean baseline percent of energy from fat ranging from approximately 30 to 40 percent (Appendix F Table 7).^72, 85, 92, 97, 106, 115, 126, 135, 143, 147, 176, 188, 194, 209, 217^ For saturated fat, mean between-group differences ranged from about −0.3 to −4.1 percentage points in the reduction of saturated fat intake, in favor of the intervention groups. For example, a trial by King et al^152^ of a 1-year telephone counseling intervention reported mean changes in the percent of energy from saturated fat ranging from −1.8 to −2.5 percentage points within three active intervention arms, while the control arm experienced a decrease of only −1.2 percentage points (a statistically significant between-group difference for the active intervention arm focusing simultaneously on diet and physical activity and the arm focusing on messages sequentially, with diet messages first). Additionally, a greater proportion of intervention participants were meeting recommendations for less than 10 percent of calories from saturated fat among the three active intervention arms (40% to 59%) versus the control arm (31%). Among trials that reported both total fat and saturated fat outcomes, consistent results were seen across these outcomes within each trial.

Figure 14 Change in Fat Intake in Healthful Diet Interventions (With or Without Physical Activity) Compared With Controls^*^ * Pooled estimate not presented given considerable statistical heterogeneity in meta-analysis.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DM=diabetes mellitus; Elev=elevated; GDM=gestational diabetes mellitus; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in fat intake (% energy) in healthful diet interventions (with or without physical activity) compared with controls.

Figure 15 Change in Saturated Fat Intake in Healthful Diet Interventions (With or Without Physical Activity) Compared With Controls^*^ * Pooled estimate not presented given considerable statistical heterogeneity in meta-analysis.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DM=diabetes mellitus; Elev=elevated; GDM=gestational diabetes mellitus; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in saturated fat intake (% energy) in healthful diet interventions (with or without physical activity) compared with controls.

##### Fruits and Vegetables

Twenty-six studies reported fruit and vegetable intake and found that healthful diet interventions generally resulted in small increases in fruit and vegetable intake compared with controls (n=67,821) (Figure 16; Appendix F Table 7).^85, 86, 93, 100, 101, 106, 109, 115, 125, 126, 141, 144, 147, 149, 152, 156, 162, 176, 181, 188–190, 198, 203, 207, 209^ Again, the meta-analysis of trials reporting servings per day of fruit and vegetables found considerable heterogeneity (I^2^=95.6%); thus, we do not present the pooled estimate. Between-group differences in the mean change of fruit and vegetable intake ranged from −0.2 servings/day (favoring the control group) to 2.2 servings/day (favoring the intervention group) at 6 months to 1 year of followup; baseline servings of fruits and vegetables were between 3 and 6 servings/day. All six trials that focused dietary messages exclusively on increased fruit and vegetable intake found statistically significantly greater benefit among intervention versus control participants.^86, 93, 125, 144, 162, 189^ For example, the U.S.-based Making Effective Nutritional Choices study by Alexander et al^86^ (n=2,540) found a statistically significantly greater increase in the number of fruit and vegetable servings per day for the intervention group randomized to the use of a tailored Web-based intervention plus email counseling (+2.8 servings/day [95% CI, 2.6 to 3.0]) compared with a control arm randomized to a generic nutrition Web site (+2.3 servings/day [95% CI, 2.1 to 2.5]). Likewise, another computer-tailored Web-based intervention—the Family Healthware Impact Trial (n=3,389)—found that intervention participants were more likely to increase daily fruit and vegetable consumption from 5 or fewer servings/day to 5 or more servings/day after 6 months (adjusted OR, 1.29 [95% CI, 1.05 to 1.58]). The intervention itself was generally low intensity in that it involved no face-to-face contact with an interventionist; participants could complete the intervention in one Web-based session or through multiple sessions over the course of 6 months.^189^

Figure 16 Change in Fruit and Vegetable Intake in Healthful Diet Interventions (With or Without Physical Activity) Compared With Controls^*^ * Pooled estimate not presented given considerable statistical heterogeneity in meta-analysis.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; CVD=cardiovascular disease; DM=diabetes mellitus; Elev=elevated; GDM=gestational diabetes mellitus; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity; RF=risk factor.

This figure is a forest plot of the change in fruit and vegetable intake (servings/day) in healthful diet interventions (with or without physical activity) compared with controls.

##### Fiber

Fewer trials (k=11; n=47,218) reported the effects of interventions on fiber intake.^90, 92, 93, 97, 100, 109, 116, 176, 188, 197, 209^ Six of the trials reported fiber intake in terms of grams per day, whereas the remaining five trials reported grams per 1,000 kilocalories per day or a study-defined fiber score (Appendix F Table 7). All but one of the 11 trials are shown in the forest plot that presents the standardized MD (SMD) in fiber intake (Figure 17). The remaining trial^109^ did not present within-group variance but reported a statistically significantly greater increase in grams of fiber per day among intervention versus control participants (adjusted MD, 1.00 g/day [95% CI, 0.40 to 1.60]). In general, all but one of the trials suggested a benefit of the intervention on fiber intake but only four of the individual trials reported statistically significantly greater benefit versus the control group.^90, 97, 109, 209^ Among studies reporting change in fiber intake as grams per day, the magnitude of between-group difference was approximately 1 to 2.5 g/day at 6 months to 1 year in favor of the intervention groups. The baseline levels of fiber intake were quite low in these samples, ranging from 6 to 25 g/day.

Figure 17 Change in Fiber Intake in Healthful Diet Interventions (With or Without Physical Activity) Compared With Controls^*^ * Pooled estimate not presented given considerable statistical heterogeneity in meta-analysis.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; DM=diabetes mellitus; Elev=elevated; GDM=gestational diabetes mellitus; HD=healthful diet; hx=history; IG=intervention group; Int=intervention; MD=mean difference; OW=overweight; Pop=population; PA=physical activity.

This figure is a forest plot of the fiber intake (standardized mean difference) in healthful diet interventions (with or without physical activity) compared with controls.

##### Sodium

Six trials, all of which were conducted in the United States, reported sodium outcomes (n=2,572) (Appendix F Table 7).^85, 101, 137, 140, 204, 205^ All of the interventions included specific messages about decreasing salt or sodium intake, including counseling on the DASH diet,^101, 137^ specific goals for decreasing sodium intake to approximately 1,400 to 1,600 mg or less per day,^140, 204, 205^ or general messages about reducing dietary salt intake.^85^ We did not pool these studies given the small number of trials and extensive variability in the populations and measurement of sodium (i.e., self-reported vs. 8- to 24-hour urine collection). All but one of the trials reported statistically significantly greater reductions in sodium among intervention versus control group participants. The one trial that found no benefit was one of the two trials reporting this outcome that included general heart healthy dietary messages, including limiting salt intake, but did not focus on salt intake alone.^101^ The remaining trials reported quite large differences in sodium (mg/day) or urinary sodium output (mmol/8 or 24 hours) between intervention and control participants, with evidence of persistence in the effects up to 3 years of followup (Appendix F Table 7). For example, in the trial by Aldana et al,^85^ which included general messages about decreasing salt intake, intervention group participants reduced their sodium intake on average from a baseline of 2,941 to 2,332 mg/day at 6 months (MD, −609 mg/day [95% CI, −817 to −401]), whereas control group participants decreased intake from 2,712 to 2,486 mg/day over this same period (MD, −226 mg/day [95% CI, −402 to −50]), for a statistically significant between-group difference of −383 mg/day (95% CI, −590 to −176) in favor of the intervention group. The TOHP phase I and phase II trials among adults with high-normal blood pressure indicated statistically significant between-group differences in urinary sodium output, which ranged from approximately −40 mmol/24 hours (−920 mg/day) to −60 mmol/24 hours (−1,380 mg/day) at up to 3 years of followup. The most intensive phases of these two interventions occurred within the first 3 and 4 months of the studies, with refresher or booster sessions occurring up to 1.5 to 3 years, respectively.^204, 205^

#### Physical Activity

Sixty-three trials reported the effects of a behavioral intervention on participants’ physical activity levels (Appendix F Table 8).^72, 81, 83, 85, 94, 97, 98, 100, 102, 103, 108, 111, 112, 115, 120, 122, 123, 128, 131, 132, 135, 141, 143, 146, 148, 152–155, 160, 161, 166, 167, 170, 172, 176, 177, 179, 181, 184–186, 189, 194, 197, 201, 203, 207, 208, 210, 212, 214, 217–219^ Within these 63 trials, 14 trials were of good quality and the remaining 49 trials of fair quality. Physical activity was the primary outcome in 41 trials.^81, 83, 94, 98, 100, 102, 103, 108, 111, 112, 115, 120, 122, 123, 131, 132, 141, 146, 148, 152–155, 160, 161, 166, 167, 170, 172, 177, 179, 181, 184–186, 189, 197, 201, 203, 207, 208, 210, 212, 214, 217–219^ Thirty trials were newly identified as part of this update and 33 were included in the original review. Most of the studies relied on self-reported measures of physical activity (e.g., 7-day physical activity recall, International Physical Activity Questionnaire); only 11 studies used accelerometers^113, 132, 164, 169, 194, 197, 208^ or pedometers^94, 119, 130, 212^ to capture an objective measure of physical activity. The specific physical activity outcomes were highly variable across studies and included continuous measures such as total physical activity, moderate- to vigorous-intensity physical activity, walking, study-defined physical activity scores, and a binary measure of the number of participants meeting physical activity recommendations (≥150 minutes of moderate-intensity or 75 minutes of vigorous-intensity physical activity per week). Likewise, the unit of measurement for each of these outcomes was very diverse (e.g., minutes/week, metabolic equivalent of task [MET]-minutes/week, days/week, steps/day, kcal/kg/day).

Across the 87 intervention arms included in these 63 trials, most were of low or medium intensity and focused on physical activity alone. Additional characteristics of these interventions are described above (see Intervention Characteristics). Low-intensity interventions were mostly print-, Web-, or text-based interventions whereby participants received tailored information to set appropriate behavior change goals and monitor their progress and which were typically based on the stages of change (transtheoretical) model. Medium-intensity interventions typically included at least one face-to-face session and followup with several telephone counseling calls. High-intensity interventions often included group sessions. Almost half of the trials that reported a physical activity outcome were conducted in the United States (35 of 63 trials); however, only six of these U.S.-based studies were conducted in a primary care setting or included intervention components delivered by primary care staff.^117, 120, 148, 179, 186, 203^

##### Continuous Levels of Physical Activity

Overall, there was evidence that behavioral interventions increased participants’ physical activity levels (Table 6). The meta-analysis of the SMD in change in continuous measures of physical activity (e.g., minutes/week, kcal/kg/day, steps/day) showed a small but statistically significant association between physical activity interventions (with or without healthful diet messages) and an increase in physical activity levels compared with controls at 6 to 12 months of followup (SMD, 0.20 [95% CI, 0.14 to 0.26]; k=46; n=16,948; I^2^=60.2%) (Figure 18). Meta-regression revealed no evidence of effect modification based on study quality, intervention intensity, intervention focus (physical activity only vs. physical activity and healthful diet), mean age, or link to primary care. In addition, there was no evidence that the effectiveness varied by intensity or that the effects differed between the subgroup of interventions focused only on increasing physical activity (SMD, 0.23 [95% CI, 0.16 to 0.31]; k=34; n=12,588; I^2^=58.9%) versus those that focused on both physical activity and healthful diet goals (SMD, 0.11 [95% CI, 0.02 to 0.20); k=12; n=4,360; I^2^=51.0%) (p=0.09).

Figure 18 Pooled Analysis of Change in Physical Activity (Standardized Mean Difference) in Physical Activity Interventions (With or Without Healthful Diet) Compared With Controls, by Intervention Intensity

Abbreviations: AUS=Australia; BEL=Belgium; BL=baseline; CAN=Canada; CG=control group; CI=confidence interval; DEU=Germany; DNK=Denmark; ESP=Spain; EUR7=7 European countries; FIN=Finland; GBR=United Kingdom; HD=healthful diet; HRV=Croatia; IG=intervention group; Int=intervention; ITA=Italy; JPN=Japan; NLD=Netherlands; NZL=New Zealand; PA=physical activity; Pop=population; SMD=standardized mean difference; SWE=Sweden; USA=United States.

This figure is a forest plot of the standardized mean difference in change in physical activity in physical activity interventions (with or without healthful diet) compared with controls, organized by intervention intensity.

There was evidence, however, of an interaction between intervention effectiveness and physical activity outcomes according to whether the sample was selected on the basis of suboptimal behavior (i.e., not meeting physical activity recommendations or a specific threshold of physical activity). The pooled effect size for studies that limited enrollment to participants with suboptimal levels of physical activity (SMD, 0.28 [95% CI, 0.18 to 0.38]; k=24; n=8,211; I^2^=64.4%) was statistically significantly higher than for those that did not limit enrollment based on baseline physical activity levels (SMD, 0.12 [95% CI, 0.05 to 0.19]; k=22; n=8,737; I^2^=44.9%) (meta-regression, p=0.012). Review of the baseline levels of physical activity within each sample confirmed lower levels of baseline physical activity in general among participants selected for low levels of physical activity compared with those not selected on the basis of their baseline levels of physical activity (Appendix F Table 8). In most of the studies in which participants were selected on the basis of suboptimal behavior, participants were well below the recommended levels of physical activity at baseline (from 2.5 to 99 minutes/week), whereas studies in which participants were enrolled regardless of their baseline physical activity levels had higher baseline values (from 257 to 620 minutes/week). All but one of the studies that selected participants with suboptimal baseline physical activity were physical activity–only trials. Most interventions were of medium or low intensity.

To assist with interpretation of our findings, we also conducted an analysis limited to studies that reported minutes per week of physical activity (as opposed to measures such as MET-minutes or scale scores). Among the 27 trials that reported minutes per week of physical activity, this change amounted to approximately 35 additional minutes of physical activity per week for the intervention group compared with the control group (MD, 34.5 minutes/week [95% CI, 22.0 to 47.0]; n=11,289) (Figure 19). Statistical heterogeneity was still substantial within this meta-analysis (I^2^=67.7%), which was likely due to the clinical heterogeneity of the populations and interventions and the specific measurement of physical activity (i.e., total physical activity, moderate- to vigorous-intensity physical activity, and moderate physical activity). There was considerable variation in the level of baseline physical activity across the studies. Physical activity ranged from 2 minutes/week among a sample of Hispanic/Latina women to 621 minutes/week (nearly 1.5 hours/day) among older adults (mean age, 64.5 years) in the Netherlands. Absolute differences between groups at 6 months to 1 year ranged from approximately 14 minutes/week more in favor of the control group to 106 minutes/week in favor of the intervention group.

Figure 19 Pooled Analysis of Change in Physical Activity (Minutes/Week) in Physical Activity Interventions (With or Without Healthful Diet) Compared With Controls, by Intervention Intensity

Abbreviations: AUS=Australia; BEL=Belgium; BL=baseline; CAN=Canada; CG=control group; CI=confidence interval; DNK=Denmark; ESP=Spain; EUR7=7 European countries; FIN=Finland; GBR=United Kingdom; HD=healthful diet; HRV=Croatia; IG=intervention group; Int=intervention; ITA=Italy; JPN=Japan; MD=mean difference; NLD=Netherlands; NZL=New Zealand; PA=physical activity; Pop=population; SWE=Sweden; USA=United States.

This figure is a forest plot of the change in physical activity (minutes/week) in physical activity interventions (with or without healthful diet) compared with controls, organized by intervention intensity.

Thirteen of the 27 trials reported statistically significant benefit of the intervention on minutes per week of physical activity at 6 to 12 months of followup;^83, 98, 103, 111, 112, 132, 152, 153, 155, 161, 166, 186, 214^ nine of these trials were newly identified in our update. For instance, in the trial by Lewis et al,^161^ 448 healthy, sedentary adults (70% white and 87% women) were randomly assigned to either a low-intensity, tailored, print-based physical activity or a minimal contact arm focused on general wellness over 6 months. Greater increases in self-reported physical activity were seen in the print intervention versus control arm at both 6 months (MD, 31.3 minutes/week) and 12 months (MD, 39.1 minutes/week). A few of these studies focused on specific subpopulations for which the prevalence of physical activity is generally low. For example, in the U.S.-based Nā Mikimiki Project by Albright et al,^83^ 311 postpartum women from Honolulu with infants generally around age 6 months were randomized to receive up to 17 tailored telephone counseling calls and access to a “momcentric” Web site focused on increasing physical activity or a standard physical activity Web site over the course of 1 year. Women in the intervention group reported an average increase of 202 minutes/week of moderate- to vigorous-intensity physical activity, whereas women in the control group reported an average increase of 110 minutes/week, up from baseline values of 44 and 46 minutes/week, respectively (MD, 92 minutes/week [95% CI, 64 to 120)].

Nine studies that reported a physical activity outcome were not included in any of the physical activity meta-analyses due to a lack of reporting of detailed results (e.g., no within-group data, no variance) (Appendix F Table 8).^94, 100, 115, 128, 131, 146, 201, 203, 210^ Results of these studies were mixed. Five studies reported no statistically significant effect of the intervention on levels of moderate- to vigorous-intensity physical activity or total physical activity at 6 months to 1 year,^94, 115, 131, 203, 210^ whereas four trials reported beneficial effects of the intervention on at least one physical activity outcome.^100, 128, 146, 201^ For example, one study among sedentary older adults found a statistically significant benefit of a self-help booklet and telephone and email counseling on self-reported walking at 6 months but not on moderate- or vigorous-intensity physical activity.^100^ Conversely, another study among older adults found a benefit of a primary care counseling intervention on vigorous-intensity physical activity but not on walking.^128^

Among the trials that reported a continuous measure of physical activity, 18 trials included more than one active intervention arm of varying intensities, components, modes of delivery, or timing of messages.^81, 103, 108, 115, 131, 135, 143, 152–154, 167, 169, 177, 181, 212, 214, 217, 220^ There was no consistent evidence to suggest that certain intervention characteristics were more favorable than others in increasing participants’ levels of physical activity.

##### Meeting Physical Activity Recommendations

Sixteen trials, seven of good quality, reported the proportion of participants meeting recommended levels of physical activity at 6 months to 1.5 years of followup (Appendix F Table 8).^111, 113, 117, 120, 122, 152, 155, 160, 166, 167, 170, 172, 181, 185, 189, 218^ The definition of meeting physical activity recommendations was generally the same in all of the trials—at least 150 minutes of moderate-intensity physical activity per week. The meta-analysis of all 16 studies showed that participants in the intervention groups had a 32-percent higher odds of meeting physical activity recommendations at 6 to 18 months of followup compared with those in the control group (pooled OR, 1.32 [95% CI, 1.12 to 1.56]; k=16; n=14,899; I^2^=70.3%) (Figure 20), which represents an RR of 1.22 when using a prevalence of 25 percent as the referent, based on the proportion of control group participants meeting recommendations or a number needed to treat of 17 for one additional person to meet physical activity guidelines. Despite nearly all of the trials generally showing higher rates of meeting recommendations among those receiving the intervention compared with those in the control groups, only five trials found a statistically significant benefit.^117, 155, 160, 166, 189^ Across all of the trials, the absolute difference in the percentage of participants meeting physical activity recommendations ranged from −4.1 percentage points (in favor of the control group)^218^ to 19 percentage points (in favor of the intervention group).^155^ When just the 12 trials that focused exclusively on physical activity messages were pooled, the relative association was slightly higher (pooled OR, 1.40 [95% CI, 1.13 to 1.75]; n=8,720). Five trials reported this outcome at multiple time points; there was no pattern across studies in the persistence of effect over time.^117, 122, 160, 166, 167^

Figure 20 Pooled Analysis of Odds of Meeting Physical Activity Recommendations in Physical Activity Interventions (With or Without Healthful Diet) Compared With Controls, by Intervention Intensity

Abbreviations: AUS=Australia; BEL=Belgium; BL=baseline; CAN=Canada; CG=control group; CI=confidence interval; DNK=Denmark; ESP=Spain; FIN=Finland; GBR=United Kingdom; HD=healthful diet; HRV=Croatia; IG=intervention group; Int=intervention; ITA=Italy; JPN=Japan; NLD=Netherlands; NZL=New Zealand; OR=odds ratio; PA=physical activity; Pop=population; SWE=Sweden; USA=United States.

This figure is a forest plot of the odds of meeting physical activity recommendations in physical activity interventions (with or without healthful diet) compared with controls, organized by intervention intensity.

##### Cardiorespiratory Fitness

In addition to physical activity levels, measures of cardiorespiratory fitness were reported in seven trials with eight unique intervention arms. Five interventions focused on increasing physical activity only, while three focused on improving both physical activity and diet (Appendix F Table 8).^72, 98, 122, 135, 154, 167, 207^ Most of the studies reported maximal oxygen capacity (VO_2_max) at baseline and followup (6 months to 2 years) based on maximal or submaximal treadmill or cycle ergometer tests. The effects of the interventions on cardiorespiratory fitness were generally consistent with those seen for self-reported physical activity. Those trials that reported statistically significant benefit of the intervention on self-reported minutes of physical activity per week also reported greater improvement in cardiorespiratory fitness among intervention versus control group participants, although these differences were not statistically significant.^98, 122, 167^ For example, the Colorado Stride trial found a statistically significant beneficial effect of its low-intensity, print-based physical activity intervention on self-reported physical activity (difference of approximately 33 minutes/week between groups) at 1 year. Mean VO_2_max improved slightly more in the intervention group (34.07 to 34.92 mL/kg/minute) than in the control group (33.23 to 33.39 mL/kg/minute), but there was no significant time-by-group interaction (p=0.55).^98^ Three other studies found no appreciable differences between treatment groups in either self-reported physical activity or cardiorespiratory fitness at 1 to 2 years of followup.^72, 154, 207^ In the study by Thompson et al^207^ among women, there was a slight improvement in cardiorespiratory fitness in the control group but not the intervention group at 6 months, 1 year, or 1.5 years, although this difference was reported as not statistically significant (Appendix F Table 8). One other study found a small, statistically significant difference in self-reported physical activity sessions per month and minutes per session for the combined healthful diet and physical activity intervention arm (approximately five more sessions a month) versus the control group at 6 months but reported no difference in cardiorespiratory fitness in any group.^135^

#### Sedentary Behavior

Four trials reported measures of sedentary behavior independent of physical activity behavior.^80, 100, 148, 169^ One of these trials, the good-quality study by Aadahl et al^80^ (n=149), designed its intervention specifically to reduce daily television viewing and minimize sitting time. At 6 months, objectively measured sitting time decreased in the intervention group (from 9.29 to 9.02 hours/day) and increased in the control group (from 9.78 to 9.84 hours/day), but the between-group difference in change (−0.32 hours/day) was not significantly significant (95% CI, −0.87 to 0.24). Changes in self-reported leisure sitting were statistically significantly different (5.3 to 4.4 hours/day and 5.0 to 4.9 hours/day in the intervention and control groups, respectively); the difference in change was −0.81 hours/day (95% CI, −1.36 to −0.27). The trial by Katz et al^148^ that focused on primary care provider training to encourage and facilitate increases in physical activity among primary care patients found no effect of the intervention on sitting time after 6 or 12 months. Likewise, the trial by Marsaux et al^169^ found no difference in change in minutes per week of sedentary time following a tailored Web-based intervention. In contrast, the study by Burke et al^100^ found a statistically significant group-by-time effect on self-reported minutes per week of sitting time when comparing older adults randomized to a home-based self-help diet and physical activity intervention versus a no-intervention control group.

### Reporting Bias

There was no evidence of small-study effects for either dietary or physical activity outcomes based on Egger’s test (for continuous data) or Peters’ test (for percent meeting physical activity recommendations).

## KQ 4 What Adverse Events Are Associated With Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior in Adults?

### Summary of Results

We narrowly looked at the harms of counseling interventions themselves rather than the harms of dietary or physical activity changes. We examined the 88 trials included for KQs 1 to 3 for any reported harms, as defined by the study authors. Generally, the harms of included counseling interventions were sparsely reported and were inconsistently defined, which precluded pooling. Fourteen of the included trials specifically mentioned the occurrence of harms or lack of harms (Table 2).^81, 91, 94, 100, 103, 111, 132, 137, 153, 155, 160, 179, 190, 208^ Across these studies, there were no serious adverse events related to counseling, although we did not hypothesize that these counseling interventions would result in serious harms (i.e., unexpected or unwanted medical attention). Eight trials reported adverse events of any kind or serious adverse events, with the majority reporting no differences between intervention and control participants. Similarly, eight trials reported the incidence of important patient events, including injuries, falls, or adverse cardiovascular events, and found primarily no differences between treatment groups.

### Detailed Results

Five trials (n=4,483) reported adverse events of any kind,^81, 94, 100, 132, 190^ while three trials (n=470) reported serious adverse events or cardiovascular adverse events.^91, 103, 137^ Three of these trials (one healthful diet plus physical activity, one healthful diet only, and one physical activity only) reported “no adverse events”^100, 190^ or “no serious adverse events”;^103^ however, no additional details were provided. There was no consistent evidence of harms of the interventions in the remaining five trials. The medium-intensity PACE-LIFT trial focused on increasing physical activity among adults ages 60 to 75 years and found nearly identical rates of adverse events of any kind (e.g., falls, fractures, injuries, and deterioration in health problems) between treatment groups at 12 months (55% vs. 56%; p=0.90).^132^ Similarly, a brief physical activity counseling trial found no statistically significant difference in self-reported adverse events among participants randomized to the intervention versus usual care; at 2 months, 24 percent of participants reported some adverse effects, such as musculoskeletal pain.^81^ Conversely, another medium-intensity physical activity trial in older adults (mean age, 71.3 years) reported a higher rate of adverse events that were attributed to participation in the trial over 12 months (8 vs. 2 events in the control vs, the intervention group [7% vs. 1.8%], respectively).^94^ A high-intensity diet and physical activity intervention that focused on weight gain prevention among black women who were overweight or had mild obesity reported the occurrence of six “serious” adverse events (2 cases of gynecological surgery, 1 case each of knee replacement, breast abscess, musculoskeletal injury, and cancer diagnosis) in the intervention group over 12 months of followup.^91^ It was unclear, however, if any of these events were related to study participation, and no information was reported for the women receiving usual care. Finally, one diet-focused trial, which included inactive men and women who were overweight or had obesity and above-normal blood pressure, reported that no participants experienced adverse cardiovascular events.^137^

Seven physical activity–only trials (n=3,565) reported the incidence of injuries, fractures, or falls and found primarily no differences between treatment groups.^111, 132, 153, 155, 160, 179, 208^ Three out of four studies that recorded injuries sustained by participants during the course of the trial found no significant difference between those randomized to the physical activity intervention and those randomized to usual care or an attention control in injuries reported over 12 months of followup,^111, 132, 153^ whereas one trial comprised of women ages 40 to 74 years reported significantly more injuries among participants in the intervention group than in the control group over 24 months of followup (19% vs. 14%; p=0.03).^160^ Two trials among older adults reported the incidence of fractures; one reported a single foot fracture in the intervention group (none in the control group)^208^ and the other found no significant difference in fractures between treatment groups (4% vs. 3% in intervention vs. control groups, respectively; p=0.74).^132^ Of the five trials that reported the occurrence of falls during the course of followup, only one trial reported more falls among intervention participants than among those receiving usual care; this was the same trial of women ages 40 to 74 years in which 37 percent of the intervention group versus 29 percent of the control group experienced a fall over 24 months of followup (p<0.001).^160^ The other four trials—two in older adults and two in general, primary care populations—reported no differences in falls between intervention and control participants over 12 months of followup.^111, 132, 155, 179^