# 2 Methods

## Scope of Review

The current review is an update of the 2010 review^40^ and focuses on the effectiveness of behavioral counseling interventions to promote a healthful diet and physical activity and/or reduce sedentary behavior for the primary prevention of CVD among adults without known CVD or those not at high risk for CVD (i.e., with known hypertension, dyslipidemia, or impaired fasting glucose).

## Key Questions and Analytic Framework

We developed an Analytic Framework (Figure 1) and four Key Questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

* High risk of CVD includes adults with hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors.

Abbreviation: CVD=cardiovascular disease.

Figure 1 is the analytic framework that depicts the four Key Questions to be addressed in the systematic review. The figure illustrates how behavioral counseling to improve diet, increase physical activity, and reduce sedentary behavior may result in improved health outcomes including cardiovascular morbidity and mortality, all-cause mortality, and health-related quality of life (KQ1). Additionally, the figure illustrates how counseling to promote a healthful diet, increased physical activity, and reduced sedentary time may have an impact on intermediate (KQ2) and behavioral outcomes (KQ3). Further, the figure depicts whether counseling to promote a healthful diet, increased physical activity, and reduced sedentary time are associated with any adverse events (KQ4).

### KQs

1. Do primary care behavioral counseling interventions to improve diet, increase physical activity, and/or reduce sedentary behavior improve health outcomes in adults?
2. Do primary care behavioral counseling interventions to improve diet, increase physical activity, and/or reduce sedentary behavior improve intermediate outcomes associated with CVD in adults?
3. Do primary care behavioral counseling interventions to improve diet, increase physical activity, and/or reduce sedentary behavior improve associated health behaviors in adults?
4. What adverse events are associated with primary care behavioral counseling interventions to improve diet, increase physical activity, and/or reduce sedentary behavior in adults?

## Data Sources and Searches

We designed this review as an extension of two of our prior systematic reviews on behavioral counseling for the primary prevention of CVD. The first was a review of adults not at high risk of CVD and was published in 2010 (encompassing literature through 2009).^40, 63^ The second review focused on studies among high-risk adults and was published in 2014 (encompassing literature through October 2013).^64, 65^ Regardless of the focus on high-risk persons in the 2014 review, our search strategy for that review was designed to encompass all adults regardless of risk level and was identical to the search performed for the original 2010 review. During the search process for the 2014 review, we purposefully coded studies that did not include a high-risk population but that might otherwise be included for evaluation in our updated review. As such, we re-evaluated all of these records as well as the 73 studies included in the 2010 review for potential inclusion. We then searched for new primary published literature from January 2013 through May 25, 2016. We searched the following databases: MEDLINE, PubMed (publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials. We worked with a research librarian to develop our search strategy, which was peer reviewed by a second research librarian (Appendix A). All searches were limited to articles published in the English language. Collectively, the literature searches encompassed literature published from 1966 through May 25, 2016.

Because the scope of this current review was expanded to include sedentary behavior as an independent intervention target and behavioral outcome, the updated search included specific search terms to locate this literature. We also reviewed all of the studies included in a recent systematic review of literature published through October 2013 on the effectiveness of physical activity and sedentary behavior interventions in reducing sedentary time in adults.^66^

In addition to these database searches, we searched ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform (www.who.int/ictrp) for ongoing trials through January 2016. We also examined the reference lists of previously published reviews, meta-analyses, and primary studies to identify any potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-content alerts, such as those produced by the USPSTF Scientific Resource Center LitWatch activity.^67^ We managed the literature search results using version X7 of EndNote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

We developed specific inclusion criteria to guide our study selection (Appendix A Table 1). For all KQs, we included randomized, controlled trials (RCTs), including cluster randomized trials; nonrandomized, controlled trials; and systematic reviews of trials that evaluated the effectiveness of primary care–relevant interventions focused on improving dietary habits, increasing physical activity, and/or reducing sedentary time with the primary aim of CVD primary prevention. We excluded studies with a primary aim of weight loss or weight management as this evidence is covered by a separate systematic review conducted for the USPSTF.^42^ Similarly, we excluded studies primarily aimed at falls prevention or improving cognitive function rather than CVD prevention. Studies had to report a behavioral outcome (i.e., diet, physical activity, sedentary time), intermediate outcome (e.g., blood pressure, lipid levels, weight), or health outcome (i.e., morbidity, mortality, health-related quality of life [HrQOL]) or report adverse events related to the intervention.

We included studies if they were among adults age 18 years or older without known CVD, diabetes, or CVD risk factors. The evidence on CVD prevention among adults with known cardiovascular risk factors is covered by a separate systematic review.^64, 65^ As such, we excluded studies that 1) targeted persons with known CVD, hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors; 2) targeted persons categorized as high risk based on a cardiovascular risk assessment tool; or 3) generically stated that participants must have one or more CVD risk factors to be included. We included studies with persons that may be at elevated risk for CVD based on factors such as age, race/ethnicity, family history of CVD, overweight or obesity, high-normal blood pressure (i.e., systolic blood pressure [SBP] of 120 to 139 mm Hg or diastolic blood pressure [DBP] of 80 to 89 mm Hg), or history of gestational diabetes. We also included studies among unselected samples (e.g., a general population, recruited on the basis of age or sex only) or samples that were selected because of suboptimal behavior (e.g., did not meet national physical activity guidelines). Within these samples, we examined the baseline characteristics to determine whether a sample could be considered high risk based on mean baseline values or the proportion of participants taking medications for a CVD risk factor (e.g., antihypertensive agents, statins, or hypoglycemic agents) and excluded studies that generally indicated a high-risk population. We also excluded studies of persons with other known chronic diseases, such as cancer (including studies targeting cancer survivors) or severe mental illness, as well as pregnant women.

We included interventions that were conducted in or recruited from primary care or a health care system or that we judged could feasibly be implemented in or referred from primary care. For example, we included studies relying on virtual-, computer-, or telephone-based programs or those that exclusively used print or mailed materials, as we judged these all to be potentially feasible for a primary care office or a large health system to implement. We excluded studies that took place exclusively in or in conjunction with worksites, churches, or other settings that are not generalizable to primary care given pre-existing social ties that are not easily reproducible in primary care. Behavioral counseling was broadly defined to include interventions such as counseling or education that included but was not limited to assessment with feedback, motivational interviewing, advice, collaborative goal-setting, and exercise prescriptions. Interventions could be delivered in various modes, including in person, with print materials, or by telephone or computer and could be delivered by a number of potential interventionists, such as physicians, nurses, exercise specialists, dietitians, nutritionists, or behavioral health specialists. We excluded interventions focused on supervised exercise or controlled diets as well as those that focused on stress management techniques, such as meditation or yoga. We included only studies that included the following controls: no intervention (e.g., wait list or usual care), minimal intervention (e.g., usual care limited to ≤15 minutes of contact or generic brochures), or attention controls (e.g., similar format and intensity but different content). We excluded studies that evaluated the comparative effectiveness of two active interventions without the addition of a true control group. For the greatest applicability to U.S. primary care practice, we included only studies conducted in developed countries, as defined by “very high” development according to the 2014 United Nations Human Development Index.^68^ Finally, due to resource constraints, we included only studies that published their results in English.

On the basis of these inclusion criteria, one investigator re-evaluated the 73 studies included in our original 2010 review for potential inclusion; studies proposed for exclusion were reviewed by a second investigator, and any disagreements were reconciled through consensus. For the new body of evidence, two reviewers independently reviewed titles and abstracts for potential inclusion, and two reviewers reviewed the full-text articles. Discrepancies were resolved by discussion and third party consultation as needed.

## Quality Assessment and Data Abstraction

For the new literature, two reviewers applied USPSTF design-specific criteria (Appendix A Table 2)^67^ to assess the methodological quality of all eligible studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed. Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study and followup was ≥80%), whereas fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Studies rated as poor quality had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%); differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, and questionable validity of randomization and allocation concealment procedures). Studies rated as poor quality were excluded from the review. As the quality assessment was an update of our own work, we did not repeat critical appraisal of the original studies through full dual-quality rating; rather, we confirmed the quality rating during data abstraction. In one case^69^ where we questioned the original quality rating, we re-rated the quality of the study through dual review. This one study was subsequently excluded for poor quality given serious concerns about an imbalance between treatment groups at baseline (nonrandomized trial in which intervention and control groups were selected based on different criteria) and lack of reporting on differential attrition and handling of missing data.

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in Microsoft Access® 2010 (Microsoft, Redmond, WA). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results. For intervention characteristics, we abstracted detailed information about specific components: duration, number, and length of sessions; group or one-on-one delivery; mode of delivery (i.e., in person, telephone, electronic, or print); providers and provider training; and setting. We used methods consistent with the previous reviews on this topic to estimate and categorize the intensity of each intervention. To calculate the total intensity of an intervention, we multiplied the number of sessions by the length of the respective sessions and estimated the total number of minutes. For example, a 12-month intervention consisting of eight 1-hour group sessions would have been calculated as 8 × 60 = 480 minutes. We categorized an intervention as low intensity if the number of minutes was estimated to be 30 or fewer, medium intensity if the number of minutes was 31 to 360, and high intensity if the number of minutes was greater than 360. Interventions that consisted of only print materials were categorized as low intensity. We abstracted the number of sessions and length of sessions according to what was planned (and not necessarily implemented). When reported, we abstracted actual adherence or implementation of the intervention and documented that as well. If a study did not report the length of sessions, we estimated a session described as “brief” to be 15 minutes, 5 minutes for telephone sessions, 30 minutes for individual face-to-face sessions or Web-based sessions that were not described as “brief”, and 60 minutes for group sessions. Mailings and print materials were not included in the estimated number of sessions or session length. If the intervention consisted of only mailings or print materials, it was categorized as low intensity (i.e., <30 minutes). We noted the theoretical basis of the intervention where reported and used the description of the intervention to judge the specific behavior change techniques that were used (e.g., goals and planning, feedback and monitoring, self-belief) according to the taxonomy of Michie et al^70^ for behavior change techniques.

## Data Synthesis and Analysis

We synthesized data separately for each KQ. The data on health outcomes (KQ 1) and adverse events (KQ 4) did not allow for quantitative pooling due to the limited number of contributing studies and the variability in outcomes measured, so we summarized those data in tables and narratively. For intermediate health outcomes (KQ 2) and behavioral outcomes (KQ 3), we ran random effects meta-analyses using the method of DerSimonian and Laird to calculate the pooled differences in mean changes (for continuous data) and pooled odds ratio (OR) (for binary data).^71^ Details of our data analysis methods are included in Appendix B. Briefly, we used the between-group differences for each outcome as reported by each respective study and favored adjusted over unadjusted effect estimates. If a between-group effect estimate and variance were not provided, we calculated a crude effect estimate. Within each study, we chose 52-week (1-year) outcome data if available; if they were not available we chose the time point closest to 52 weeks, and favored 78 weeks over 26 weeks. We presented the results of other time points in tabular format. For intermediate outcomes, we conducted sensitivity analyses in which we removed the one study^72^ that reported outcomes at 104 weeks (2 years) to investigate whether the longer followup altered the effect estimate. The pooled result, including precision of the estimate, was nearly identical when this study was removed. Thus, we present the results with this study included but report followup generally as 6 to 12 months. If a trial had more than one active intervention arm, we plotted the most intensive arm or the arm that was the most similar with other interventions included in the analysis.

We examined statistical heterogeneity among the pooled studies using standard chi-squared tests and estimated the proportion of total variability in point estimates using the I^2^ statistic.^73^ We applied the Cochrane Collaboration’s rules of thumb for interpreting heterogeneity: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent moderate heterogeneity, 50 to 90 percent substantial heterogeneity, and more than 75 percent considerable heterogeneity.^74^ We ran sensitivity analyses for selected intermediate outcomes (e.g., SBP, DBP, total cholesterol) using a restricted maximum likelihood model with the Knapp-Hartung modification (using the metareg command in version 13.1 of Stata [StataCorp, College Station, TX]), which is a more conservative approach when there is substantial heterogeneity or the number of studies is small.^75^ All statistically significant results remained within the restricted maximum likelihood model, so we show results using the method of DerSimonian and Laird.^71^ In addition, we generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and ran the Egger’s or Peters’ test to assess the statistical significance of imbalance in study size as well as findings that suggest a pattern.^76, 77^

We used visual displays and tables grouped and sorted by potentially important characteristics to investigate whether variability among the results was associated with any prespecified study, population, or intervention characteristics. Specifically, we examined study quality (good vs. fair), link to primary care (conducted in or recruited from primary care vs. not), population at elevated cardiovascular risk (yes vs. no), mean age, baseline mean BMI, intervention focus (healthful diet only, physical activity only, healthful diet and physical activity), intervention intensity (as continuous minutes; high vs. medium and low intensity), intervention duration (as continuous weeks), number of intervention sessions, and group sessions (yes vs. no). On the basis of this initial assessment, we used meta-regression to examine whether the effects were different in specific subgroups or by specific variables, namely study quality, link to primary care, intervention intensity, and intervention duration. There was some evidence that intervention intensity was correlated with the effect estimates; therefore, we stratified the studies according to their intensity category (high, medium, or low) and sorted studies within these groups by intervention focus.

Stata was applied for all quantitative analyses.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^78^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation Working Group.^79^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., whether the evidence links the interventions directly to a health outcome). We supplemented the four domains with the additional domain of dose-response association given our a priori hypothesis that larger effects may be seen with greater intensity (or exposure) of interventions. Evidence of a dose-response association either across or within studies may warrant increasing the overall strength of evidence.

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan was posted on the USPSTF Web site for public comment from February 19 to March 18, 2015. The USPSTF received comments from 27 individuals and organizations, with some comments reflecting the input of many individuals. We made two changes to the research plan based on these comments. The first was to include reduction of sedentary behavior, independently of physical activity, as an intervention target and behavioral outcome. The second was to explicitly acknowledge the inclusion of studies among persons who are overweight or have obesity and who do not have CVD risk factors. Other minor changes and clarifying text was added as appropriate. A final research plan was posted on the USPSTF Web site on May 14, 2015. This full draft report was shared with invited expert reviewers and federal partners. We compiled and addressed (where appropriate) the comments received from these invited experts. Additionally, a draft of the full report was posted for public comment on the USPSTF Web site from November 29, 2016 through January 2, 2017. A few comments were received during this public comment period; no changes were made to the report based on these comments.

## USPSTF Involvement

We worked with three USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. The Agency for Healthcare Research and Quality funded this review under a contract to support the work of the USPSTF. An Agency Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.