# 1 Introduction

## Purpose

The U.S. Preventive Services Task Force (USPSTF) requested an updated evidence report on primary care–relevant behavioral counseling interventions to promote healthful diet and physical activity for the primary prevention of cardiovascular disease (CVD) in adults without known CVD or CVD risk factors (i.e., hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors). This report will be used by the USPSTF to update its 2012 recommendation.^1^

## Condition Definition

### Healthful Diet

A healthful eating pattern is comprised of foods and beverages in quantities, proportions, or combinations that assist persons in achieving and maintaining a healthy weight, reducing the risk of chronic disease, and promoting overall health and well-being.^2, 3^ For the purposes of this review, we included any dietary counseling that focused on improving dietary patterns, consuming more of certain foods and nutrients (e.g., fruits, vegetables, whole grains, fat-free and low-fat dairy, lean proteins), and consuming less foods with sodium, saturated fat, trans fat, cholesterol, added sugar, or refined grains. This guidance is generally consistent with major dietary recommendations, including the “2015–2020 Dietary Guidelines for Americans.”^2^

### Physical Activity

Physical activity is generally defined as any physical movement produced by the contraction of skeletal muscle that leads to an increase in energy expenditure above being at rest.^4, 5^ Prominent national and international guideline bodies recommend that adults age 18 years or older engage in at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity physical activity, or an equivalent combination of moderate- and vigorous-intensity physical activity per week, as well as strengthening activities at least twice per week.^5, 6^

### Sedentary Behavior

Sedentary behaviors are those that involve sitting and require a low level of energy expenditure (1.0 to 1.5 metabolic equivalents of task [METs]), such as watching television, using a computer, playing an electronic game, and sitting in an automobile.^7^ Sedentary behavior is not simply the absence of physical activity; rather, it is a unique set of behaviors. There are currently no specific U.S.-based recommendations for decreasing sedentary time. In addition to their physical activity guidelines, the governments of Australia and the United Kingdom recommend minimizing the amount of time spent in prolonged sitting and breaking up long periods of sitting as often as possible.^8,9^

## Burden and Prevalence of CVD and Risk Factors

Diseases associated with modifiable risk factors are the primary cause of morbidity and mortality in the United States.^10^ CVD is the chief contributor to this trend and remains the leading cause of death for men and women in the United States, despite the overall reductions in death from coronary heart disease and stroke over the last decade.^11, 12^ In 2013, the overall mortality rate associated with CVD was 222.9 deaths per 100,000 persons, or more than 2,200 deaths each day.^12^ Treatment of CVD-related morbidity represents a significant burden to the U.S. health care system; in 2010, the estimated direct and indirect costs of CVD were approximately $444 billion, and the direct and indirect costs of high blood pressure alone were $93.5 billion.^13^

The American Heart Association’s concept of “cardiovascular health” is characterized by seven health behaviors and measures, each of which is known to substantially reduce the risk of CVD: normal blood pressure, cholesterol, and fasting glucose levels; normal body weight; healthy dietary pattern; sufficient physical activity; and not smoking.^12^ Based on 2011–2012 National Health and Nutrition Examination Survey (NHANES) data, only about 13 percent of U.S. adults met five measures of ideal cardiovascular health, 5 percent met six criteria, and almost none met all seven criteria. The prevalence of cardiovascular health across these measures varied considerably; among adults age 50 years or older, 1.8 percent met criteria for an ideal dietary pattern, 19.6 percent had a blood pressure level of less than 120/80 mm Hg, 24.2 percent had a total cholesterol level of less than 200 mg/dL, 26.7 percent had a body mass index (BMI) less than 25 kg/m^2^, 35.1 percent had a fasting glucose level of less than 100 mg/dL, 37.1 percent got at least 150 minutes per week of moderate physical activity or at least 75 minutes of vigorous physical activity, and 82.1 percent were never smokers or quit a year or more ago. The proportion of adults meeting the ideal level for each of these measures was generally higher among those ages 20 to 49 years than among older adults, with the exception of smoking (74.5% vs. 82.1% were never smokers or quit a year or more ago) and healthful diet (1.3% vs. 1.8%) (Table 1).^12^ In addition to these risk factors, a greater amount of sedentary behavior—independent of regular moderate- to vigorous-intensity physical activity—is associated with higher cardiovascular morbidity and mortality.^14–16^ Current estimates based on NHANES objective measures indicate that adults spend approximately 8 hours per day of approximately 15 waking hours engaged in sedentary behavior.^17^

Table 1 Prevalence Estimates of Ideal Cardiovascular Health for Each of the Seven Metrics of Cardiovascular Health in the AHA 2020 Goals Among U.S. Adults

Measure | Definition of ideal cardiovascular health | Prevalence among adults ages 20–49 years, % | Prevalence among adults age ≥50 years, %
Current smoking | Never or quit >12 months ago | 74.5 | 82.1
BMI | <25 kg/m^2^ | 34.6 | 26.7
Physical activity | ≥150 min/wk moderate-intensity or ≥75 min/wk vigorous-intensity | 49.3 | 37.1
Healthy diet score | AHA Diet Score of 4 to 5^*^ | 1.3 | 1.8
Total cholesterol | <200 mg/dL | 61.1 | 24.2
Blood pressure | <120/<80 mm Hg | 57.2 | 19.6
Fasting plasma glucose | <100 mg/dL | 64.6 | 35.1

* Meeting 4 to 5 of the following dietary targets: ≥4.5 cups/day fruits and vegetables, ≥2 3.5-oz servings/wk fish and shellfish, ≤1,500 mg/day sodium, ≤36 oz/wk sugar-sweetened beverages, ≥3 1-oz servings/day whole grains.

Abbreviations: AHA=American Heart Association; BMI=body mass index; min=minute; wk=week.

Adapted from Mozaffarian, 2016.^12^

In this review, “known CVD risk factors” specifically refers to known hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors. Although being overweight or having obesity is associated with higher CVD risk,^18, 19^ in this review, it was not used as a criterion for high CVD risk given the high prevalence in the U.S. population^20^ and because it is not included in CVD risk assessment models (e.g., Framingham,^21–23^ American Heart Association/American College of Cardiology pooled cohort equations^24, 25^). Likewise, although poor dietary patterns, low levels of physical activity, and high levels of sedentary behavior are associated with increased CVD risk, participants selected based on these factors were included in this review. Due to the high prevalence of these behaviors, and the high prevalence of being overweight or having obesity, we considered adults with these characteristics to be part of a generally unselected population as opposed to being selected for counseling based on high CVD risk.

Cardiovascular risk factors and the burden of CVD are not equally distributed across adults in the United States. Specific subpopulations that experience a higher prevalence of CVD risk factors and rates of avoidable death from CVD include older adults, racial/ethnic minority groups, and persons of lower socioeconomic status.^12, 26–28^ Additionally, CVD develops about 7 to 10 years earlier in men than in women, with men experiencing the first myocardial infarction (MI) at an average age of 65.1 years and women at 72.0 years.^12^ Of note, rates of controlled blood pressure and cholesterol are considerably lower among older adults (Table 1).^12^

Hispanic and black adults are less likely than white adults and other racial/ethnic groups to have measures of cardiovascular health at ideal levels. Based on 2011–2012 NHANES data, 19.6 percent of white adults age 20 years or older met five or more criteria for ideal cardiovascular health compared with only 14.4 percent of Hispanic and 10.5 percent of black adults age 20 years or older.^12^ These disparities begin early in the life course, with racial/ethnic differences in cardiovascular health measures beginning to appear in childhood.^12^

Complex health behaviors, such as healthful diet, physical activity, and sedentary behavior also vary by important subpopulations. Persons of lower socioeconomic status or those with lower educational attainment tend to be less active, eat fewer fruits and vegetables, and eat fewer foods rich in dietary fiber compared with persons in a higher socioeconomic position or with higher educational attainment.^29, 30^ Nonwhite adults tend to be less active than white adults and consume fewer servings of fruits and vegetables.^30^ Physical activity rates are lower in older persons and women than in younger persons and men.^30^ Moreover, older adults and women spend more of their waking time engaged in sedentary behaviors than do their younger and male counterparts, whereas Mexican American adults are significantly less sedentary than adults from other racial/ethnic groups.^17^

Commonly cited barriers to healthful eating include the cost of healthful foods, lack of accessible and accurate information on what constitutes a healthful diet, poor accessibility to affordable healthful foods, time constraints due to work and family demands, and sociocultural factors (e.g., family or cultural food norms, family resistance, and lack of support).^31–34^ Major barriers to physical activity include time constraints due to work and family demands; high cost of exercise facilities, exercise equipment, and sports teams; existence of physical ailments or chronic conditions; poor access to facilities; and unsafe or unsupportive environments.^32, 35–37^ Psychosocial barriers to physical activity include lack of social support for exercise, low self-efficacy for maintaining an exercise program, anxiety about unfamiliar settings for exercise, poor body image, and fatigue.^32, 36, 37^ Additionally, environmental barriers such as the nonavailability of healthy eating establishments or grocery stores, parks, sidewalks, bicycle trails, or safe and pleasant walking paths close to home or the workplace; traffic; the availability of public transportation; crime; and pollution may affect individuals’ perceived or real ability to be more active and adopt healthful eating behaviors.^38, 39^

## Behavioral Counseling Interventions for CVD Primary Prevention

Behavioral interventions to improve diet and physical activity encompass a wide range of strategies that may be available within, feasible for, or referable from primary care. These interventions can take different formats, including brief counseling by a primary care provider, with or without accompanying materials or followup counseling; mailed, print-based interventions with tailored feedback; individual or group counseling; telephone counseling with no face-to-face contact; or computer-based interventions, including Web-based sessions, email, or mobile technology. Behavioral counseling interventions can be delivered by a primary care provider, health educator or behavioral health specialist, nutritionist or dietitian, exercise specialist, or “coaches.” Behavior change techniques employed in these interventions can include a broad range of activities, including goal-setting and planning, monitoring and feedback through food and activity logs or pedometers, increasing efficacy and motivation for behavior change (including using motivational interviewing), addressing barriers to change, social support, and general education and advice regarding the benefits of healthy eating or physical activity.^40^

Other interventions for CVD prevention include tobacco cessation, weight loss, aspirin use, and screening for and treatment of high or abnormal levels of blood pressure, cholesterol, and glucose. These interventions are the focus of other reports commissioned by the USPSTF.^41–46^

## Recommendations From Other Groups on Healthful Diet and Physical Activity Counseling

The American Academy of Family Physicians fully adopted the specific recommendations of the USPSTF to selectively counsel patients not at risk for CVD (2012) and to offer or refer adults who are overweight or have obesity and have additional CVD risk factors to intensive behavioral counseling interventions to promote a healthful diet and physical activity.^47^ The American Heart Association (2013), American College of Cardiology (2013), and American College of Preventive Medicine (2006) recommend that clinicians provide nutritional assessment and physical activity counseling to their adult patients.^48, 49^ The “Exercise Is Medicine” initiative, which was developed by the American College of Sports Medicine and American Medical Association^50^ and is endorsed by the American Heart Association,^51^ calls for health care providers to review and assess every patient’s physical activity level (e.g., physical activity as a vital sign), with office visits concluding with an exercise prescription or referral to a qualified health and fitness professional for further counseling. The Community Preventive Services Task Force (2001) recommends implementing behavioral and social interventions such as individually-adapted health behavior change programs and social support interventions in community settings to increase physical activity.^52^ Through its Healthy People 2020 objectives, the U.S. Department of Health and Human Services also encourages health care providers to counsel patients on nutrition, diet, and physical activity.^53^

## Current Clinical Practice in the United States

In 2012 in the United States, 61.4 percent of preventive care visits were made to office-based physicians per 100 persons, and 58.2 percent of those visits were made to primary care physicians.^54^ Although patients perceive family doctors as one of the most reliable sources for health and medical information,^55^ and specifically for food and nutrition advice,^56^ few adults report receiving any advice on diet or exercise. In a 2000 survey of U.S. adults, only 21.3 and 24.5 percent of respondents reported receiving advice by a physician in the past year to modify their diet or exercise, respectively.^57^ There are no updated data for dietary counseling, but the percentage of patients who had been seen by a health professional in the previous year and were advised to begin or continue physical activity rose from 22.6 percent in 2001 to 36.6 percent in 2012.^58^ A majority (70% to 97%) of physicians endorse physical activity or lifestyle counseling as important to very important, and most report that they consider it their role to provide such counseling.^59^ Frequently cited barriers to physical activity counseling by primary care providers include the lack of time, knowledge, or training about physical activity counseling, or lack of success with changing patients’ behaviors.^59^

## Previous USPSTF Recommendations

In 2012, the USPSTF concluded with moderate certainty that in a primary care setting, medium- or high-intensity behavioral counseling interventions to promote a healthful diet and physical activity have a small net benefit for adults without known CVD risk factors.^1^ Therefore, it issued a C recommendation, meaning that clinicians may choose to selectively counsel patients rather than incorporate counseling into the care of all adults in the general population. The body of evidence related to this recommendation represented generally unselected adults who were not targeted for counseling based on their risk for CVD (i.e., having hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors).

In 2014, the USPSTF issued a separate recommendation regarding behavioral counseling interventions to promote healthful diet and physical activity in adults with known CVD risk factors.^60^ It recommended that clinicians offer intensive behavioral counseling interventions to adults who are overweight or have obesity and who have additional CVD risk factors, or refer these patients to such interventions (B recommendation). The evidence review to support this recommendation included studies in which participants were selected on the basis of their CVD risk, including those with hypertension, dyslipidemia, impaired fasting glucose, or a combination of these factors. Although that recommendation is specifically for adults who are overweight or have obesity and who have additional CVD risk factors, the evidence review was not limited to such adults. The recommendation specified this population because all but two included studies were among adults who were overweight or had obesity.

Two other USPSTF recommendations relate to the current update. In 2015, the USPSTF recommended screening for abnormal blood glucose as part of cardiovascular risk assessment in adults ages 40 to 70 years who are overweight or have obesity and offering or referring patients with abnormal blood glucose to intensive behavioral counseling interventions to promote a healthful diet and physical activity (B recommendation).^61^ Similarly, in 2012, the USPSTF recommended screening all adults for obesity and offering or referring patients with a BMI of 30 kg/m^2^ or higher to intensive, multicomponent behavioral interventions (B recommendation).^62^