# Appendix F Evidence Tables

Appendix F Table 1 Cardiovascular Disease Health Outcomes

Appendix F Table 2 Pooled Results of Intermediate Outcomes for All Interventions and by Intervention Focus

Appendix F Table 3 Blood Pressure Outcomes

Appendix F Table 4 Lipid Outcomes

Appendix F Table 5 Glucose Outcomes

Appendix F Table 6 Adiposity Outcomes

Appendix F Table 7 Dietary Outcomes

Appendix F Table 8 Physical Activity Outcomes