# Appendix E Intervention Details

Appendix E Table 1 Intervention Details