# Appendix D Excluded Studies

Reason for Exclusion
E1. | Study aim: not focused on cardiovascular disease primary prevention
E2a. | Setting: Not conducted in ‘very high’ HDI country
E2b. | Setting: Not conducted in, recruited from, or feasible for primary care or a health care system
^*^E3a. | Population: Adults at high-risk for CVD
E3b. | Population: Adults with known CVD or diabetes mellitus
E3c. | Population: Adults with other known chronic disease (e.g., cancer, chronic kidney disease, severe mental illness)
E3d. | Population: Other excluded population (i.e., children and adolescents, parents, pregnant women, institutionalized adults)
E4. | Outcomes: No relevant outcomes
E5a. | Interventions: Intervention out-of-scope
E5b. | Interventions: Stress reduction-focused intervention (e.g., Yoga, Tai Chi)
E6a. | Study design: Not RCT, CCT for KQ1–3; not RCT, CCT, large comparative cohort or case-control or event monitoring study for KQ4
E6b. | Study design: Less than 6 months f/u (for KQ1–3)
E6c. | Study design: Not an included comparator/comparative effectiveness
E7. | Publication date: primary results published prior to 1990
E8. | Language: Publication not in English
E9. | Study quality: Poor quality rating

* Assigned at abstract and full-text phase.

Abbreviations: CCT=controlled clinical trial; CVD=cardiovascular disease; f/u=follow-up; E=exclude; HDI=human development index; KQ=key question; RCT=randomized, controlled trial.

1 Ackermann RT, Liss DT, Finch E, . A randomized comparative effectiveness trial of a primary care-community linkage for preventing type 2 diabetes. J Gen Intern Med. 2015;30:S88–s9. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
2 Admiraal WM, Vlaar EM, Nierkens V, . Intensive lifestyle intervention in general practice to prevent type 2 diabetes among 18 to 60-year-old South Asians: 1-year effects on the weight status and metabolic profile of participants in a randomized controlled trial. PloS One. 2013;8(7):e68605. PMID: 23894322. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.23894322
3 Aggarwal B, Liao M, Allegrante JP, . Low social support level is associated with non-adherence to diet at 1 year in the Family Intervention Trial for Heart Health (FIT Heart). J Nutr Educ Behav. 2010;42(6):380–8. PMID: 20696617. KQ1E4, KQ2E4, KQ3E4, KQ4E4.20696617
4 Aggarwal B, Liao M, Mosca L. Predictors of physical activity at 1 year in a randomized controlled trial of family members of patients with cardiovascular disease. J Cardiovasc Nurs. 2010;25(6):444–9. PMID: 20856131. KQ1E4, KQ2E4, KQ3E4, KQ4E4.20856131
5 Aguiar E, Morgan P, Collins C, . Improvements in weight, HbA1C and fitness following lifestyle intervention: the PULSE trial for type 2 diabetes prevention in men. J Sci Med Sport. 2014;18:e68. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
6 Aguiar EJ, Morgan PJ, Collins CE, . The PULSE (Prevention Using LifeStyle Education) trial protocol: a randomised controlled trial of a type 2 diabetes prevention programme for men. Contemp Clin Trials. 2014;39(1):132–44. PMID: 25092484. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25092484
7 Albert CM, Mittleman MA, Chae CU, . Triggering of sudden death from cardiac causes by vigorous exertion. N Engl J Med. 2000;343(19):1355–61. PMID: 11070099. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.11070099
8 Albright CL, Saiki K, Steffen AD, . What barriers thwart postpartum women’s physical activity goals during a 12-month intervention? A process evaluation of the Nā Mikimiki Project. Women Health. 2015;55(1):1–21. PMID: 25402618. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25402618
9 Andersen E, Burton NW, Anderssen SA. Physical activity levels six months after a randomised controlled physical activity intervention for Pakistani immigrant men living in Norway. Int J Behav Nutr Phys Act. 2012;9:47. PMID: 22537281. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.22537281
10 Andersen E, Hostmark AT, Holme I, . Intervention effects on physical activity and insulin levels in men of Pakistani origin living in Oslo: a randomised controlled trial. J Immigr Minor Health. 2013;15(1):101–10. PMID: 22828963. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.22828963
11 Anderson JW, Garrity TF, Wood CL, . Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations. Am J Int Nutr. 1992;56(5):887–94. PMID: 1329482. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.1329482
12 Andrade LF, Barry D, Litt MD, . Maintaining high activity levels in sedentary adults with a reinforcement-thinning schedule. J Appl Behav Anal. 2014;47(3):523–36. PMID: 25041789. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.25041789
13 Ashe MC, Winters M, Hoppmann CA, . “Not just another walking program”: Everyday Activity Supports You (EASY) model—a randomized pilot study for a parallel randomized controlled trial. Pilot Feasibility Stud. 2015;1(4):1–12. PMID: 27175291. KQ1E9, KQ2E9, KQ3E9, KQ4E9.27175291
14 Ayala GX, Ibarra L, Horton L, . Evidence supporting a promotora-delivered entertainment education intervention for improving mothers’ dietary intake: the Entre Familia: Reflejos de Salud study. J Health Commun. 2015;20(2):165–76. PMID: 25375276. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.25375276
15 Babazono A, Kame C, Ishihara R, . Patient-motivated prevention of lifestyle-related disease in Japan: a randomized, controlled clinical trial. Dis Manage Health Outcomes. 2007;15(2):119–26. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.
16 Bains A, Pakseresht M, Roache C, . Healthy Foods North improves diet among Inuit and Inuvialuit women of childbearing age in Arctic Canada. J Hum Nutr Diet. 2014;27(Suppl 2):175–85. PMID: 23808787. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.23808787
17 Baird J, Jarman M, Lawrence W, . The effect of a behaviour change intervention on the diets and physical activity levels of women attending Sure Start Children’s Centres: results from a complex public health intervention. BMJ Open. 2014;4(7):e005290. PMID: 25031194. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.25031194
18 Baker G, Gray SR, Wright A, . The effect of a pedometer-based community walking intervention “Walking for Wellbeing in the West” on physical activity levels and health outcomes: a 12-week randomized controlled trial. Int J Behav Nutr Phys Act. 2010;7:51. PMID: 20507592. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.20507592
19 Bantum EO, Albright CL, White KK, . Surviving and thriving with cancer using a web-based health behavior change intervention: randomized controlled trial. J Med Internet Res. 2014;16(2):e54. PMID: 24566820. KQ1E1, KQ2E1, KQ3E1, KQ4E1.24566820
20 Baumann S, Toft U, Aadahl M, . The long-term effect of screening and lifestyle counseling on changes in physical activity and diet: the Inter99 Study—a randomized controlled trial. Int J Behav Nutr Phys Act. 2015;12:33. PMID: 25886540. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25886540
21 Bickmore TW, Schulman D, Sidner C. Automated interventions for multiple health behaviors using conversational agents. Patient Educ Couns. 2013;92(2):142–8. PMID: 23763983. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.23763983
22 Biddle SJ, Edwardson CL, Wilmot EG, . A randomised controlled trial to reduce sedentary time in young adults at risk of type 2 diabetes mellitus: Project STAND (Sedentary Time ANd Diabetes). PLoS One. 2015;10(12):e0143398. PMID: 26623654. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26623654
23 Bouchonville M, Armamento-Villareal R, Shah K, . Weight loss, exercise or both and cardiometabolic risk factors in obese older adults: results of a randomized controlled trial. Int J Obes (Lond). 2014;38(3):423–31. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E1.23823329
24 Brekke HK, Bertz F, Rasmussen KM, . Diet and exercise interventions among overweight and obese lactating women: randomized trial of effects on cardiovascular risk factors. PLoS One. 2014;9(2):e88250. PMID: 24516621. KQ1E1, KQ2E1, KQ3E1, KQ4E1.24516621
25 Brekke HK, Sunesson A, Axelsen M, . Attitudes and barriers to dietary advice aimed at reducing risk of type 2 diabetes in first-degree relatives of patients with type 2 diabetes. J Hum Nutr Diet. 2004;17(6):513–21. PMID: 15546428. KQ1E4, KQ2E4, KQ3E4, KQ4E4.15546428
26 Brumby S, Chandrasekara A, Kremer P, . The effect of physical activity on psychological distress, cortisol and obesity: results of the Farming Fit intervention program. BMC Public Health. 2013;13:1018. PMID: 24165391. KQ1E1, KQ2E1, KQ3E1, KQ4E1.24165391
27 Buman MP, Giacobbi PR Jr, Dzierzewski JM, . Peer volunteers improve long-term maintenance of physical activity with older adults: a randomized controlled trial. J Phys Act Health. 2011;8(Suppl 2):S257–S66. PMID: 21918240. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.21918240
28 Cadmus-Bertram LA, Marcus BH, Patterson RE, . Randomized trial of a fitbit-based physical activity intervention for women. Am J Prev Med. 2015;49(3):414–8. PMID: 26071863. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.26071863
29 Campbell K, Foster-Schubert K, Xiao L, . Injuries in sedentary individuals enrolled in a 12-month, randomized, controlled, exercise trial. J Phys Act Health. 2012;9(2):198–207. PMID: 22368219. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.22368219
30 Castro CM, Wilcox S, O’Sullivan P, . An exercise program for women who are caring for relatives with dementia. Psychosom Med. 2002;64(3):458–68. PMID: 12021419. KQ1E1, KQ2E1, KQ3E1, KQ4E4.12021419
31 Cavallo DN, Brown JD, Tate DF, . The role of companionship, esteem, and informational support in explaining physical activity among young women in an online social network intervention. J Behav Med. 2014;37(5):955–66. PMID: 24081454. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.24081454
32 Cavallo DN, Tate DF, Ries AV, . A social media-based physical activity intervention: a randomized controlled trial. Am J Prev Med. 2012;43(5):527–32. PMID: 23079176. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.23079176
33 Chang MW, Nitzke S, Brown R. Design and outcomes of a Mothers In Motion behavioral intervention pilot study. J Nutr Educ Behav. 2010;42(3 Suppl):S11–21. PMID: 20399404. KQ1E4, KQ2E9, KQ3E9, KQ4E4.20399404
34 Chapman J, Armitage CJ. Do techniques that increase fruit intake also increase vegetable intake? Evidence from a comparison of two implementation intention interventions. Appetite. 2012;58(1):28–33. PMID: 22001024. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.22001024
35 Cheung NW, Smith BJ, van der Ploeg HP, . A pilot structured behavioural intervention trial to increase physical activity among women with recent gestational diabetes. Diabetes Res Clin Pract. 2011;92(1):e27–e9. PMID: 21316788. KQ1E4, KQ2E9, KQ3E9, KQ4E4.21316788
36 Cicolini G, Simonetti V, Comparcini D, . Efficacy of a nurse-led email reminder program for cardiovascular prevention risk reduction in hypertensive patients: a randomized controlled trial. Int J Nurs Stud. 2014;51(6):833–43. PMID: 24225325. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24225325
37 Clare L, Nelis SM, Jones IR, . The Agewell trial: a pilot randomised controlled trial of a behaviour change intervention to promote healthy ageing and reduce risk of dementia in later life. BMC Psychiatry. 2015;15:25. PMID: 25880911. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25880911
38 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: a randomized controlled trial. J Appl Gerontol. 2009;28(2):171–94. PMID: 21709757. KQ1E1, KQ2E1, KQ3E1, KQ4E4.21709757
39 Conroy MB, Sward KL, Spadaro KC, . Effectiveness of a physical activity and weight loss intervention for middle-aged women: healthy bodies, healthy hearts randomized trial. J Gen Intern Med. 2015;30(2):207–13. PMID: 25391601. KQ1E1, KQ2E1, KQ3E1, KQ4E1.25391601
40 Costa B, Barrio F, Cabre JJ, . Delaying progression to type 2 diabetes among high-risk Spanish individuals is feasible in real-life primary healthcare settings using intensive lifestyle intervention. Diabetologia. 2012;55(5):1319–28. PMID: 22322921. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.22322921
41 Curtis PJ, Adamson AJ, Mathers JC. Effects on nutrient intake of a family-based intervention to promote increased consumption of low-fat starchy foods through education, cooking skills and personalised goal setting: the Family Food and Health Project. Br J Nutr. 2012;107(12):1833–44. PMID: 22017999. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22017999
42 Dapp U, Anders JA, von Renteln-Kruse W, . A randomized trial of effects of health risk appraisal combined with group sessions or home visits on preventive behaviors in older adults. J Gerontol A Biol Sci Med Sci. 2011;66(5):591–8. PMID: 21350242. KQ1E1, KQ2E1, KQ3E1, KQ4E1.21350242
43 Davies M, Gray LJ, Goldby S, . A community-based primary prevention programme for type 2 diabetes in the UK: a cluster randomised controlled trial. Diabetes. 2015;64:A188. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
44 Davies AK, McGale N, Humphries SE, . Effectiveness of a self-management intervention with personalised genetic and lifestyle-related risk information on coronary heart disease and diabetes-related risk in type 2 diabetes (CoRDia): study protocol for a randomised controlled trial. Trials. 2015;16(547). PMID: 26631181 KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26631181
45 Davis-Lameloise N, Hernan A, Janus ED, . The Melbourne Diabetes Prevention Study (MDPS): study protocol for a randomized controlled trial. Trials. 2013;14:31. PMID: 23369724. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.23369724
46 De Cocker K, Spittaels H, Cardon G, . Web-based, computer-tailored, pedometer-based physical activity advice: development, dissemination through general practice, acceptability, and preliminary efficacy in a randomized controlled trial. J Med Internet Res. 2012;14(2):e53. PMID: 22532102. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.22532102
47 Driehuis F, Barte JC, Ter Bogt NC, . Maintenance of lifestyle changes: 3-year results of the Groningen Overweight and Lifestyle study. Patient Educ Couns. 2012;88(2):249–55. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.22560253
48 Duda JL, Williams GC, Ntoumanis N, . Effects of a standard provision versus an autonomy supportive exercise referral programme on physical activity, quality of life and well-being indicators: a cluster randomised controlled trial. Int J Behav Nutr Phys Act. 2014;11:10. PMID: 24475766. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24475766
49 Duijzer G, Haveman-Nies A, Jansen SC, . SLIMMER: a randomised controlled trial of diabetes prevention in Dutch primary health care: design and methods for process, effect, and economic evaluation. BMC Public Health. 2014;14:602. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24928217
50 Duncan M, Vandelanotte C, Kolt GS, . Effectiveness of a web- and mobile phone-based intervention to promote physical activity and healthy eating in middle-aged males: randomized controlled trial of the ManUp study. J Med Internet Res. 2014;16(6):e136. PMID: 24927299. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24927299
51 Eakin EG, Bull SS, Riley KM, . Resources for health: a primary-care-based diet and physical activity intervention targeting urban Latinos with multiple chronic conditions. Health Psychol. 2007;26(4):392–400. PMID: 17605558. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.17605558
52 Eaton CB, Hartman S, Risica PM, . P119: tailored lifestyle intervention for obese, sedentary patients in primary care: Choose to Lose study. American Heart Association’s Epidemiology and Prevention/Lifestyle and Cardiometabolic Health 2015 Scientific Sessions. 2015;131. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
53 Edelman D, Dolor RJ, Coffman CJ, . Nurse-led behavioral management of diabetes and hypertension in community practices: a randomized trial. J Gen Intern Med. 2015;30(5):626–33. PMID: 25567758. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25567758
54 Edelman D, Oddone EZ, Liebowitz RS, . A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728–34. PMID: 16808774. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.16808774
55 Elley CR, Garrett S, Rose SB, . Cost-effectiveness of exercise on prescription with telephone support among women in general practice over 2 years. Br J Sports Med. 2011;45(15):1223–9. PMID: 21081641. KQ1E4, KQ2E4, KQ3E4, KQ4E4.21081641
56 Emmons KM, Puleo E, Greaney ML, . A randomized comparative effectiveness study of Healthy Directions 2—a multiple risk behavior intervention for primary care. Prev Med. 2014;64:96–102. PMID: 24642140. KQ1E4, KQ2E4, KQ3E4, KQ4E4.24642140
57 Fahs PS, Pribulick M, Williams IC, . Promoting heart health in rural women. J Rural Health. 2013;29(3):248–57. PMID: 23802927. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.23802927
58 Fitzpatrick SL, Bandeen-Roche K, Stevens VJ, . Examining behavioral processes through which lifestyle interventions promote weight loss: results from PREMIER. Obesity (Silver Spring). 2014;22(4):1002–7. PMID: 24124061. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24124061
59 Fitzsimons CF, Baker G, Gray SR, . Does physical activity counselling enhance the effects of a pedometer-based intervention over the long-term: 12-month findings from the Walking for Wellbeing in the West study. BMC Public Health. 2012;12:206. PMID: 22429600. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.22429600
60 Fjeldsoe B, Phongsavan P, Bauman A, . “Get Healthy, Stay Healthy”: protocol for evaluation of a lifestyle intervention delivered by text-message following the Get Healthy Information and Coaching Service. BMC Public Health. 2014;14:112. PMID: 24495781. KQ1E4, KQ2E4, KQ3E4, KQ4E4.24495781
61 Friederichs SA, Oenema A, Bolman C, . Long term effects of self-determination theory and motivational interviewing in a web-based physical activity intervention: randomized controlled trial. Int J Behav Nutr Phys Act. 2015;12(101). PMID: 26283094 KQ1E4, KQ2E4, KQ3E9, KQ4E4.26283094
62 Gabriel KK, Conroy MB, Schmid KK, . The impact of weight and fat mass loss and increased physical activity on physical function in overweight, postmenopausal women: results from the Women on the Move Through Activity and Nutrition study. Menopause. 2011;18(7):759–65. PMID: 21705864. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.21705864
63 Garmendia ML, Dangour AD, Albala C, . Adherence to a physical activity intervention among older adults in a post-transitional middle income country: a quantitative and qualitative analysis. J Nutr Health Aging. 2013;17(5):466–71. PMID: 23636549. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.23636549
64 Gell NM, Wadsworth DD. The use of text messaging to promote physical activity in working women: a randomized controlled trial. J Phys Act Health. 2014. PMID: 25110303. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.25110303
65 Giri S, Thompson PD, Kiernan FJ, . Clinical and angiographic characteristics of exertion-related acute myocardial infarction. JAMA. 1999;282(18):1731–6. PMID: 10568645. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.10568645
66 Golsteijn RH, Peels DA, Evers SM, . Cost-effectiveness and cost-utility of a web-based or print-delivered tailored intervention to promote physical activity among adults aged over fifty: an economic evaluation of the Active Plus intervention. Int J Behav Nutr Phys Act. 2014;11:122. PMID: 25262435. KQ1E4, KQ2E4, KQ3E9, KQ4E4.25262435
67 Golubic R, Wijndaele K, Sharp SJ, . Physical activity, sedentary time and gain in overall and central body fat: 7-year follow-up of the ProActive trial cohort. Int J Obes (Lond). 2015;39(1):142–8. PMID: 24732143. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.24732143
68 Gomez-Huelgas R, Jansen-Chaparro S, Baca-Osorio AJ, . Effects of a long-term lifestyle intervention program with Mediterranean diet and exercise for the management of patients with metabolic syndrome in a primary care setting. Eur J Intern Med. 2015;26(5):317–23. PMID: 25907985. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25907985
69 Gothe NP, Wojcicki TR, Olson EA, . Physical activity levels and patterns in older adults: the influence of a DVD-based exercise program. J Behav Med. 2015;38(1):91–7. PMID: 24966113. KQ1E1, KQ2E1, KQ3E1, KQ4E1.24966113
70 Goyder E, Hind D, Breckon J, . A randomised controlled trial and cost-effectiveness evaluation of “booster” interventions to sustain increases in physical activity in middle-aged adults in deprived urban neighbourhoods. Health Technol Assess. 2014;18(13):1–210. PMID: 24571932. KQ1E6c, KQ2E4, KQ3E6c, KQ4E4.24571932
71 Greaney ML, Riebe D, Ewing GC, . Long-term effects of a stage-based intervention for changing exercise intentions and behavior in older adults. Gerontologist. 2008;48(3):358–67. PMID: 18591361. KQ1E1, KQ2E1, KQ3E1, KQ4E4.18591361
72 Hageman PA, Pullen CH, Hertzog M, . Effectiveness of tailored lifestyle interventions, using web-based and print-mail, for reducing blood pressure among rural women with prehypertension: main results of the Wellness for Women: DASHing towards Health clinical trial. Int J Behav Nutr Phys Act. 2014;11:148. PMID: 25480461. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25480461
73 Hall PA, Zehr C, Paulitzki J, . Implementation intentions for physical activity behavior in older adult women: an examination of executive function as a moderator of treatment effects. Ann Behav Med. 2014;48(1):130–6. PMID: 24500080. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.24500080
74 Hallqvist J, Moller J, Ahlbom A, . Does heavy physical exertion trigger myocardial infarction? A case-crossover analysis nested in a population-based case-referent study. Am J Epidemiol. 2000;151(5):459–67. PMID: 10707914. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.10707914
75 Hansen AW, Gronbaek M, Helge JW, . Effect of a web-based intervention to promote physical activity and improve health among physically inactive adults: a population-based randomized controlled trial. J Med Internet Res. 2012;14(5):e145. PMID: 23111127. KQ1E4, KQ2E4, KQ3E9, KQ4E4.23111127
76 Hardcastle S, Taylor A, Bailey M, . A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Educ Couns. 2008;70(1):31–9. PMID: 17997263. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.17997263
77 Hasandokht T, Farajzadegan Z, Siadat ZD, . Lifestyle interventions for hypertension treatment among Iranian women in primary health-care settings: results of a randomized controlled trial. J Res Med Sci. 2015;20(1):54–61. PMID: 25767523 KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25767523
78 Helland-Kigen KM, Raberg Kjollesdal MK, Hjellset VT, . Maintenance of changes in food intake and motivation for healthy eating among Norwegian-Pakistani women participating in a culturally adapted intervention. Public Health Nutr. 2013;16(1):113–22. PMID: 22781507. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.22781507
79 Hillier FC, Batterham AM, Nixon CA, . A community-based health promotion intervention using brief negotiation techniques and a pledge on dietary intake, physical activity levels and weight outcomes: lessons learnt from an exploratory trial. Public Health Nutr. 2012;15(8):1446–55. PMID: 22122753. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.22122753
80 Hollis JL, Williams LT, Young MD, . Compliance to step count and vegetable serve recommendations mediates weight gain prevention in mid-age, premenopausal women. Findings of the 40-Something RCT. Appetite. 2014;83:33–41. PMID: 25062965. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25062965
81 Holme I, Retterstol K, Norum KR, . Lifelong benefits on myocardial infarction mortality: 40-year follow-up of the randomized Oslo diet and antismoking study. J Intern Med. 2016;280(2):221–7. PMID: 26924204. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26924204
82 Howard BV, Curb JD, Eaton CB, . Low-fat dietary pattern and lipoprotein risk factors: the Women’s Health Initiative Dietary Modification Trial 1. Am J Clin Nutr. 2010;91(4):860–74. PMID: 20164311. KQ1E4, KQ2E4, KQ3E4, KQ4E4.20164311
83 Imayama I, Alfano CM, Mason CE, . Exercise adherence, cardiopulmonary fitness, and anthropometric changes improve exercise self-efficacy and health-related quality of life. J Phys Act Health. 2013;10(5):676–89. PMID: 23036856. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.23036856
84 Irvine AB, Gelatt VA, Seeley JR, . Web-based intervention to promote physical activity by sedentary older adults: randomized controlled trial. J Med Internet Res. 2013;15(2):e19. PMID: 23470322. KQ1E1, KQ2E1, KQ3E1, KQ4E1.23470322
85 Islam NS, Zanowiak JM, Wyatt LC, . A randomized-controlled, pilot intervention on diabetes prevention and healthy lifestyles in the New York City Korean community. J Community Health. 2013;38(6):1030–41. PMID: 23813322. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.23813322
86 Jacobs N, Hagger MS, Streukens S, . Testing an integrated model of the theory of planned behaviour and self-determination theory for different energy balance-related behaviours and intervention intensities. Br J Health Psychol. 2011;16(Pt 1):113–34. PMID: 21226787. KQ1E4, KQ2E4, KQ3E4, KQ4E4.21226787
87 Jahangiry L, Shojaeizadeh D, Najafi M, . “Red Ruby”: an interactive web-based intervention for lifestyle modification on metabolic syndrome: a study protocol for a randomized controlled trial. BMC Public Health. 2014;14:748. PMID: 25059121. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25059121
88 Johansen KS, Bjorge B, Hjellset VT, . Changes in food habits and motivation for healthy eating among Pakistani women living in Norway: results from the InnvaDiab-DEPLAN study. Public Health Nutr. 2010;13(6):858–67. PMID: 19941691. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.19941691
89 Jørgensen T, Jacobsen RK, Toft U, . Effect of screening and lifestyle counselling on incidence of ischaemic heart disease in general population: Inter99 randomised trial. BMJ. 2014;348:g3617. PMID: 24912589. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24912589
90 Joseph RP, Keller C, Adams MA, . Print versus a culturally-relevant Facebook and text message delivered intervention to promote physical activity in African American women: a randomized pilot trial. BMC Womens Health. 2015;15:30. PMID: 25886945. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.25886945
91 Juul L, Andersen VJ, Arnoldsen J, . Effectiveness of a brief theory-based health promotion intervention among adults at high risk of type 2 diabetes: one-year results from a randomised trial in a community setting. Prim Care Diabetes. 2016;10(2):111–20. PMID: 26259517. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26259517
92 Kandula NR, Dave S, De Chavez PJ, . Translating a heart disease lifestyle intervention into the community: the South Asian Heart Lifestyle Intervention (SAHELI) study; a randomized control trial. BMC Public Health. 2015;15:1064. PMID: 26475629. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26475629
93 Kangasniemi AM, Lappalainen R, Kankaanpaa A, . Towards a physically more active lifestyle based on one’s own values: study design of a randomized controlled trial for physically inactive adults. BMC Public Health. 2013;13:671. PMID: 23866812. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.23866812
94 Kangasniemi AM, Lappalainen R, Kankaanpaa A, . Towards a physically more active lifestyle based on one’s own values: the results of a randomized controlled trial among physically inactive adults. BMC Public Health. 2015;15(1):260. PMID: 25848812. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25848812
95 Keyserling TC, Samuel Hodge CD, Jilcott SB, . Randomized trial of a clinic-based, community-supported, lifestyle intervention to improve physical activity and diet: the North Carolina enhanced WISEWOMAN project. Prev Med. 2008;46(6):499–510. PMID: 18394692. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.18394692
96 Khare MM, Cursio JF, Locklin CA, . Lifestyle intervention and cardiovascular disease risk reduction in low-income Hispanic immigrant women participating in the Illinois WISEWOMAN program. J Community Health. 2014;39(4):737–46. PMID: 24469546. KQ1E4, KQ2E9, KQ3E9, KQ4E4.24469546
97 Khare MM, Carpenter RA, Huber R, . Lifestyle intervention and cardiovascular risk reduction in the Illinois WISEWOMAN Program. J Womens Health (Larchmt). 2012;21(3):294–301. PMID: 22136298. KQ1E4, KQ2E9, KQ3E9, KQ4E4.22136298
98 Kim Y, Pike J, Adams H, . Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50(3):112–7. PMID: 20006642. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.20006642
99 Kimura M, Moriyasu A, Kumagai S, . Community-based intervention to improve dietary habits and promote physical activity among older adults: a cluster randomized trial. BMC Geriatr. 2013;13:8. PMID: 23343312. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.23343312
100 King AC, Baumann K, O’Sullivan P, . Effects of moderate-intensity exercise on physiological, behavioral, and emotional responses to family caregiving: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2002;57(1):M26–M36. PMID: 11773209. KQ1E1, KQ2E1, KQ3E1, KQ4E1.11773209
101 King AC, Bickmore TW, Campero MI, . Employing virtual advisors in preventive care for underserved communities: results from the COMPASS study. J Community Health. 2013;18(12):1449–64. PMID: 23941610. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.23941610
102 King HA, Jeffreys AS, McVay MA, . Spouse health behavior outcomes from a randomized controlled trial of a spouse-assisted lifestyle change intervention to improve patient low-density lipoprotein cholesterol. J Behav Med. 2014;37(6):1102–7. PMID: 24584818. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24584818
103 Knight E, Petrella RJ. Prescribing physical activity for healthy aging: longitudinal follow-up and mixed method analysis of a primary care intervention. Phys Sportsmed. 2014;42(4):30–8. PMID: 25419886. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25419886
104 Ko LK, Campbell MK, Lewis MA, . Information processes mediate the effect of a health communication intervention on fruit and vegetable consumption. J Health Commun. 2011;16(3):282–99. PMID: 21132593. KQ1E4, KQ2E4, KQ3E4, KQ4E4.21132593
105 Kuller LH, Pettee Gabriel KK, Kinzel LS, . The Women on the Move Through Activity and Nutrition (WOMAN) study: final 48-month results. Obesity (Silver Spring). 2012;20(3):636–43. PMID: 21494228. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.21494228
106 Kwon I, Choi S, Mittman B, . Study protocol of “Worth the Walk”: a randomized controlled trial of a stroke risk reduction walking intervention among racial/ethnic minority older adults with hypertension in community senior centers. BMC Neurol. 2015;15:91. PMID: 26072359. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26072359
107 Lane A, Murphy N, Bauman A. An effort to “leverage” the effect of participation in a mass event on physical activity. Health Promot Int. 2015;30(3):542–51. PMID: 24226297. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.24226297
108 Larsen B, Gilmer T, Pekmezi D, . Cost effectiveness of a mail-delivered individually tailored physical activity intervention for Latinas vs. a mailed contact control. Int J Behav Nutr Phys Act. 2015;12:140. PMID: 26559336. KQ1E4, KQ2E4, KQ3E4, KQ4E4.26559336
109 Lefler LL, McSweeney JC, Lensing SY, . 15978: The Lifestyle Physical Activity for sedentary older Women (LPAW) study: primary outcomes from a randomized controlled clinical trial. American Heart Association’s 2015 Scientific Sessions and Resuscitation Science Symposium. 2015. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
110 Lilienthal KR, Pignol AE, Holm JE, . Telephone-based motivational interviewing to promote physical activity and stage of change progression in older adults. J Aging Phys Act. 2014;22(4):527–35. PMID: 24226309. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.24226309
111 Lima ST, Silva Nalin de Souza B, França AK, . Dietary approach to hypertension based on low glycaemic index and principles of DASH (Dietary Approaches to Stop Hypertension): a randomised trial in a primary care service. Br J Nutr. 2013;110(8):1472–9. PMID: 23632203. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.23632203
112 Lombard C, Harrison C, Kozica S, . preventing weight gain in women in rural communities: a cluster randomised controlled trial. PLoS Med. 2016;13(1):e1001941. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E1.26785406
113 Lubans DR, Mundey C, Lubans NJ, . Testing physical activity mediators in an intervention for sedentary older adults. Int J Sport Psychol. 2013;44(3):252–62. PMID: None. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.
114 Lynch BM, Courneya KS, Sethi P, . A randomized controlled trial of a multiple health behavior change intervention delivered to colorectal cancer survivors: effects on sedentary behavior. Cancer. 2014;120(17):2665–72. PMID: 24816611. KQ1E1, KQ2E1, KQ3E1, KQ4E1.24816611
115 Mackey E, Schweitzer A, Hurtado ME, . The feasibility of an e-mail-delivered intervention to improve nutrition and physical activity behaviors in African American college students. J Am Coll Health. 2015;63(2):109–17. PMID: 25611932. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25611932
116 Mancuso CA, Choi TN, Westermann H, . Increasing physical activity in patients with asthma through positive affect and self-affirmation: a randomized trial. Arch Intern Med. 2012;172(4):337–43. PMID: 22269593. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.22269593
117 Mansikkamaki K, Raitanen J, Nygard CH, . Long-term effect of physical activity on menopause-related quality of life: a 4 year follow-up study of a randomized controlled trial. Maturitas. 2015;81(1):139. PMID: None. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.
118 Mansikkamaki K, Raitanen J, Nygard CH, . Long-term effect of physical activity on health-related quality of life among menopausal women: a 4-year follow-up study to a randomised controlled trial. BMJ Open. 2015;5(9):e008232. PMID: 26362664. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.26362664
119 McAuley E, Wojcicki TR, Gothe NP, . Effects of a DVD-delivered exercise intervention on physical function in older adults. J Gerontol A Biol Sci Med Sci. 2013;68(9):1076–82. PMID: 23401566. KQ1E1, KQ2E1, KQ3E1, KQ4E1.23401566
120 McAuley E, Wojcicki TR, White SM, . Physical activity, function, and quality of life: design and methods of the FlexToBa trial. Contemp Clin Trials. 2012;33(1):228–36. PMID: 22024470. KQ1E1, KQ2E1, KQ3E1, KQ4E1.22024470
121 McEvoy CT, Wallace IR, Hamill LL, . Increasing fruit and vegetable intake has no dose-response effect on conventional cardiovascular risk factors in overweight adults at high risk of developing cardiovascular disease. J Nutr. 2015;145(7):1464–71. PMID: 25972532. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25972532
122 McKenzie SH, Jayasinghe UW, Fanaian M, . Analysis of the psychological impact of a vascular risk factor intervention: results from a cluster randomized controlled trial in Australian general practice. BMC Fam Pract. 2013;14:190. PMID: 24330347. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24330347
123 McMurdo ME, Sugden J, Argo I, . Do pedometers increase physical activity in sedentary older women? A randomized controlled trial. J Am Geriatr Soc. 2010;58(11):2099–106. PMID: 21054290. KQ1E1, KQ2E1, KQ3E1, KQ4E1.21054290
124 McVay MA, King HA, Jeffreys AS, . Mechanisms of patient health behavior change in a randomized controlled trial of a spouse-assisted intervention. Psychol Health Med. 2015;20(7):753–66. PMID: 25774698. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25774698
125 Middleton KR. Preventing the freshman 15: the effect of lifestyle intervention on freshman-year weight gain [Dissertation]. 2015. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E1.
126 Middleton KR, Perri MG. A randomized trial investigating the effect of a brief lifestyle intervention on freshman-year weight gain. J Am Coll Health. 2014;62(2):101–9. PMID: 24456512. KQ1E6b, KQ2E6b, KQ3E3a, KQ4E3a.24456512
127 Mittleman MA, Maclure M, Tofler GH, . Triggering of acute myocardial infarction by heavy physical exertion: protection against triggering by regular exertion. N Engl J Med. 1993;329(23):1677–83. PMID: 8232456. KQ1E4, KQ2E4, KQ3E4, KQ4E4.8232456
128 Mochari-Greenberger H, Terry MB, Mosca L. Does stage of change modify the effectiveness of an educational intervention to improve diet among family members of hospitalized cardiovascular disease patients? J Am Diet Assoc. 2010;110(7):1027–35. PMID: 20630159. KQ1E4, KQ2E4, KQ3E4, KQ4E4.20630159
129 Morey MC, Peterson MJ, Pieper CF, . Project LIFE—Learning to Improve Fitness and function in Elders: methods, design, and baseline characteristics of randomized trial. J Rehabil Res Dev. 2008;45(1):31–42. PMID: 18566924. KQ1E1, KQ2E1, KQ3E1, KQ4E4.18566924
130 Morey MC, Peterson MJ, Pieper CF, . The Veterans Learning to Improve Fitness and Function in Elders Study: a randomized trial of primary care-based physical activity counseling for older men. J Am Geriatr Soc. 2009;57(7):1166–74. PMID: 19467149. KQ1E1, KQ2E1, KQ3E1, KQ4E4.19467149
131 Mouton A, Cloes M. Efficacy of a web-based, center-based or combined physical activity intervention among older adults. Health Edu Res. 2015;30(3):422–35. PMID: 25772974. KQ1E4, KQ2E4, KQ3E9, KQ4E4.25772974
132 Mutrie N, Doolin O, Fitzsimons CF, . Increasing older adults’ walking through primary care: results of a pilot randomized controlled trial. Fam Pract. 2012;29(6):633–42. PMID: 22843637. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.22843637
133 Naslund GK, Fredrikson M, Hellenius ML, . Effect of diet and physical exercise intervention programmes on coronary heart disease risk in smoking and non-smoking men in Sweden. J Epidemiol Community Health. 1996;50(2):131–6. PMID: 8762375. KQ1E4, KQ2E4, KQ3E4, KQ4E4.8762375
134 Neville CE, McKinley MC, Draffin CR, . Participating in a fruit and vegetable intervention trial improves longer term fruit and vegetable consumption and barriers to fruit and vegetable consumption: a follow-up of the ADIT study. Int J Behav Nutr Phys Act. 2015;12:158. PMID: 26684653. KQ1E1, KQ2E1, KQ3E1, KQ4E1.26684653
135 Niiranen TJ, Leino K, Puukka P, . Lack of impact of a comprehensive intervention on hypertension in the primary care setting. Am J Hypertens. 2014;27(3):489–96. PMID: 24186848. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24186848
136 Normansell R, Smith J, Victor C, . Numbers are not the whole story: a qualitative exploration of barriers and facilitators to increased physical activity in a primary care based walking intervention. BMC Public Health. 2014;14:1272. PMID: 25511452. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25511452
137 O’Dea A, Tierney M, McGuire BE, . Can the onset of type 2 diabetes be delayed by a group-based lifestyle intervention in women with prediabetes following gestational diabetes mellitus (GDM)? Findings from a randomized control mixed methods trial. J Diabetes Res. 2015;2015:798460. PMID: 26347894. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26347894
138 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29–43. PMID: 11182214. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.11182214
139 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating lifestyle interventions in people with impaired glucose tolerance. Diabetes Res Clin Pract. 2006;72(2):117–27. PMID: 16297488. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.16297488
140 Pace WD, Lanigan AM, Staton EW, . Effectiveness of 2 methods of promoting physical activity, healthy eating, and emotional well-being with the Americans in Motion-Healthy Interventions approach. Ann Fam Med. 2013;11(4):373–80. PMID: 23835824. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.23835824
141 Panunzio MF, Caporizzi R, Antoniciello A, . Randomized, controlled nutrition education trial promotes a Mediterranean diet and improves anthropometric, dietary, and metabolic parameters in adults. Ann Ig. 2011;23(1):13–25. PMID: 21736003. KQ1E4, KQ2E9, KQ3E9, KQ4E4.21736003
142 Papandonatos GD, Williams DM, Jennings EG, . Mediators of physical activity behavior change: findings from a 12-month randomized controlled trial. Health Psychol. 2012;31(4):512–20. PMID: 22149130. KQ1E4, KQ2E4, KQ3E4, KQ4E4.22149130
143 Parekh S, Vandelanotte C, King D, . Improving diet, physical activity and other lifestyle behaviours using computer-tailored advice in general practice: a randomised controlled trial. Int J Behav Nutr Phys Act. 2012;9:108. PMID: 22963354. KQ1E4, KQ2E4, KQ3E4, KQ4E4.22963354
144 Patel A, Keogh JW, Kolt GS, . The long-term effects of a primary care physical activity intervention on mental health in low-active, community-dwelling older adults. Aging Ment Health. 2013;17(6):766–72. PMID: 23547971. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.23547971
145 Peacock OJ, Western MJ, Batterham AM, . Multidimensional individualised Physical ACTivity (Mi-PACT)—a technology-enabled intervention to promote physical activity in primary care: study protocol for a randomised controlled trial. Trials. 2015;16:381. PMID: 26314577. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26314577
146 Peels DA, Bolman C, Golsteijn RH, . Long-term efficacy of a printed or a web-based tailored physical activity intervention among older adults. Int J Behav Nutr Phys Act. 2013;10:104. PMID: 24228862. KQ1E4, KQ2E4, KQ3E9, KQ4E4.24228862
147 Pekmezi DW, Williams DM, Dunsiger S, . Feasibility of using computer-tailored and internet-based interventions to promote physical activity in underserved populations. Telemed J E Health. 2010;16(4):498–503. PMID: 20507203. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.20507203
148 Petrella RJ, Koval JJ, Cunningham DA, . Can primary care doctors prescribe exercise to improve fitness? The Step Test Exercise Prescription (STEP) project. Am J Prev Med. 2003;24(4):316–22. PMID: 12726869. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.12726869
149 Petrella RJ, Lattanzio CN, Shapiro S, . Improving aerobic fitness in older adults: effects of a physician-based exercise counseling and prescription program. Can Fam Physician. 2010;56(5):e191–e200. PMID: 20463260. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.20463260
150 Phillips G, Bottomley C, Schmidt E, . Well London Phase-1: results among adults of a cluster-randomised trial of a community engagement approach to improving health behaviours and mental well-being in deprived inner-city neighbourhoods. J Epidemiol Community Health. 2014;68(7):606–14. PMID: 24489043. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.24489043
151 Poddar KH, Hosig KW, Anderson-Bill ES, . Dairy intake and related self-regulation improved in college students using online nutrition education. J Acad Nutr Diet. 2012;112(12):1976–86. PMID: 23044035. KQ1E1, KQ2E1, KQ3E1, KQ4E1.23044035
152 Prentice RL, Caan B, Chlebowski RT, . Low-fat dietary pattern and risk of invasive breast cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):629–42. PMID: 16467232. KQ1E4, KQ2E4, KQ3E4, KQ4E4.16467232
153 Prestwich A, Conner MT, Lawton RJ, . Partner- and planning-based interventions to reduce fat consumption: randomized controlled trial. Br J Health Psychol. 2014;19(1):132–48. PMID: 23659492. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.23659492
154 Prochaska JO, Velicer WF, Redding C, . Stage-based expert systems to guide a population of primary care patients to quit smoking, eat healthier, prevent skin cancer, and receive regular mammograms. Prev Med. 2005;41(2):406–16. PMID: 15896835. KQ1E4, KQ2E4, KQ3E9, KQ4E4.15896835
155 Puhkala J, Kukkonen-Harjula K, Mansikkamaki K, . Lifestyle counseling to reduce body weight and cardiometabolic risk factors among truck and bus drivers: a randomized controlled trial. Scand J Work Environ Health. 2015;41(1):54–64. PMID: 25310464. KQ1E1, KQ2E1, KQ3E1, KQ4E1.25310464
156 Raben A, Fogelholm M, Larsen TM, . PREVIEW: prevention of diabetes through lifestyle intervention and population studies in Europe and around the world. Obesity Facts. 2015;8:126. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
157 Råberg Kjøllesdal MK, Hjellset VT, Bjorge B, . Intention to change dietary habits, and weight loss among Norwegian-Pakistani women participating in a culturally adapted intervention. J Immigr Minor Health. 2011;13(6):1150–8. PMID: 21082252. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.21082252
158 Rasinaho M, Hirvensalo M, Tormakangas T, . Effect of physical activity counseling on physical activity of older people in Finland (ISRCTN 07330512). Health Promot Int. 2012;27(4):463–74. PMID: 21911336. KQ1E1, KQ2E1, KQ3E1, KQ4E1.21911336
159 Redfern J, Usherwood T, Harris MF, . A randomised controlled trial of a consumer-focused e-health strategy for cardiovascular risk management in primary care: the Consumer Navigation of Electronic Cardiovascular Tools (CONNECT) study protocol. BMJ Open. 2014;4(2):e004523. PMID: 24486732. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24486732
160 Reid RD, McDonnell LA, Riley DL, . Effect of an intervention to improve the cardiovascular health of family members of patients with coronary artery disease: a randomized trial. CMAJ. 2014;186(1):23–30. PMID: 24246588. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24246588
161 Reinhardt JA, van der Ploeg HP, Grzegrzulka R, . Implementing lifestyle change through phone-based motivational interviewing in rural-based women with previous gestational diabetes mellitus. Health Promot J Aust. 2012;23(1):5–9. PMID: None. KQ1E4, KQ2E4, KQ3E9, KQ4E4.
162 Ritenbaugh C, Patterson RE, Chlebowski RT, . The Women’s Health Initiative Dietary Modification Trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13(9 Suppl):S87–97. PMID: 14575941. KQ1E4, KQ2E4, KQ3E4, KQ4E4.14575941
163 Rogers LQ, Courneya KS, Anton PM, . Effects of the BEAT Cancer physical activity behavior change intervention on physical activity, aerobic fitness, and quality of life in breast cancer survivors: a multicenter randomized controlled trial. Breast Cancer Res Treat. 2015;149(1):109–19. PMID: 25417174. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.25417174
164 Rubinstein A, Miranda JJ, Beratarrechea A, . Effectiveness of an mHealth intervention to improve the cardiometabolic profile of people with prehypertension in low-resource urban settings in Latin America: a randomised controlled trial. Lancet Diabetes Endocrinol. 2016;4(1):52–63. PMID: 26653067. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.26653067
165 Ruzicka M, Ramsay T, Bugeja A, . Does pragmatically structured outpatient dietary counselling reduce sodium intake in hypertensive patients? Study protocol for a randomized controlled trial. Trials. 2015;16:273. PMID: 26081765. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26081765
166 Share BL, Naughton GA, Obert P, . Effects of a multi-disciplinary lifestyle intervention on cardiometabolic risk factors in young women with abdominal obesity: a randomised controlled trial. PLoS One. 2015;10(6). PMID: 26114854. KQ1E6, KQ2E6, KQ3E6, KQ4E6.26114854
167 Schoenthaler A, Teresi J, Luerassi L, . Comparative effectiveness of a practice-based trial of blood pressure control in blacks: is less more? J Gen Intern Med. 2014;29:S54–s5. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
168 Schulz DN, Kremers SP, Osch LA, . Testing a Dutch web-based tailored lifestyle programme among adults: a study protocol. BMC Public Health. 2011;11:108. PMID: 21324181. KQ1E4, KQ2E4, KQ3E9, KQ4E4.21324181
169 Schulz DN, Kremers SP, Vandelanotte C, . Effects of a web-based tailored multiple-lifestyle intervention for adults: a two-year randomized controlled trial comparing sequential and simultaneous delivery modes. J Med Internet Res. 2014;16(1):48–65. PMID: 24472854. KQ1E4, KQ2E4, KQ3E9, KQ4E4.24472854
170 Schwerdtfeger AR, Schmitz C, Warken M. Using text messages to bridge the intention-behavior gap? A pilot study on the use of text message reminders to increase objectively assessed physical activity in daily life. Front Psychol. 2012;3:270. PMID: 22876237. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.22876237
171 Simmons RK, van Sluijs EM, Hardeman W, . Who will increase their physical activity? Predictors of change in objectively measured physical activity over 12 months in the ProActive cohort. BMC Public Health. 2010;10:226. PMID: 20433700. KQ1E4, KQ2E4, KQ3E4, KQ4E4.20433700
172 Siscovick DS, Weiss NS, Fletcher RH, . The incidence of primary cardiac arrest during vigorous exercise. N Engl J Med. 1984;311(14):874–7. PMID: 6472399. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.6472399
173 Solberg PA, Halvari H, Ommundsen Y, . A 1-year follow-up of effects of exercise programs on well-being in older adults. J Aging Phys Act. 2014;22(1):52–64. PMID: 23348061. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.23348061
174 Soureti A, Murray P, Cobain M, . Exploratory study of web-based planning and mobile text reminders in an overweight population. J Med Internet Res. 2011;13(4):232–42. PMID: 22182483. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.22182483
175 Spassova L, Vittore D, Droste DW, . Randomised controlled trial to evaluate the efficacy and usability of a computerised phone-based lifestyle coaching system for primary and secondary prevention of stroke. BMC Neurol. 2016;16:22. PMID: 26861865. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26861865
176 Spink KS, Wilson KS. Physician counseling and longer term physical activity. J Prim Care Community Health. 2010;1(3):173–7. PMID: 23804607. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.23804607
177 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. Prev Med. 2007;44(3):209–17. PMID: 17197015. KQ1E4, KQ2E4, KQ3E9, KQ4E4.17197015
178 Stadler G, Oettingen G, Gollwitzer PM. Intervention effects of information and self-regulation on eating fruits and vegetables over two years. Health Psychol. 2010;29(3):274–83. PMID: 20496981. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.20496981
179 Staudter M, Dramiga S, Webb L, . Effectiveness of pedometer use in motivating active duty and other military healthcare beneficiaries to walk more. US Army Med Dep J. 2011:108–19. PMID: 21805462. KQ1E1, KQ2E1, KQ3E1, KQ4E1.21805462
180 Stefanick ML, Mackey S, Sheehan M, . Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12–20. PMID: 9647874. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.9647874
181 Stensel DJ, Brooke-Wavell K, Hardman AE, . The influence of a 1-year programme of brisk walking on endurance fitness and body composition in previously sedentary men aged 42–59 years. Eur J Appl Physiol Occup Physiol. 1994;68(6):531–7. PMID: 7957147. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E4.7957147
182 Stevens VJ, Glasgow RE, Toobert DJ, . One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Prev Med. 2003;36(5):594–600. PMID: 12689805. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.12689805
183 Tapper K, Jiga-Boy G, Maio GR, . Development and preliminary evaluation of an internet-based healthy eating program: randomized controlled trial. J Med Internet Res. 2014;16(10):12–27. PMID: 25305376. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25305376
184 Telle-Hjellset V, Raberg Kjollesdal MK, Bjorge B, . The InnvaDiab-DE-PLAN study: a randomised controlled trial with a culturally adapted education programme improved the risk profile for type 2 diabetes in Pakistani immigrant women. Br J Nutr. 2013;109(3):529–38. PMID: 22717286. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.22717286
185 Uritani D, Matsumoto D, Asano Y, . Effects of regular exercise and nutritional guidance on body composition, blood pressure, muscle strength and health-related quality of life in community-dwelling Japanese women. Obes Res Clin Pract. 2013;7(2):e155–e63. PMID: 24331777. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.24331777
186 Varma VR, Tan EJ, Gross AL, . Effect of community volunteering on physical activity: a randomized controlled trial. Am J Prev Med. 2016;50(1):106–10. PMID: 26340864. KQ1E1, KQ2E1, KQ3E1, KQ4E1.26340864
187 Vinkers CD, Adriaanse MA, Kroese FM, . Efficacy of a self-management intervention for weight control in overweight and obese adults: a randomized controlled trial. J Behav Med. 2014;37(4):781–92. PMID: 23954938. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.23954938
188 von Klot S, Mittleman MA, Dockery DW, . Intensity of physical exertion and triggering of myocardial infarction: a case-crossover study. Eur Heart J. 2008;29(15):1881–8. PMID: 18534976. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.18534976
189 Vroege DP, Wijsman CA, Broekhuizen K, . Dose-response effects of a web-based physical activity program on body composition and metabolic health in inactive older adults: additional analyses of a randomized controlled trial. J Med Internet Res. 2014;16(12):e265. PMID: 25486673. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.25486673
190 Wagner MG, Rhee Y, Honrath K, . Nutrition education effective in increasing fruit and vegetable consumption among overweight and obese adults. Appetite. 2016;100:94–101. PMID: 26850310. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.26850310
191 Walker SN, Pullen CH, Boeckner L, . Clinical trial of tailored activity and eating newsletters with older rural women. Nurs Res. 2009;58(2):74–85. PMID: 19289928. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.19289928
192 Walker SN, Pullen CH, Hageman PA, . Maintenance of activity and eating change after a clinical trial of tailored newsletters with older rural women. Nurs Res. 2010;59(5):311–21. PMID: 20697307. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.20697307
193 Watanabe M, Yamaoka K, Yokotsuka M, . Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003;26(12):3209–14. PMID: 14633803. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.14633803
194 Weinhold K, Miller CK, Marrero DG, . Worksite diabetes prevention trial improves outcomes among employees with prediabetes. Diabetes. 2015;64:A216. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.
195 Werkman A, Hulshof PJ, Stafleu A, . Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10:110. PMID: 20205704. KQ1E4, KQ2E9, KQ3E9, KQ4E4.20205704
196 Williams LT, Hollis JL, Collins CE, . Can a relatively low-intensity intervention by health professionals prevent weight gain in mid-age women? 12-month outcomes of the 40-Something randomised controlled trial. Nutr Diabetes. 2014;4:e116. PMID: 24799163. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24799163
197 Williams SL, French DP. Theory of planned behaviour variables and objective walking behaviour do not show seasonal variation in a randomised controlled trial. BMC Public Health. 2014;14:120. PMID: 24499405. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24499405
198 Williams SL, Michie S, Dale J, . The effects of a brief intervention to promote walking on theory of planned behavior constructs: a cluster randomized controlled trial in general practice. Patient Educ Couns. 2015;98(5):651–9. PMID: 25677127. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25677127
199 Willich SN, Lewis M, Lowel H, . Physical exertion as a trigger of acute myocardial infarction. N Engl J Med. 1993;329(23):1684–90. PMID: 8232457. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.8232457
200 Wister A, Loewen N, Kennedy-Symonds H, . One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. CMAJ. 2007;177(8):859–65. PMID: 17923653. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.17923653
201 Wolff JK, Warner LM, Ziegelmann JP, . What do targeting positive views on ageing add to a physical activity intervention in older adults? Results from a randomised controlled trial. Psychol Health. 2014;29(8):915–32. PMID: 24559210. KQ1E4, KQ2E4, KQ3E9, KQ4E4.24559210
202 Wu RR, Myers RA, Hauser ER, . Impact of genetic testing and family health history based risk counseling on behavior change and cognitive precursors for type 2 diabetes. J Genet Couns. 2017;26(1):133–140. PMID: 27296809. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.27296809
203 Yates BC, Pullen CH, Santo JB, . The influence of cognitive-perceptual variables on patterns of change over time in rural midlife and older women’s healthy eating. Soc Sci Med. 2012;75(4):659–67. PMID: 22365936. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.22365936
204 Yates T, Davies M, Gorely T, . Rationale, design and baseline data from the Pre-diabetes Risk Education and Physical Activity Recommendation and Encouragement (PREPARE) programme study: a randomized controlled trial. Patient Educ Couns. 2008;73(2):264–71. PMID: 18653305. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.18653305
205 Yates T, Davies M, Gorely T, . Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32(8):1404–10. PMID: 19602539. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.19602539
206 Yates T, Davies M, Gorely T, . Twelve-month follow-up from the PREPARE (Prediabetes Risk Education and Physical Activity Recommendation and Encouragement) programme study: a randomized controlled trial. Diabet Med. 2009;26(Suppl 1):17. PMID: None. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E4.