# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1 Aadahl M, Linneberg A, Moller TC, . Motivational counseling to reduce sitting time: a community-based randomized controlled trial in adults. Am J Prev Med. 2014;47(5):576–86. PMID: 25113139.25113139
2 Aittasalo M, Miilunpalo S, Kukkonen-Harjula K, . A randomized intervention of physical activity promotion and patient self-monitoring in primary health care. Prev Med. 2006;42(1):40–6. PMID: 16297442.16297442
3 Albright CL, Steffen AD, Wilkens LR, . Effectiveness of a 12-month randomized clinical trial to increase physical activity in multiethnic postpartum women: Results from Hawaii’s N Mikimiki Project. Prev Med. 2014;69:214–23. PMID: 25285751.25285751 a.Albright CL, Saiki K, Steffen AD, . What barriers thwart postpartum women’s physical activity goals during a 12-month intervention? A process evaluation of the Na Mikimiki Project. Women & Health. 2015;55(1):1–21. PMID: 25402618.25402618 b.Albright CL, Steffen AD, Novotny R, . Baseline results from Hawaii’s Na Mikimiki Project: a physical activity intervention tailored to multiethnic postpartum women. Women & Health. 2012;52(3):265–91. PMID: 22533900.22533900
4 Aldana SG, Greenlaw RL, Diehl HA, . The behavioral and clinical effects of therapeutic lifestyle change on middle-aged adults. Prev Chronic Dis. 2006;3(1):A05. PMID: 16356358.16356358 a.Aldana SG, Greenlaw RL, Diehl HA, . Effects of an intensive diet and physical activity modification program on the health risks of adults. J Am Diet Assoc. 2005;105(3):371–81. PMID: 15746824.15746824
5 Alexander GL, McClure JB, Calvi JH, . A randomized clinical trial evaluating online interventions to improve fruit and vegetable consumption. American journal of public health. 2010;100(2):319–26. PMID: 20019315.20019315 a.Stopponi MA, Alexander GL, McClure JB, . Recruitment to a randomized web-based nutritional intervention trial: characteristics of participants compared to non-participants. J Med Internet Res. 2009;11(3):e38. PMID: 19709990.19709990
6 Baron JA, Gleason R, Crowe B, . Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Pract. 1990;40(333):137–41. PMID: 2115348.2115348
7 Bennett GG, Foley P, Levine E, . Behavioral treatment for weight gain prevention among black women in primary care practice: A randomized clinical trial. JAMA Intern Med. 2013;173(19):1770–7. PMID: 23979005.23979005 a.Foley P, Levine E, Askew S, . Weight gain prevention among black women in the rural community health center setting: the Shape Program. BMC Public Health. 2012;12:305. PMID: 22537222.22537222
8 Beresford SA, Curry SJ, Kristal AR, . A dietary intervention in primary care practice: the Eating Patterns Study. Am J Public Health. 1997;87(4):610–6. PMID: 9146440.9146440
9 Bernstein A, Nelson ME, Tucker KL, . A home-based nutrition intervention to increase consumption of fruits, vegetables, and calcium-rich foods in community dwelling elders. J Am Diet Assoc. 2002;102(10):1421–7. PMID: 12396159.12396159
10 Bickmore TW, Silliman RA, Nelson K, . A Randomized Controlled Trial of an Automated Exercise Coach for Older Adults. J Am Geriatr Soc. 2013;61(10):1676–83. PMID: 24001030.24001030
11 Brekke HK, Jansson PA, Lenner RA. Long-term (1- and 2-year) effects of lifestyle intervention in type 2 diabetes relatives. Diabetes Res Clin Pract. 2005;70(3):225–34. PMID: 15885845.15885845
12 Bryan AD, Magnan RE, Hooper AE, . Colorado stride (COSTRIDE): testing genetic and physiological moderators of response to an intervention to increase physical activity. Int J Behav Nutr Phys Act. 2013;10:139. PMID: 24359456.24359456
13 Burke L, Lee AH, Jancey J, . Physical activity and nutrition behavioural outcomes of a home-based intervention program for seniors: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:14. PMID: 23363616.23363616 a.Burke L, Jancey J, Howat P, . Physical activity and nutrition program for seniors (PANS): protocol of a randomized controlled trial. BMC Public Health. 2010;10:751. PMID: 21129226.21129226
14 Carpenter RA, Finley C, Barlow CE. Pilot test of a behavioral skill building intervention to improve overall diet quality. J Nutr Educ Behav. 2004;36(1):20–4. PMID: 14756978.14756978
15 Carroll JK, Lewis BA, Marcus BH, . Computerized tailored physical activity reports. A randomized controlled trial. Am J Prev Med. 2010;39(2):148–56. PMID: 20621262.20621262
16 Castro CM, Pruitt LA, Buman MP, . Physical activity program delivery by professionals versus volunteers: the TEAM randomized trial. Health Psychol. 2011;30(3):285–94. PMID: 21553972.21553972
17 Coates RJ, Bowen DJ, Kristal AR, . The Women’s Health Trial Feasibility Study in Minority Populations: changes in dietary intakes. Am J Epidemiol. 1999;149(12):1104–12. PMID: 10369504.10369504 a.Bowen D, Clifford CK, Coates R, . The Women’s Health Trial Feasibility Study in Minority Populations: design and baseline descriptions. Ann Epidemiol. 1996;6(6):507–19. PMID: 8978881.8978881 b.Hall WD, Feng Z, George VA, . Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13(3):337–43. PMID: 12894958.12894958
18 De Vet E, Oenema A, Sheeran P, . Should implementation intentions interventions be implemented in obesity prevention: the impact of if-then plans on daily physical activity in Dutch adults. Int J Behav Nutr Phys Act. 2009;6:11. PMID: 19267889.19267889
19 Delichatsios HK, Friedman RH, Glanz K, . Randomized trial of a “talking computer” to improve adults’ eating habits. Am J Health Promot. 2001;15(4):215–24. PMID: 11349340.11349340
20 Elley CR, Kerse N, Arroll B, . Effectiveness of counselling patients on physical activity in general practice: cluster randomised controlled trial. BMJ. 2003;326(7393):793. PMID: None.12689976 a.Kerse N, Elley CR, Robinson E, . Is physical activity counseling effective for older people? A cluster randomized, controlled trial in primary care. J Am Geriatr Soc. 2005;53(11):1951–6. PMID: 1627437716274377
21 Estabrooks PA, Smith-Ray RL, Almeida FA, . Move More: Translating an efficacious group dynamics physical activity intervention into effective clinical practice. Int J Sport Exerc Psychology. 2011;9(1):4–18. PMID: None.
22 Fjeldsoe BS, Miller YD, Graves N, . Randomized Controlled Trial of an Improved Version of MobileMums, an Intervention for Increasing Physical Activity in Women with Young Children. Ann Behav Med. 2015;49(4):487–99. PMID: 25582987.25582987 a.Marshall AL, Miller YD, Graves N, . Moving MobileMums forward: protocol for a larger randomized controlled trial of an improved physical activity program for women with young children. BMC Public Health. 2013;13(1):593. PMID: None.23777245
23 Franko DL, Cousineau TM, Trant M, . Motivation, self-efficacy, physical activity and nutrition in college students: Randomized controlled trial of an internet-based education program. Prev Med. 2008;47(4):369–77. PMID: 18639581.18639581
24 Fries E, Edinboro P, McClish D, . Randomized trial of a low-intensity dietary intervention in rural residents: the Rural Physician Cancer Prevention Project. Am J Prev Med. 2005;28(2):162–8. PMID: 15710271.15710271
25 Gao S, Stone RA, Hough LJ, . Physical activity counseling in overweight and obese primary care patients: Outcomes of the VA-STRIDE randomized controlled trial. Prev Med Rep. 2016;3:113–20. PMID: 26844197.26844197
26 Gell NM, Wadsworth DD. The use of text messaging to promote physical activity in working women: A randomized controlled trial. J Phys Act Health. 2015;12(6):756–63. PMID: 25110303.25110303
27 Goldstein MG, Pinto BM, Marcus BH, . Physician-based physical activity counseling for middle-aged and older adults: a randomized trial. Ann Behav Med. 1999;21(1):40–7. PMID: 18425653.18425653 a.Pinto BM, Goldstein MG, DePue JD, . Acceptability and feasibility of physician-based activity counseling. The PAL project. Am J Prev Med. 1998;15(2):95–102. PMID: 9713664.9713664
28 Grandes G, Sanchez A, Sanchez-Pinilla RO, . Effectiveness of physical activity advice and prescription by physicians in routine primary care: a cluster randomized trial. Arch Intern Med. 2009;169(7):694–701. PMID: 19364999.19364999 a.Garcia-Ortiz L, Grandes G, Sanchez-Perez A, . Effect on cardiovascular risk of an intervention by family physicians to promote physical exercise among sedentary individuals. Rev Esp Cardiol. 2010;63(11):1244–52. PMID: 21070720.21070720 b.Grandes G, Sanchez A, Montoya I, . Two-year longitudinal analysis of a cluster randomized trial of physical activity promotion by general practitioners. PLoS One. 2011;6(3):e18363. PMID: 21479243.21479243
29 Green BB, McAfee T, Hindmarsh M, . Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177–83. PMID: 11897462.11897462
30 Greene GW, Fey-Yensan N, Padula C, . Change in fruit and vegetable intake over 24 months in older adults: results of the SENIOR project intervention. Gerontologist. 2008;48(3):378–87. PMID: 18591363.18591363 a.Clark PG, Nigg CR, Greene G, . The Study of Exercise and Nutrition in Older Rhode Islanders (SENIOR): translating theory into research. Health Educ Res. 2002;17(5):552–61. PMID: 12408200.12408200 b.Clark PG, Rossi JS, Greaney ML, . Intervening on exercise and nutrition in older adults: the Rhode Island SENIOR Project. J Aging Health. 2005;17(6):753–78. PMID: 16377771.16377771
31 Greenlee H, Gaffney AO, Aycinena AC, . Cocinar Para Su Salud!: Randomized Controlled Trial of a Culturally Based Dietary Intervention among Hispanic Breast Cancer Survivors.[Reprint in J Acad Nutr Diet. 2015 May;115(5 Suppl):S42–S56.e3; PMID: 25911520]. J Acad Nutr Diet. 2015;115(5):709–23.e3. PMID: 25578926.25578926
32 Halbert JA, Silagy CA, Finucane PM, . Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice. Med J Aust. 2000;173(2):84–7. PMID: 10937036.10937036 a.Halbert JA, Silagy CA, Finucane P, . Recruitment of older adults for a randomized, controlled trial of exercise advice in a general practice setting. J Am Geriatr Soc. 1999;47(4):477–81. PMID: 10203125.10203125
33 Hargreaves EA, Mutrie N, Fleming JD. A Web-Based Intervention to Encourage Walking (StepWise): Pilot Randomized Controlled Trial. JMIR Res Protoc. 2016;5(1):e14. PMID: 26810251.26810251
34 Harland J, White M, Drinkwater C, . The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. BMJ. 1999;319(7213):828–32. PMID: 10496829.10496829
35 Harris T, Kerry SM, Victor CR, . A primary care nurse-delivered walking intervention in older adults: PACE (pedometer accelerometer consultation evaluation)-Lift cluster randomised controlled trial. PLoS Med. 2015;12(2):e1001783. PMID: 25689364.25689364 a.Harris T, Kerry S, Victor C, . Randomised controlled trial of a complex intervention by primary care nurses to increase walking in patients aged 60–74 years: protocol of the PACE-Lift (Pedometer Accelerometer Consultation Evaluation - Lift) trial. BMC Public Health. 2013;13:5. PMID: 23289648.23289648
36 Hellenius ML, de FU, Berglund B, . Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. 1993;103(1):81–91. PMID: 8280188.8280188 a.Hellenius ML, Dahlof C, Aberg H, . Quality of life is not negatively affected by diet and exercise intervention in healthy men with cardiovascular risk factors. Qual Life Res. 1995;4(1):13–20. PMID: 7711685.7711685
37 Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586.24084586 a.Blumenthal JA, Babyak MA, Hinderliter A, . Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. 2010;170(2):126–35. PMID: 20101007.20101007
38 Hivert MF, Langlois MF, Bérard P, . Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes (Lond). 2007;31(8):1262–9. PMID: 17356531.17356531
39 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477.2404477 a.Meinert CL, Borhani NO, Langford HG. Design, methods, and rationale in the Hypertension Prevention Trial. Hypertension Prevention Trial Research Group. Control Clin Trials. 1989;10(3 Suppl):1S–29S. PMID: 2680271.2680271 b.Shah M, Jeffery RW, Laing B, . Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69–76. PMID: 2404050.2404050
40 Jacobs N, Clays E, De BD, . Effect of a tailored behavior change program on a composite lifestyle change score: a randomized controlled trial. Health education research. 2011;26(5):886–95. PMID: 21712501.21712501 a.Jacobs N, De BI, Thijs H, . Effect of a cardiovascular prevention program on health behavior and BMI in highly educated adults: a randomized controlled trial. Patient Educ Couns. 2011;85(1):122–6. PMID: 20888728.20888728
41 Jeffery RW, French SA. Preventing weight gain in adults: the pound of prevention study. Am J Public Health. 1999;89(5):747–51. PMID: 10224988.10224988
42 John JH, Ziebland S, Yudkin P, . Effects of fruit and vegetable consumption on plasma antioxidant concentrations and blood pressure: a randomised controlled trial. Lancet. 2002;359(9322):1969–74. PMID: 12076551.12076551
43 Kallings LV, Sierra JJ, Fisher RM, . Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2009;16(1):80–4. PMID: 19237997.19237997 a.Kallings LV. Physical activity on prescription: studies on physical activity level, adherence, and cardiovascular risk factors [Doctoral]. Stockholm, Sweden: Karolinska Institute; 2008. PMID: None.
44 Kattelmann KK, Bredbenner CB, White AA, . The effects of Young Adults Eating and Active for Health (YEAH): A theory-based web-delivered intervention. J Nutr Educ Behav. 2014;46(6):S27–S41. PMID: None.
45 Katz DL, Shuval K, Comerford BP, . Impact of an educational intervention on internal medicine residents’ physical activity counselling: the Pressure System Model. J Eval Clin Pract. 2008;14(2):294–9. PMID: 18324934.18324934
46 Kerr DA, Harray AJ, Pollard CM, . The connecting health and technology study: A 6-month randomized controlled trial to improve nutrition behaviours using a mobile food record and text messaging support in young adults. Int J Behav Nutr Phys Act. 2016;13(1):52. PMID: 27098449.27098449 a.Kerr DA, Pollard CM, Howat P, . Connecting Health and Technology (CHAT): protocol of a randomized controlled trial to improve nutrition behaviours using mobile devices and tailored text messaging in young adults. BMC Public Health. 2012;12:477. PMID: None.22726532
47 King AC, Castro CM, Buman MP, . Behavioral Impacts of Sequentially versus Simultaneously Delivered Dietary Plus Physical Activity Interventions: the CALM Trial. Ann Behav Med. 2013;46(2):157–68. PMID: 23609341.23609341
48 King AC, Friedman R, Marcus B, . Ongoing physical activity advice by humans versus computers: the Community Health Advice by Telephone (CHAT) trial. Health Psychol. 2007;26(6):718–27. PMID: 18020844.18020844
49 Kinmonth AL, Wareham NJ, Hardeman W, . Efficacy of a theory-based behavioural intervention to increase physical activity in an at-risk group in primary care (ProActive UK): a randomised trial. Lancet. 2008;371(9606):41–8. PMID: 18177774.18177774 a.Williams K, Prevost AT, Griffin S, . The ProActive trial protocol - a randomised controlled trial of the efficacy of a family-based, domiciliary intervention programme to increase physical activity among individuals at high risk of diabetes [ISRCTN61323766]. BMC Public Health. 2004;4:48. PMID: 15491494.15491494
50 Kolt GS, Schofield GM, Kerse N, . Effect of telephone counseling on physical activity for low-active older people in primary care: a randomized, controlled trial. J Am Geriatr Soc. 2007;55(7):986–92. PMID: 17608869.17608869
51 Kristal AR, Curry SJ, Shattuck AL, . A randomized trial of a tailored, self-help dietary intervention: the Puget Sound Eating Patterns study. Prev med. 2000;31(4):380–9. PMID: 11006063.11006063
52 Lawton BA, Rose SB, Elley CR, . Exercise on prescription for women aged 40–74 recruited through primary care: two year randomised controlled trial. BMJ. 2008;337:a2509. PMID: 19074218.19074218
53 Lewis BA, Williams DM, Martinson BC, . Healthy for life: A randomized trial examining physical activity outcomes and psychosocial mediators. Ann Behav Med. 2013;45(2):203–12. PMID: 23229158.23229158
54 Lutz SF, Ammerman AS, Atwood JR, . Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99(6):705–9. PMID: 10361533.10361533
55 Mailey EL, McAuley E. Impact of a brief intervention on physical activity and social cognitive determinants among working mothers: a randomized trial. J Behav Med. 2014;37(2):343–55. PMID: 23338616.23338616
56 Marcus BH, Dunsiger SI, Pekmezi DW, . The Seamos Saludables study: A randomized controlled physical activity trial of Latinas. Am J Prev Med. 2013;45(5):598–605. PMID: 24139773.24139773 a.Marcus BH, Dunsiger SI, Pekmezi D, . Twelve-month physical activity outcomes in Latinas in the Seamos Saludables trial. Am J Prev Med. 2015;48(2):179–82. PMID: 25442225.25442225 b.Pekmezi D, Dunsiger S, Gans K, . Rationale, design, and baseline findings from Seamos Saludables: a randomized controlled trial testing the efficacy of a culturally and linguistically adapted, computer- tailored physical activity intervention for Latinas. Contemp Clin Trials. 2012;33(6):1261–71. PMID: 22789455.22789455
57 Marcus BH, Napolitano MA, King AC, . Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol. 2007;26(4):401–9. PMID: 17605559.17605559 a.Magnan RE, Nilsson R, Marcus BH, . A transdisciplinary approach to the selection of moderators of an exercise promotion intervention: baseline data and rationale for Colorado STRIDE. J Behav Med. 2013;36(1):20–33. PMID: 22083142.22083142 b.Marcus BH, Napolitano MA, King AC, . Examination of print and telephone channels for physical activity promotion: Rationale, design, and baseline data from Project STRIDE. Contemp Clin Trials. 2007;28(1):90–104. PMID: 16839823.16839823
58 Marsaux CF, Celis-Morales C, Fallaize R, . Effects of a Web-Based Personalized Intervention on Physical Activity in European Adults: A Randomized Controlled Trial. J Med Internet Res. 2015;17(10):e231. PMID: 26467573.26467573
59 Marshall AL, Bauman AE, Owen N, . Population-based randomized controlled trial of a stage-targeted physical activity intervention. Ann Behav Med. 2003;25(3):194–202. PMID: 12763714.12763714
60 Martinson BC, Crain AL, Sherwood NE, . Maintaining physical activity among older adults: six-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev med. 2008;46(2):111–9. PMID: 17904629.17904629 a.Martinson BC, Sherwood NE, Crain AL, . Maintaining physical activity among older adults: 24-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev Med. 2010. PMID: 20382179.20382179 b.Sherwood NE, Martinson BC, Crain AL, . A new approach to physical activity maintenance: rationale, design, and baseline data from the Keep Active Minnesota Trial. BMC Geriatrics. 2008;8:17. PMID: 18655709.18655709
61 Mosca L, Mochari H, Liao M, . A novel family-based intervention trial to improve heart health: FIT Heart: results of a randomized controlled trial. Circ Cardiovasc Qual Outcomes. 2008;1(2):98–106. PMID: 20031796.20031796 a.Greenberger HM. Modifiers of the effectiveness of a diet intervention in family members of cardiovascular disease patients [Dissertation Research]. UMI Dissertation Publishing: Columbia University; 2010. PMID: None. b.Mochari-Greenberger H, Terry MB, Mosca L. Sex, age, and race/ethnicity do not modify the effectiveness of a diet intervention among family members of hospitalized cardiovascular disease patients. J Nutr Educ Behav. 2011;43(5):366–73. PMID: 21906549.21906549
62 Napolitano MA, Whiteley JA, Papandonatos G, . Outcomes from the women’s wellness project: a community-focused physical activity trial for women. Prev Med. 2006;43(6):447–53. PMID: 16919322.16919322 a.Dutton GR, Napolitano MA, Whiteley JA, . Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Prev Med. 2008;46(3):216–21. PMID: 18234327.18234327
63 Norris SL, Grothaus LC, Buchner DM, . Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30(6):513–23. PMID: 10901494.10901494
64 Parekh S, King D, Boyle FM, . Randomized controlled trial of a computer-tailored multiple health behaviour intervention in general practice: 12-month follow-up results. Int J Behav Nutr Phys Act. 2014;11(1):41. PMID: 24646165.24646165 a.Parekh S, Vandelanotte C, King D, . Design and baseline characteristics of the 10 Small Steps Study: a randomised controlled trial of an intervention to promote healthy behaviour using a lifestyle score and personalised feedback. BMC Public Health. 2012;12:179. PMID: 22405027.22405027
65 Pekmezi DW, Neighbors CJ, Lee CS, . A culturally adapted physical activity intervention for Latinas: a randomized controlled trial. Am J Prev Med. 2009;37(6):495–500. PMID: 19944914.19944914
66 Pinto BM, Friedman R, Marcus BH, . Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23(2):113–20. PMID: 12121799.12121799
67 Pinto BM, Goldstein MG, Ashba J, . Randomized controlled trial of physical activity counseling for older primary care patients. Am J Prev Med. 2005;29(4):247–55. PMID: 16242586.16242586
68 Roderick P, Ruddock V, Hunt P, . A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47(414):7–12. PMID: 9115804.9115804
69 Ruffin MT, Nease DE, Jr., Sen A, . Effect of preventive messages tailored to family history on health behaviors: the Family Healthware Impact Trial. Ann Fam Med. 2011;9(1):3–11. PMID: 21242555.21242555 a.O’Neill SM, Rubinstein WS, Wang C, . Familial risk for common diseases in primary care: the Family Healthware Impact Trial. Am J Prev Med. 2009;36(6):506–14. PMID: 19460658.19460658
70 Sacerdote C, Fiorini L, Rosato R, . Randomized controlled trial: effect of nutritional counselling in general practice. Int J Epidemiol. 2006;35(2):409–15. PMID: 16157616.16157616
71 Simkin-Silverman L, Wing RR, Hansen DH, . Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24(5):509–17. PMID: 8524727.8524727 a.Kuller LH, Simkin-Silverman LR, Wing RR, . Women’s Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32–7. PMID: 11136682.11136682 b.Simkin-Silverman LR, Wing RR, Boraz MA, . Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26(3):212–20. PMID: 14644697.14644697 c.Simkin-Silverman LR, Wing RR, Boraz MA, . Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4(3):255–71. PMID: 9787651.9787651
72 Smith BJ, Cinnadaio N, Cheung NW, . Investigation of a lifestyle change strategy for high-risk women with a history of gestational diabetes. Diabetes Res Clin Pract. 2014;106(3):e60–3. PMID: 25451910.25451910
73 Springvloet L, Lechner L, de Vries H, . Short- and medium-term efficacy of a Web-based computer-tailored nutrition education intervention for adults including cognitive and environmental feedback: randomized controlled trial. J Med Internet Res. 2015;17(1):e23. PMID: 25599828.25599828 a.Springvloet L, Lechner L, de Vries H, . Long-term efficacy of a Web-based computer-tailored nutrition education intervention for adults including cognitive and environmental feedback: a randomized controlled trial. BMC Public Health. 2015;15:372. PMID: 25887891.25887891 b.Springvloet L, Lechner L, Oenema A. Planned development and evaluation protocol of two versions of a web-based computer-tailored nutrition education intervention aimed at adults, including cognitive and environmental feedback. BMC Public Health. 2014;14:47. PMID: 24438381.24438381
74 Stewart AL, Verboncoeur CJ, McLellan BY, . Physical activity outcomes of CHAMPS II: a physical activity promotion program for older adults. J Gerontol A Biol Sci Med Sci. 2001;56(8):M465–M70. PMID: 11487597.11487597
75 Taveras EM, Blackburn K, Gillman MW, . First steps for mommy and me: a pilot intervention to improve nutrition and physical activity behaviors of postpartum mothers and their infants. Matern Child Health J. 2011;15(8):1217–27. PMID: 20957514.20957514
76 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398.1586398 a.Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506.17449506 b.Kumanyika SK, Hebert PR, Cutler JA, . Feasibility and efficacy of sodium reduction in the Trials of Hypertension Prevention, phase I. Trials of Hypertension Prevention Collaborative Research Group. Hypertension. 1993;22(4):502–12. PMID: 8406655.8406655 c.Satterfield S, Cutler JA, Langford HG, . Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1(5):455–71. PMID: 1669525.1669525
77 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920.9080920 a.Hebert PR, Bolt RJ, Borhani NO, . Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):130–9. PMID: 7795831.7795831 b.Kumanyika SK, Cook NR, Cutler JA, . Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. J Hum Hypertens. 2005;19(1):33–45. PMID: 15372064.15372064
78 Thompson JL, Allen P, Helitzer DL, . Reducing diabetes risk in American Indian women. Am J Prev Med. 2008;34(3):192–201. PMID: 18312806.18312806 a.Allen P, Thompson JL, Herman CJ, . Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Prev Chronic Dis. 2008;5(3):A76. PMID: 18558026.18558026 b.Herman C, Thompson J, Wolfe V, ., editors. Six-month results from a healthy lifestyles diabetes primary prevention program among urban Native American women. American Public Health Association 134th Annual Meeting & Exposition; 2006 Nov 4; Boston, MA (USA). 2010 HL Review. PMID: None.
79 Thompson WG, Kuhle CL, Koepp GA, . “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Arch Gerontol Geriatr. 2014;58(3):314–9. PMID: 24485546.24485546
80 Tinker LF, Bonds DE, Margolis KL, . Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women’s Health Initiative randomized controlled dietary modification trial. Arch Intern Med. 2008;168(14):1500–11. PMID: 18663162.18663162 a.Allison MA, Aragaki AK, Ray RM, . A Randomized Trial of a Low-Fat Diet Intervention on Blood Pressure and Hypertension: Tertiary Analysis of the WHI Dietary Modification Trial. Am J Hypertens. 2015. PMID: 26708006.26708006 b.Assaf AR, Beresford SA, Risica PM, . Low-Fat Dietary Pattern Intervention and Health-Related Quality of Life: The Women’s Health Initiative Randomized Controlled Dietary Modification Trial. J Acad Nutr Diet. 2016;116(2):259–71. PMID: 26384466.26384466 c.Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39–49. PMID: 16391215.16391215 d.Howard BV, Van HL, Hsia J, . Low-fat dietary pattern and risk of cardiovascular disease: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):655–66. PMID: 16467234.16467234 e.The Women’s Health Initiative Study Group. Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19(1):61–109. PMID: 9492970.9492970
81 Tokunaga-Nakawatase Y, Nishigaki M, Taru C, . Computer-supported indirect-form lifestyle-modification support program using Lifestyle Intervention Support Software for Diabetes Prevention (LISS-DP) for people with a family history of type 2 diabetes in a medical checkup setting: A randomized controlled trial. Prim Care Diabetes. 2014;8(3):207–14. PMID: 24529485.24529485 a.Nishigaki M, Tokunaga-Nakawatase Y, Nishida J, . Randomized controlled trial of the effectiveness of genetic counseling and a distance, computer-based, lifestyle intervention program for adult offspring of patients with type 2 diabetes: background, study protocol, and baseline patient characteristics. J Nutr Metab. 2012;2012:831735. PMID: 2261970522619705
82 Valve P, Lehtinen-Jacks S, Eriksson T, . LINDA - a solution-focused low-intensity intervention aimed at improving health behaviors of young females: a cluster-randomized controlled trial. BMC Public Health. 2013;13:1044. PMID: 24188719.24188719
83 Van Hoecke AS, Delecluse C, Bogaerts A, . The long-term effectiveness of need-supportive physical activity counseling compared with a standard referral in sedentary older adults. J Aging Phys Act. 2014;22(2):186–98. PMID: 23628840.23628840 a.Van Hoecke AS, Delecluse C, Bogaerts A, . Effects of need-supportive physical activity counseling on well-being: a 2-year follow-up among sedentary older adults. J Phys Act Health. 2014;11(8):1492–502. PMID: 24384675.24384675
84 van Stralen MM, de VH, Bolman C, . Exploring the efficacy and moderators of two computer-tailored physical activity interventions for older adults: a randomized controlled trial. Ann Behav Med. 2010;39(2):139–50. PMID: 20182833.20182833 a.van Stralen MM, de VH, Mudde AN, . The long-term efficacy of two computer-tailored physical activity interventions for older adults: main effects and mediators. Health Psychol. 2011;30(4):442–52. PMID: 21639638.21639638 b.van Stralen MM, de Vries H, Mudde AN, . Efficacy of two tailored interventions promoting physical activity in older adults. Am J Prev Med. 2009;37(5):405–17. PMID: 19840695.19840695
85 Vandelanotte C, De B, I, Sallis JF, . Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med. 2005;29(2):138–46. PMID: 15823787.15823787
86 Vrdoljak D, Markovic BB, Puljak L, . Lifestyle intervention in general practice for physical activity, smoking, alcohol consumption and diet in elderly: a randomized controlled trial. Arch Gerontol Geriatr. 2014;58(1):160–9. PMID: 24012131.24012131
87 Wadsworth DD, Hallam JS. Effect of a web site intervention on physical activity of college females. Am J Health Behav. 2010;34(1):60–9. PMID: 19663753.19663753
88 Warner LM, Wolff JK, Ziegelmann JP, . Revisiting self-regulatory techniques to promote physical activity in older adults: null-findings from a randomised controlled trial. Psychol Health. 2016:1–21. PMID: 27145328.27145328