# Appendix B Detailed Data Analysis Methods

We ran random effects meta-analyses using the DerSimonian and Laird method to calculate the pooled differences in means for intermediate outcomes (systolic and diastolic blood pressure, low-density lipoprotein cholesterol, total cholesterol, high-density lipoprotein cholesterol, triglycerides, glucose, and measures of adiposity) and behavioral outcomes (self-reported or objectively-measured physical activity, intake of total energy, fat, saturated fat, fruits and vegetables, and fiber).^71^ We used the between-group differences for each outcome as reported by each respective study and favored adjusted effect estimates over unadjusted. If a between group effect estimate and variance were not provided, we calculated a crude effect estimate.

We converted certain International System of Units/Système International (SI) values to conventional units for ease of interpretation. Appendix B Table 1 presents conversion factors for the units that we converted.

Appendix B Table 1 Factors Used to Convert International System (SI) Units to Conventional Units of Measure

Measure | SI Unit | Conventional Unit | Conversion Factor^271^ | Reverse Conversion Factor (SI to Conventional, 1/x)
Total cholesterol | mmol/l | mg/dL | 0.0259 | 38.61
Low-density lipoprotein cholesterol | mmol/l | mg/dL | 0.0259 | 38.61
High-density lipoprotein cholesterol | mmol/l | mg/dL | 0.0259 | 38.61
Triglycerides | mmol/l | mg/dL | 0.0113 | 88.496
Glucose | mmol/l | mg/dL | 0.0555 | 18.02
Weight | kg | lb | 0.4535 | 2.205
Length | cm | in | 0.3937 | 2.54
Energy | kJ | kcal | 0.2389 | 4.186

In cases where a cluster randomized trial was used but the analysis did not account for the nested nature of the data (as was the case in 11 trials^81, 92, 102, 111, 122, 132, 148, 179, 188, 214, 218^), we adjusted for the clustering effect by applying a design effect, which was based on an estimated average cluster size (the total number of randomized participants divided by the total number of clusters) and multiplied by an estimated intraclass correlation. We estimated the intraclass correlation to be 0.032 for meeting physical activity recommendations, 0.033 for continuous physical activity outcomes, and 0.03 for fat, saturated fat, and fiber based on existing literature.^122, 269^

Within each study, we chose 52-week (1 year) outcome data if available. If not, we chose the time point closest to 52 weeks and favored 78 weeks over 26 weeks where provided. We describe the results generally as 6 to 12-months followup. If a trial had more than one active intervention arm, we plotted the most intensive arm or the arm that was the most similar with other interventions included in that respective analysis. WebPlotDigitizer© version 3.10 was used to extract data from four figures within three trials to provide estimates of the within-group means and 95% confidence intervals at followup for the following outcome measures: diastolic blood pressure^137^, moderate-to-vigorous physical activity (95% confidence interval at 52 weeks)^165^, moderate physical activity^169^, and sedentary time.^169^

Because we included different measures in the pooled analyses for continuous measures of physical activity, fat, saturated fat, and fiber, we pooled standardized mean differences in change between groups. We also conducted analyses limited to only studies that reported similar measures (e.g., minutes per week of physical activity, percent of energy from fat) and found that the standardized pooled effects were very similar to analyses that included trials reporting other measures, indicating that confounding by measurement is minimal or absent.

We used standard calculations to convert standard errors and 95% confidence intervals to standard deviations:

SD_mean_ = SE_mean_ * sqrt(n) or SD_mean_ = (CI_upper_ − CI_lower_) * sqrt(n) / 3.92

If reported, within-group change from baseline was used for analysis. Where change scores were not available, they were calculated from baseline and followup measures if possible, using an outcome-specific correlation (Appendix B Table 2). This correlation was used to estimate the standard deviation in the following formula:^74^

SD_change_ = Sqrt(SD^2^_base_ + SD^2^_post _− 2 * SD_base_ * SD_post_ * r_base,post_)

Appendix B Table 2 Estimated Correlations Between Baseline and Followup Values, by Outcome

Outcome (treatment group) | Correlation used in data calculations for meta-analysis
Systolic BP (CG) | 0.65
Systolic BP (IG) | 0.60
Diastolic BP (CG) | 0.65
Diastolic BP (IG) | 0.60
LDL Cholesterol (CG) | 0.65
LDL Cholesterol (IG) | 0.60
Total Cholesterol (CG) | 0.65
Total Cholesterol (IG) | 0.60
HDL Cholesterol (CG) | 0.75
HDL (Cholesterol (IG) | 0.70
Triglycerides (CG) | 0.65
Triglycerides (IG) | 0.60
Adiposity (CG) | 0.90
Adiposity (IG) | 0.90
Total Energy (CG) | 0.60
Total Energy (IG) | 0.50
Fat/Saturated Fat (CG) | 0.50
Fat/Saturated Fat (IG) | 0.40
Fruits and Vegetables (CG) | 0.70
Fruits and Vegetables (IG) | 0.55
Fiber (CG) | 0.50
Fiber (IG) | 0.40

Abbreviations: BP=blood pressure; CG=control group; IG=intervention group; HDL=high-density lipoprotein; LDL=low-density lipoprotein.

In one study,^90^ results were presented separately for males and females. We used the following formula to calculate a combined mean and standard deviation by group:^74^

Mean_combined _= N_1_M_1_ + N_2_M_2_ / N_1_ + N_2_

SD_combined_ = sqrt((( N_1_ - 1 ) SD_1_^2^ + ( N_2_ - 1 ) SD_2_^2^ + (N_1_ N_2_)/(N_1_ + N_2_) ( M_1_^2^ + M_2_^2^ - 2 M_1_ M_2_ ))/(N_1_ + N_2_ - 1))

The only non-continuous outcome for which we performed meta-analysis was the proportion of people meeting the recommended level physical activity. Because half of the studies that reported this outcome reported adjusted odds ratios and their corresponding 95% confidence interval, we opted to use study-reported adjusted odds ratios as reported. When not reported, we calculated an odds ratio and 95% confidence interval using the raw numbers of participants meeting recommendations at followup. After calculating a pooled odds ratio, we estimated the risk ratio (relative risk) based on the formula:

RR=OR(1−P_ref_)+(P_ref_*OR)

where P_ref_ equaled the prevalence of meeting physical activity recommendations in the control group (or referent).

In one case,^207^ the standard deviation of the triglycerides in the control group at baseline was approximately five times larger than all other standard deviations, so we assume that was a typo and substituted baseline intervention group standard deviation instead.

We ran sensitivity analyses for selected intermediate outcomes (systolic and diastolic blood pressure and total cholesterol) using a restricted maximum likelihood model with the Knapp-Hartung modification (using the metareg command in Stata), which is a more conservative approach than the DerSimonian and Laird method when there is substantial heterogeneity or the number of studies is small.^75, 270^ All statistically significant results remained within the restricted maximum likelihood model, so we show results using the DerSimonian and Laird method.^71^ For intermediate outcomes, we also ran sensitivity analyses whereby we removed two trials among older adults;^146, 208^ differences in the results of these sensitivity analyses are noted in the results.

We generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and ran the Egger’s test^77^ (for continuous data) and Peters’ test^76^ (for binary data) to assess statistical significance of imbalance in study size and findings that suggest a pattern.

We investigated whether variability among the results was associated with any pre-specified study, population, or intervention characteristics first qualitatively, using visual displays and tables grouped and sorted by these potentially important characteristics. Specifically, we examined study quality (good versus fair), link to primary care (conducted in or recruited from primary care versus not), population at elevated cardiovascular risk (yes/no), mean age, baseline mean body mass index, intervention focus (healthful diet and physical activity, healthful-diet only, physical activity-only), intervention intensity (as continuous minutes and high-intensity versus medium- and low-intensity), intervention duration (continuous weeks), number of intervention sessions, and whether the intervention included group sessions (yes/no). Based on this initial assessment, we ran a series of meta-regressions to examine the effects of study, populations, and intervention characteristics on effect size. Specifically, we included a single factor of interest (study quality [good versus fair], link to primary care [Y/N], intervention intensity [continuous and high- versus medium- and low-intensity], and intervention duration [continuous]) in each meta-regression model. Two-level variables were entered as 1/0 dummy variables and 3-level variables were converted to two 1/0 dummy variables with reference groups selected on the basis of interpretability of results. There was some evidence that intervention intensity was correlated with the effect estimates; therefore, we stratified the studies according to their intensity category (high, medium, or low) and sorted studies within these groups by intervention focus.

To estimate the relationship between differences in intermediate outcomes and associated health outcomes, we relied upon estimates from very large individual participant data meta-analyses of observational studies (IPA MA).^19, 234, 235, 238, 239^ These analyses reported the difference in risk for a relevant health outcome (e.g., ischemic heart disease or stroke death), consistently expressed as HRs, for given increments of difference in an intermediate outcome (e.g., 20 mm Hg, 5 kg/m^2^). Reported increments of difference for intermediate outcomes were much larger than changes in our pooled analyses, so we converted these to smaller increments more comparable with our results. Conversions were made using the formula:

HRc=exp(ln(HRo)/Io*Ic)

where HRc is the converted HR, HRo is the originally reported HR, Io is the original increment for HR calculation, and Ic is the increment to which the HR was converted. The CIs were also converted accordingly using the formula LBc=exp(ln(LBo)/Io*Ic) and UBc=exp(ln(UBo)/Io*Ic), where LBo and LBc are the original and converted lower bounds of the CI and UBo and UBc are the original and converted upper bounds of the CI, respectively. To ensure face validity we cross-checked our formula by applying it to any additional reported increments and associated HRs in the source IPD MA.

We used Stata version 13.1 (Stata Corp LP, College Station, TX) for all quantitative analyses. All significance testing was two-sided and results were considered statistically significant if the p-value was 0.05 or less.