# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

/ = MeSH subject heading

$ = truncation

* = truncation

? = wildcard

ab = word in abstract

adj# = adjacent within x number of words

ae = adverse effects

hw = subject heading word

id = identifier

kw = keyword

md = methodology

near/# = adjacent within x number of words

ti = word in title

### Cochrane Central Register of Controlled Clinical Trials (CENTRAL)

Issue 3 of 12, May 2016

#1 | diet:ti
#2 | diets:ti
#3 | dietary:ti
#4 | exercis*:ti
#5 | "physical activity":ti,ab,kw
#6 | fruit*:ti,ab,kw
#7 | vegetable*:ti,ab,kw
#8 | sedentary:ti,ab,kw next (lifestyle* or (life next style*) or behavior* or behaviour* or time):ti,ab,kw
#9 | (sitting or lying):ti,ab,kw near/2 time:ti,ab,kw
#10 | “screen time”:ti,ab,kw
#11 | (television or tv):ti,ab,kw next viewing:ti,ab,kw
#12 | (watch* or view*):ti,ab,kw next (television or tv):ti,ab,kw
#13 | (computer or internet):ti,ab,kw next (time or use or usage):ti,ab,kw
#14 | (computer or video):ti,ab,kw next game*:ti,ab,kw
#15 | (screen or screen-based):ti,ab,kw next (entertainment or behavior* or behaviour* or use or usage):ti,ab,kw
#16 | (low next energy next expenditure*):ti,ab,kw
#17 | (physical* next inactiv*):ti,ab,kw
#18 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17
#19 | counsel*:ti,ab,kw
#20 | (Behavio* next therap*):ti,ab,kw
#21 | (cognitive next therap*):ti,ab,kw
#22 | advice.ti,ab,kw
#23 | (Behavio* next chang*):ti,ab,kw
#24 | (Behavio* next modification*):ti,ab,kw
#25 | Referral:ti,ab,kw
#26 | “life style”:ti,ab,kw
#27 | lifestyle:ti,ab,kw
#28 | #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27
#29 | #18 and #28 Publication Year from 2013 to 2016, in Trials

### Medline (via Ovid)

Database: Ovid MEDLINE(R) <1946 to May Week 1 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < May 25, 2016>, Ovid MEDLINE(R) Daily Update <May 25, 2016>

1 | Diet, Reducing/
2 | Diet, Fat-Restricted/
3 | Diet, Mediterranean/
4 | Diet, Sodium-Restricted/
5 | Diet, Carbohydrate-Restricted/
6 | Caloric Restriction/
7 | Fruit/
8 | Vegetables/
9 | Diet Therapy/
10 | Food Habits/
11 | Exercise/
12 | Exercise Therapy/
13 | Motor Activity/
14 | Physical Fitness/
15 | Walking/
16 | (diet or dietary).ti.
17 | (fruit$ or vegetable$).ti.
18 | (exercise or physical activity).ti.
19 | walking.ti.
20 | Sedentary lifestyle/
21 | (sedentary adj (lifestyle$ or life style$ or behavio$ or time)).ti.
22 | ((sitting or lying) adj2 time).ti.
23 | Screen time.ti.
24 | Television/
25 | Computers/
26 | Video games/
27 | ((television or TV) adj viewing).ti.
28 | ((watch$ or view$) adj (television or TV)).ti.
29 | ((computer or internet) adj (time or "use" or usage)).ti.
30 | ((computer or video) adj game$).ti.
31 | (screen adj (entertainment or behavio$ or "use" or usage)).ti.
32 | low energy expenditure$.ti.
33 | physical$ inactiv$.ti.
34 | or/1–33
35 | Counseling/
36 | Directive Counseling/
37 | “Behavior-Therapy”/
38 | Cognitive Therapy/
39 | “Referral and Consultation”/
40 | Persuasive Communication/
41 | Social Control, Informal/
42 | Risk Reduction Behavior/
43 | Life Style/
44 | Motivation/
45 | Social Support/
46 | Feedback, Psychological/
47 | Self Efficacy/
48 | Health Knowledge, Attitudes, Practice/
49 | Health Behavior/
50 | Health Education/
51 | Health Promotion/
52 | Patient Education as Topic/
53 | counsel$.ti,ab.
54 | advice.ti,ab.
55 | (behavio$ adj (therap$ or chang$ or modification$)).ti,ab.
56 | referral.ti,ab.
57 | (life style or lifestyle).ti,ab.
58 | motivation$.ti,ab.
59 | health behavio$.ti,ab.
60 | health education.ti,ab.
61 | health promotion.ti,ab.
62 | patient education.ti,ab.
63 | nonpharmacologic intervention$.ti,ab.
64 | non pharmacologic intervention$.ti,ab.
65 | or/35–64
66 | 34 and 65
67 | limit 66 to (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial)
68 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (
69 | Meta-Analysis as Topic/
70 | (control$ adj3 trial$).ti,ab.
71 | random$.ti,ab.
72 | clinical trial$.ti,ab.
73 | meta analy$.ti,ab.
74 | 68 or 69 or 70 or 71 or 72 or 73
75 | 66 and 74
76 | 67 or 75
77 | limit 76 to english language
78 | limit 77 to yr="2013 – Current"
79 | remove duplicates from 78
80 | (harm or harms or harmful or harmed).ti,ab.
81 | (risky behavior$ or risky behaviour$).ti,ab.
82 | (adverse effects or mortality).fs.
83 | Mortality/
84 | Morbidity/
85 | death/
86 | Athletic injuries/
87 | Malnutrition/
88 | nutritional defici$.ti,ab.
89 | (death or deaths).ti,ab.
90 | fracture$.ti,ab,hw.
91 | 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90
92 | 66 and 91
93 | case-control studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/
94 | case control$.ti,ab.
95 | cohort.ti,ab.
96 | longitudinal.ti,ab.
97 | (follow-up or followup).ti,ab.
98 | prospective$.ti,ab.
99 | (comparison group$ or control group$).ti,ab.
100 | observational.ti,ab.
101 | retrospective studies/
102 | retrospective$.ti,ab.
103 | database$.ti,ab.
104 | nonrandomi$.ti,ab.
105 | population$.ti,ab.
106 | 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105
107 | 92 and 106
108 | limit 107 to english language
109 | limit 108 to yr="2013 – Current"
110 | remove duplicates from 109
111 | 79 or 110
112 | limit 111 to "all child (0 to 18 years)"
113 | limit 111 to "all adult (19 plus years)"
114 | 112 not 113
115 | 111 not 114
116 | Animals/ not (Humans/ and Animals/)
117 | 115 not 116

### PsycInfo (via Ovid)

Database: PsycINFO <1806 to May Week 3 2016>

1 | Diets/
2 | Dietary Restraint/
3 | Eating Behavior/
4 | fruit$.ti,ab,id,hw.
5 | vegetable$.ti,ab,id,hw.
6 | Exercise/
7 | Physical Activity/
8 | Aerobic Exercise/
9 | Walking/
10 | physical activity.ti,ab,id,hw.
11 | Activity Level/
12 | (sedentary adj (lifestyle$ or life style$ or behavio$ or time)).ti,ab,id,hw.
13 | ((sitting or lying) adj2 time).ti,ab,id,hw.
14 | Television/
15 | Television Viewing/
16 | Computers/
17 | Computer Games/
18 | Role Playing Games/
19 | Simulation Games/
20 | ((television or TV) adj viewing).ti,ab,id,hw.
21 | ((watch$ or view$) adj (television or TV)).ti,ab,id,hw.
22 | ((computer or internet) adj (time or "use" or usage)).ti,ab,id,hw.
23 | ((computer or video) adj game$).ti,ab,id,hw.
24 | (screen adj (entertainment or behavio$ or "use" or usage)).ti,ab,id,hw.
25 | low energy expenditure$.ti,ab,id,hw.
26 | physical$ inactiv$.ti,ab,id,hw.
27 | or/1–26
28 | behavior therapy/
29 | cognitive behavior therapy/
30 | cognitive therapy/
31 | Cognitive Techniques/
32 | Behavior Modification/
33 | Behavior Change/
34 | Lifestyle Changes/
35 | Lifestyle/
36 | Persuasive Communication/
37 | Motivation/
38 | Motivational Interviewing/
39 | Self Efficacy/
40 | Health Knowledge/
41 | Health Behavior/
42 | Health Education/
43 | Health Promotion/
44 | Client Education/
45 | counseling/
46 | counseling.id.
47 | counselling.id.
48 | advice.ti,ab,id,hw.
49 | or/28–48
50 | 27 and 49
51 | controlled trial$.ti,ab,id,hw.
52 | clinical trial$.ti,ab,id,hw.
53 | random$.ti,ab,id,hw.
54 | treatment outcome clinical trial.md.
55 | or/51–54
56 | 50 and 55
57 | (harm or harms or harmful or harmed).ti,ab,id,hw.
58 | (risky behavior$ or risky behaviour$).ti,ab,id,hw.
59 | adverse effect$.ti,ab,id,hw.
60 | mortality.ti,ab,id,hw.
61 | morbidity.ti,ab,id,hw.
62 | death.ti,ab,id,hw.
63 | Nutritional Defici$.ti,ab,id,hw.
64 | fracture$.ti,ab,id,hw.
65 | cardiovascular.ti,ab,id,hw.
66 | injur$.ti,ab,id,hw.
67 | or/57–66
68 | 50 and 67
69 | case control$.ti,ab,id,hw.
70 | cohort.ti,ab,id,hw.
71 | longitudinal.ti,ab,id,hw.
72 | (follow-up or followup).ti,ab,id,hw.
73 | prospective$.ti,ab,id,hw.
74 | (comparison group$ or control group$).ti,ab,id,hw.
75 | observational.ti,ab,id,hw.
76 | retrospective$.ti,ab,id,hw.
77 | database$.ti,ab,id,hw.
78 | nonrandomi$.ti,ab,id,hw.
79 | population$.ti,ab,id,hw.
80 | or/69–79
81 | 68 and 80
82 | 56 or 81
83 | limit 82 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <2 to 23 mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
84 | limit 82 to ("300 adulthood <age 18 yrs and older>" or 320 young adulthood <age 18 to 29 yrs> or 340 thirties <age 30 to 39 yrs> or 360 middle age <age 40 to 64 yrs> or "380 aged <age 65 yrs and older>" or "390 very old <age 85 yrs and older>")
85 | 83 not 84
86 | 82 not 85
87 | limit 86 to (english language and yr="2013 – Current")

### PubMed, publisher-supplied records

#44 | Search #43 AND publisher[sb] AND English[Language] AND ("2013"[Date - Publication] : "3000"[Date - Publication])
#43 | Search #33 OR #42
#42 | Search #31 AND #41
#41 | Search #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40
#40 | Search fracture*[tiab]
#39 | Search death[tiab] OR deaths[tiab]
#38 | Search nutritional defici*[tiab]
#37 | Search injury[tiab] OR injuries[tiab]
#36 | Search risky behavio*[tiab]
#35 | Search complication*[tiab]
#34 | Search (harm*[tiab] OR adverse event*[tiab] OR adverse effect*[tiab] OR adverse outcome*[tiab])
#33 | Search #31 AND #32
#32 | Search trial[tiab] OR trials[tiab] OR random*[tiab] OR metaanaly*[tiab] OR "meta analysis"[tiab] OR "meta analyses"[tiab] OR "meta analytic"[tiab] OR systematic[tiab]
#31 | Search #14 AND #30
#30 | Search #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29
#29 | Search "patient education" [tiab]
#28 | Search "health promotion" [tiab]
#27 | Search "health education" [tiab]
#26 | Search "health behaviours" [tiab]
#25 | Search "health behaviour" [tiab]
#24 | Search "health behaviors" [tiab]
#23 | Search "health behavior" [tiab]
#22 | Search motivation* [tiab]
#21 | Search "life style"[tiab] OR lifestyle[tiab]
#20 | Search referral[tiab]
#19 | Search behavio*[tiab] AND modification*[tiab]
#18 | Search behavio*[tiab] AND change[tiab]
#17 | Search behavio*[tiab] AND therapy[tiab]
#16 | Search advice[tiab]
#15 | Search counsel*[tiab]
#14 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13
#13 | Search physical* inactiv*[ti]
#12 | Search energy expenditure*[ti]
#11 | Search screen[ti] AND (entertainment[ti] OR behavio*[ti] OR use[ti] OR usage[ti])
#10 | Search (computer[ti] OR video[ti]) AND game*[ti]
#9 | Search (computer[ti] OR internet[ti]) AND (time[ti] OR use[ti] OR usage[ti])
#8 | Search (television[ti] OR tv[ti]) AND (watch*[ti] OR view*[ti])
#7 | Search “screen time”[ti]
#6 | Search ((sitting[ti] OR lying[ti]) AND time[ti])
#5 | Search sedentary[ti]
#4 | Search walking[ti]
#3 | Search exercise[ti] OR "physical activity"[ti]
#2 | Search fruit*[ti] OR vegetable*[ti]
#1 | Search diet[ti] OR dietary[ti]

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 5,235 citations identified through literature databases. An additional 55 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, 4,221 citations were from the 2014 USPSTF Healthy Lifestyle-High Risk review, and 109 citations were moved forward from the 2010 USPSTF Healthy Lifestyle review. After duplicates were removed, 10,045 unique citations were screened at the title/abstract stage. The full text of 351 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=12), Key Question 2 (k=34), Key Question 3 (k=86), and Key Question 4 (k=14). Reasons for excluding the other articles are available in Appendix D.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Study aim | Primary prevention of CVD | - Secondary or tertiary prevention of CVD; - Weight loss^*^; - Cancer prevention or treatment; - Prevention of cognitive decline; - Prevention of falls; - Smoking cessation
Condition definition | - A healthful diet includes dietary patterns that emphasize vegetables, fruits, whole grains, legumes, and nuts; include low-fat dairy products and seafood; limit sodium, saturated fat, refined grains, and sugar-sweetened foods and beverages; and have lower in amounts of red and processed meats.; - Physical activity is defined as any bodily movement produced by the contraction of skeletal muscle that increases energy expenditure. For the purposes of this review, physical activity includes aerobic and muscle-strengthening physical activity.; - Sedentary behavior refers to behavior characterized by minimal energy expenditure while in a sitting or reclining posture. | Aspects of a healthful diet that are out of scope include:; - Dietary calcium and other vitamin, micronutrient, and antioxidant supplementation; - Alcohol moderation; Aspects of physical activity that are out of scope include:; - Balance; - Flexibility; - Gait
Populations | Adults age >18 years without known CVD, hypertension, dyslipidemia, impaired fasting glucose/glucose tolerance, and/or smoking, or those who are high risk based on a cardiovascular risk assessment tool, including:; - Persons who are unselected; - Persons who have suboptimal behavior (e.g., poor dietary intake, not meeting recommended levels of physical activity, high levels of sedentary time); - Persons who are at increased risk for CVD (e.g., due to family history, overweight [BMI of 25.0 to 29.9 kg/m^2^] or obesity [BMI of ≥30 kg/m^2^], high-normal blood pressure) | Studies limited to:; - Adults with known CVD or diabetes mellitus; - Adults with other known chronic diseases (e.g., cancer, chronic kidney disease, severe mental illness, cognitive impairment); - Adults with known traditional, modifiable CVD risk factors (i.e., hypertension, dyslipidemia, impaired fasting glucose/glucose tolerance, smoking); adults at high risk for CVD based on a cardiovascular risk assessment tool; or trial inclusion criteria specifies that the population has ≥1 CVD risk factors; - Children and adolescents; - Parents (if intended behavior change is directed toward children); - Pregnant women; - Institutionalized adults
Settings | Conducted in or recruited from primary care or a health care system or could feasibly be implemented in or referred from primary care | Conducted in or recruited from settings not generalizable to primary care (e.g., worksites, university classrooms, institutional settings, community-wide settings) or in a population with pre-existing social ties (e.g., from the same worksite or church), or in a setting that could not be reproduced in primary care or within a broader health system
Interventions | - Behavioral counseling intervention alone or as part of a larger multicomponent intervention on healthful diet and nutrition, physical activity, sedentary behavior, or a combination, including but not limited to: assessment with feedback, advice, collaborative goal-setting, assistance, exercise prescriptions (referral to exercise facility or program), or arranging further contacts; - Interventions may be delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer-based, text messages) and can be delivered by a number of potential interventionists, including but not limited to: physicians, nurses, exercise specialists, dietitians, nutritionists, and behavioral health specialists | - Supervised exercise; - Controlled diet (i.e., feeding trials or providing food to participants); - Dietary supplements; - Stress management interventions (e.g., meditation, yoga, tai chi); - Prenatal or postnatal dietary counseling; - Broader community-based programs (e.g., mass media, social marketing, changes to the community built environment, legislation)
Comparisons | - No intervention (e.g., wait-list control, usual care); - Minimal intervention (e.g., usual care limited to ≤15 minutes of information or pamphlets); - Attention control (e.g., similar format and intensity of intervention on a different content area) | - Active comparators without a control (as defined above); - Studies in which the control group is instructed not to exercise
Outcomes | KQ 1: Health outcomes (i.e., CVD events [stroke, myocardial infarction], cardiovascular and all-cause mortality, health-related quality of life [physical and mental health–related quality of life]) KQ 2: Intermediate outcomes (e.g., blood pressure, lipid levels, glucose levels, weight, BMI, waist circumference) KQ 3: Behavioral outcomes (i.e., physical activity, dietary intake or patterns, sedentary behavior) KQ 4: Adverse outcomes, including any harms requiring unexpected or unwanted medical attention (e.g., nutritional deficiencies, musculoskeletal injuries, cardiovascular events) | Knowledge, attitudes, and self-efficacy
Timing of outcome assessment | KQs 1–3: ≥6 months after baseline KQ 4: No minimum followup | KQs 1–3: <6 months after baseline
Countries | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Study designs | KQs 1–3: Systematic reviews, individual and cluster RCTs, nonrandomized CCTs KQ 4: Systematic reviews, RCTs, CCTs, large comparative cohort or case-control studies with appropriate comparison group, large event-monitoring studies | KQs 1–3: Any observational studies KQ 4: Ecological studies, case-series, case reports
Publication date | Trials whose primary results were published from 1990 to present | Trials whose primary results were published prior to 1990
Publication language | English | Non-English
Study quality | Fair or good | Poor (according to design-specific USPSTF criteria)

* Studies that focus on the effectiveness of primary care interventions for weight management are included in a separate review commissioned by the USPSTF on screening for and management of adult obesity.

Abbreviations: CCT=controlled clinical trial; CVD=cardiovascular disease; RCT=randomized, controlled trial; USPSTF=U.S. Preventive Services Task Force.

Appendix A Table 2 Quality Assessment Criteria of Randomized, Controlled Trials

USPSTF Quality Rating Criteria
- Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered; - Intention-to-treat analysis