# References

1 National Comprehensive Cancer Network Clinical Practice Guidelines in Oncology (NCCN Guidelines)2014.
2 Davies L, Welch HG. Current thyroid cancer trends in the United States. JAMA Otolaryngol Head Neck Surg. 2014 Apr;140(4):317-22. PMID: 24557566.24557566
3 Eden K, Mahon S, Helfand M. Screening high-risk populations for thyroid cancer. Med Pediatr Oncol. 2001 May;36(5):583-91. PMID: 11340616.11340616
4 Dean DS, Gharib H. Epidemiology of thyroid nodules. Best practice & research Clinical endocrinology & metabolism. 2008 Dec;22(6):901-11. PMID: 19041821.19041821
5 Haugen BRM, Alexander EK, Bible KC, Doherty G, Mandel SJ, Nikiforov YE, . 2015 American Thyroid Association Management Guidelines for Adult Patients with Thyroid Nodules and Differentiated Thyroid Cancer. Thyroid 2015 Oct 14. PMID: 26462967.26462967
6 SEER Stat Fact Sheets: Thyroid Cancer. http://seer.cancer.gov/statfacts/html/thyro.html: Surveillance, Epidemiology and End Results Program; 2014 [cited 2014 November 30, 2015].
7 Schneider DF, Chen H. New developments in the diagnosis and treatment of thyroid cancer. CA Cancer J Clin 2013 Nov-Dec;63(6):374-94. PMID: 23797834.23797834
8 What are the key statistics about thyroid cancer? : American Cancer Society 2015 [cited 2015 November 30, 2015]; Available from: http://www.cancer.org/cancer/thyroidcancer/detailedguide/thyroid-cancer-key-statistics.
9 Aschebrook-Kilfoy B, Schechter RB, Shih YC, Kaplan EL, Chiu BC, Angelos P, . The clinical and economic burden of a sustained increase in thyroid cancer incidence. Cancer Epidemiol Biomarkers Prev. 2013 Jul;22(7):1252-9. PMID: 23677575.23677575
10 Cooper DS, Doherty GM, Haugen BR, Kloos RT, Lee SL, Mandel SJ, . Revised American Thyroid Association management guidelines for patients with thyroid nodules and differentiated thyroid cancer.[Erratum appears in Thyroid. 2010 Aug;20(8):942 Note: Hauger, Bryan R [corrected to Haugen, Bryan R]], [Erratum appears in Thyroid. 2010 Jun;20(6):674-5]. Thyroid. 2009 Nov;19(11):1167-214. PMID: 19860577.19860577
11 Hughes DT, Doherty GM. Central neck dissection for papillary thyroid cancer. Cancer Control. 2011 Apr;18(2):83-8. PMID: 21451450.21451450
12 Xing MM. Thyroid carcinoma. 2012 [updated September 10, 2012; cited August 5 2014]; Available from: https://www.clinicalkey.com/#!/content/medical_topic/21-s2.0-1014684.
13 Malchoff CD, Malchoff DM. Familial nonmedullary thyroid carcinoma. Cancer Control. 2006 Apr;13(2):106-10. PMID: 16735984.16735984
14 World Health Organization. International classification of diseases for oncology (ICD-O)–3rd edition, 1st revision. 2013. PMID.
15 Pelizzo M, Boschin I, Bernante P, Toniato A, Piotto A, Pagetta C, . Natural history, diagnosis, treatment and outcome of medullary thyroid cancer: 37 years experience on 157 patients. European Journal of Surgical Oncology (EJSO). 2007;33(4):493-7. PMID.17125960
16 Saad MF, Ordonez NG, Rashid RK, Guido JJ, Hill CS Jr., Hickey RC, . Medullary carcinoma of the thyroid. A study of the clinical features and prognostic factors in 161 patients. Medicine (Baltimore). 1984 Nov;63(6):319-42. PMID: 6503683.6503683
17 Kebebew E, Ituarte PH, Siperstein AE, Duh QY, Clark OH. Medullary thyroid carcinoma: clinical characteristics, treatment, prognostic factors, and a comparison of staging systems. Cancer. 2000 Mar 1;88(5):1139-48. PMID: 10699905.10699905
18 Pellegriti G, Frasca F, Regalbuto C, Squatrito S, Vigneri R. Worldwide increasing incidence of thyroid cancer: update on epidemiology and risk factors. Journal of cancer epidemiology. 2013;2013:965212. PMID: 23737785.23737785
19 Schonfeld SJ, Lee C, Berrington de Gonzalez A. Medical exposure to radiation and thyroid cancer. Clin Oncol (R Coll Radiol). 2011 May;23(4):244-50. PMID: 21296564.21296564
20 Ron E, Lubin JH, Shore RE, Mabuchi K, Modan B, Pottern LM, . Thyroid cancer after exposure to external radiation: a pooled analysis of seven studies. 1995. Radiat Res. 2012 Aug;178(2):AV43-60. PMID: 22870979.22870979
21 Little MP, Wakeford R, Tawn EJ, Bouffler SD, Berrington de Gonzalez A. Risks associated with low doses and low dose rates of ionizing radiation: why linearity may be (almost) the best we can do. Radiology. 2009 Apr;251(1):6-12. PMID: 19332841.19332841
22 Safety Xray and CT exams. http://www.radiologyinfo.org/en/safety/?pg=sfty_xray2014 [cited October 7, 2014].
23 Oakley GM, Curtin K, Layfield L, Jarboe E, Buchmann LO, Hunt JP. Increased melanoma risk in individuals with papillary thyroid carcinoma. JAMA Otolaryngol Head Neck Surg. 2014 May;140(5):423-7. PMID: 24626334.24626334
24 Pal T, Vogl FD, Chappuis PO, Tsang R, Brierley J, Renard H, . Increased risk for nonmedullary thyroid cancer in the first degree relatives of prevalent cases of nonmedullary thyroid cancer: a hospital-based study. J Clin Endocrinol Metab. 2001 Nov;86(11):5307-12. PMID: 11701697.11701697
25 Jasperson KW, Burt RW. APC-Associated Polyposis Conditions. In: Pagon RA, Adam MP, Ardinger HH, Bird TD, Dolan CR, Fong CT, ., editors. GeneReviews(R). Seattle WA: University of Washington, Seattle; 1993.
26 Krampitz GW, Norton JA. RET gene mutations (genotype and phenotype) of multiple endocrine neoplasia type 2 and familial medullary thyroid carcinoma. Cancer. 2014 Jul 1;120(13):1920-31. PMID: 24699901.24699901
27 Quadbeck B, Pruellage J, Roggenbuck U, Hirche H, Janssen OE, Mann K, . Long-term follow-up of thyroid nodule growth. Exp Clin Endocrinol Diabetes. 2002 Oct;110(7):348-54. PMID: 12397534.12397534
28 Sciuto R, Romano L, Rea S, Marandino F, Sperduti I, Maini C. Natural history and clinical outcome of differentiated thyroid carcinoma: a retrospective analysis of 1503 patients treated at a single institution. Annals of oncology. 2009;20(10):1728-35. PMID: 19773250.19773250
29 Sipos JA, Mazzaferri EL. Thyroid cancer epidemiology and prognostic variables. Clin Oncol (R Coll Radiol). 2010 Aug;22(6):395-404. PMID: 20627675.20627675
30 Lee YS, Lim H, Chang H-S, Park CS. Papillary Thyroid Microcarcinomas Are Different from Latent Papillary Thyroid Carcinomas at Autopsy. J Korean Med Sci 2014 04/25;29(5):676-9. PMID: PMC4024958.24851024
31 Zaydfudim V, Feurer ID, Griffin MR, Phay JE. The impact of lymph node involvement on survival in patients with papillary and follicular thyroid carcinoma. Surgery. 2008 Dec;144(6):1070-7; discussion 7-8. PMID: 19041020.19041020
32 Ort S, Goldenberg D. Management of regional metastases in well-differentiated thyroid cancer. Otolaryngol Clin North Am. 2008 Dec;41(6):1207-18, xi. PMID: 19040980.19040980
33 Norman J. Papillary Cancer: Symptoms, Treatments and Prognosis for Papillary Thyroid Carcinoma. Endocrineweb2012 [cited 2014 October 27]; Available from: http://www.endocrineweb.com/conditions/thyroid-cancer/papillary-cancer.
34 Barbet J, Campion L, Kraeber-Bodere F, Chatal J-F, Group GTES. Prognostic impact of serum calcitonin and carcinoembryonic antigen doubling-times in patients with medullary thyroid carcinoma. J Clin Endocrinol Metab. 2005 Nov;90(11):6077-84. PMID: 16091497.16091497
35 Laure Giraudet A, Al Ghulzan A, Auperin A, Leboulleux S, Chehboun A, Troalen F, . Progression of medullary thyroid carcinoma: assessment with calcitonin and carcinoembryonic antigen doubling times. Eur J Endocrinol. 2008 Feb;158(2):239-46. PMID: 18230832.18230832
36 Pelizzo MR, Boschin IM, Toniato A, Piotto A, Pagetta C, Gross MD, . Papillary thyroid carcinoma: 35-year outcome and prognostic factors in 1858 patients. Clinical nuclear medicine. 2007 Jun;32(6):440-4. PMID: 17515749.17515749
37 Tan RK, Finley RK, 3rd, Driscoll D, Bakamjian V, Hicks WL, Jr., Shedd DP. Anaplastic carcinoma of the thyroid: a 24-year experience. Head Neck 1995 Jan-Feb;17(1):41-7; discussion 7-8. PMID: 7883548.7883548
38 McIver B, Hay ID, Giuffrida DF, Dvorak CE, Grant CS, Thompson GB, . Anaplastic thyroid carcinoma: a 50-year experience at a single institution. Surgery. 2001 Dec;130(6):1028-34. PMID: 11742333.11742333
39 Tennvall J, Lundell G, Wahlberg P, Bergenfelz A, Grimelius L, Akerman M, . Anaplastic thyroid carcinoma: three protocols combining doxorubicin, hyperfractionated radiotherapy and surgery. Br J Cancer. 2002 Jun 17;86(12):1848-53. PMID: 12085174.12085174
40 Smith-Bindman R, Lebda P, Feldstein VA, Sellami D, Goldstein RB, Brasic N, . Risk of thyroid cancer based on thyroid ultrasound imaging characteristics: results of a population-based study. JAMA Intern Med. 2013 Oct 28;173(19):1788-96. PMID: 23978950.23978950
41 Cramer JD, Fu P, Harth KC, Margevicius S, Wilhelm SM. Analysis of the rising incidence of thyroid cancer using the Surveillance, Epidemiology and End Results national cancer data registry. Surgery. 2010 Dec;148(6):1147-52; discussion 52-3. PMID: 21134545.21134545
42 Hughes DT, Haymart MR, Miller BS, Gauger PG, Doherty GM. The most commonly occurring papillary thyroid cancer in the United States is now a microcarcinoma in a patient older than 45 years. Thyroid. 2011 Mar;21(3):231-6. PMID: 21268762.21268762
43 Udelsman R, Zhang Y. The epidemic of thyroid cancer in the United States: the role of endocrinologists and ultrasounds. Thyroid. 2014 Mar;24(3):472-9. PMID: 23937391.23937391
44 Baloch ZW, Cibas ES, Clark DP, Layfield LJ, Ljung B-M, Pitman MB, . The National Cancer Institute Thyroid fine needle aspiration state of the science conference: a summation. Cytojournal. 2008 04/07;5:6-. PMID: PMC2365970.18394201
45 Iyer NG, Morris LG, Tuttle RM, Shaha AR, Ganly I. Rising incidence of second cancers in patients with low-risk (T1N0) thyroid cancer who receive radioactive iodine therapy. Cancer. 2011 Oct 1;117(19):4439-46. PMID: 21432843.21432843
46 Sawka AM, Thabane L, Parlea L, Ibrahim-Zada I, Tsang RW, Brierley JD, . Second primary malignancy risk after radioactive iodine treatment for thyroid cancer: a systematic review and meta-analysis. Thyroid. 2009 May;19(5):451-7. PMID: 19281429.19281429
47 Ahn HS, Kim HJ, Welch HG. Korea's thyroid-cancer “epidemic”--screening and overdiagnosis. New England journal of medicine. 2014 Nov 6;371(19):1765-7. PMID: 25372084.25372084
48 United Nations Development Programme. Human Development Index: 2013 Rankings. United Nations Development Programme; 2013 [cited 2014]; Available from: http://hdr.undp.org/en/2013-report.
49 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, . Current methods of the US Preventive Services Task Force: a review of the process. American journal of preventive medicine. 2001 Apr;20(3 Suppl):21-35. PMID: 11306229.11306229
50 Wells G, Shea B, O'connell D, Peterson J, Welch V, Losos M, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.
51 Whiting PF, Rutjes AW, Westwood ME, Mallett S, Deeks JJ, Reitsma JB, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529-36. PMID: 22007046.22007046
52 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003 Nov 10;3(1):25. PMID: 14606960.14606960
53 Bucci A, Shore-Freedman E, Gierlowski T, Mihailescu D, Ron E, Schneider AB. Behavior of small thyroid cancers found by screening radiation-exposed individuals. J Clin Endocrinol Metab. 2001 Aug;86(8):3711-6. PMID: 11502800.11502800
54 Ishida O, Izuo M, Ogawa T, Kurebayashi J, Satoh K. Evaluation of mass screening for thyroid cancer. Jpn J Clin Oncol. 1988 Dec;18(4):289-95. PMID: 3204679.3204679
55 Brander A, Viikinkoski P, Nickels J, Kivisaari L. Thyroid gland: US screening in a random adult population. Radiology. 1991 Dec;181(3):683-7. PMID: 1947082.1947082
56 Brander A, Viikinkoski P, Nickels J, Kivisaari L. Thyroid gland: US screening in middle-aged women with no previous thyroid disease. Radiology. 1989 Nov;173(2):507-10. PMID: 2678263.2678263
57 Kim SJ, Moon WK, Cho N. Sonographic criteria for fine-needle aspiration cytology in a Korean female population undergoing thyroid ultrasound screening. Acta Radiol. 2010 Jun;51(5):475-81. PMID: 20235746.20235746
58 Kim JY, Lee CH, Kim SY, Jeon WK, Kang JH, An SK, . Radiologic and pathologic findings of nonpalpable thyroid carcinomas detected by ultrasonography in a medical screening center. Journal of ultrasound in medicine. 2008 Feb;27(2):215-23. PMID: 18204012.18204012
59 Suehiro F. Thyroid cancer detected by mass screening over a period of 16 years at a health care center in Japan. Surgery today. 2006;36(11):947-53. PMID: 17072713.17072713
60 Chung WY, Chang HS, Kim EK, Park CS. Ultrasonographic mass screening for thyroid carcinoma: a study in women scheduled to undergo a breast examination. Surgery today. 2001;31(9):763-7. PMID: 11686552.11686552
61 Lee HK, Hur MH, Ahn SM. Diagnosis of occult thyroid carcinoma by ultrasonography. Yonsei medical journal. 2003 Dec 30;44(6):1040-4. PMID: 14703614.14703614
62 Ron E, Lubin E, Modan B. Screening for early detection of radiation-associated thyroid cancer: a pilot study. Isr J Med Sci. 1984 Dec;20(12):1164-8. PMID: 6519948.6519948
63 Shimaoka K, Bakri K, Sciascia M, Razack M, Rao U, Mettlin C, . Thyroid screening program; follow-up evaluation. N Y State J Med. 1982 Jul;82(8):1184-7. PMID: 6957738.6957738
64 Ron E, Modan B, Preston D, Alfandary E, Stovall M, Boice JD, Jr. Thyroid neoplasia following low-dose radiation in childhood. Radiat Res. 1989 Dec;120(3):516-31. PMID: 2594972.2594972
65 Hobbs HA, Bahl M, Nelson RC, Eastwood JD, Esclamado RM, Hoang JK. Applying the Society of Radiologists in Ultrasound recommendations for fine-needle aspiration of thyroid nodules: effect on workup and malignancy detection. AJR American Journal of Roentgenology. 2014 Mar;202(3):602-7. PMID: 24555597.24555597
66 Ito Y, Tomoda C, Uruno T, Takamura Y, Miya A, Kobayashi K, . Needle tract implantation of papillary thyroid carcinoma after fine-needle aspiration biopsy. World journal of surgery. 2005 Dec;29(12):1544-9. PMID: 16311845.16311845
67 Abu-Yousef MM, Larson JH, Kuehn DM, Wu AS, Laroia AT. Safety of ultrasound-guided fine needle aspiration biopsy of neck lesions in patients taking antithrombotic/anticoagulant medications. Ultrasound Q. 2011 Sep;27(3):157-9. PMID: 21873852.21873852
68 Frates MC, Benson CB, Charboneau JW, Cibas ES, Clark OH, Coleman BG, . Management of thyroid nodules detected at US: Society of Radiologists in Ultrasound consensus conference statement. Radiology. 2005 Dec;237(3):794-800. PMID: 16304103.16304103
69 Davies L, Welch HG. Thyroid cancer survival in the United States: observational data from 1973 to 2005. Arch Otolaryngol Head Neck Surg. 2010 May;136(5):440-4. PMID: 20479371.20479371
70 Ito Y, Miyauchi A, Inoue H, Fukushima M, Kihara M, Higashiyama T, . An observational trial for papillary thyroid microcarcinoma in Japanese patients. World journal of surgery. 2010 Jan;34(1):28-35. PMID: 20020290.20020290
71 Ito Y, Uruno T, Nakano K, Takamura Y, Miya A, Kobayashi K, . An observation trial without surgical treatment in patients with papillary microcarcinoma of the thyroid. Thyroid. 2003 Apr;13(4):381-7. PMID: 12804106.12804106
72 Ito Y, Miyauchi A, Kihara M, Higashiyama T, Kobayashi K, Miya A. Patient age is significantly related to the progression of papillary microcarcinoma of the thyroid under observation. Thyroid. 2014 Jan;24(1):27-34. PMID: 24001104.24001104
73 Oda H, Miyauchi A, Ito Y, Yoshioka K, Nakayama A, Sasai H, . Incidences of Unfavorable Events in the Management of Low-Risk Papillary Microcarcinoma of the Thyroid by Active Surveillance Versus Immediate Surgery. Thyroid. 2016 Jan;26(1):150-5. PMID: 26426735.26426735
74 Tartaglia F, Blasi S, Giuliani A, Sgueglia M, Tromba L, Carbotta S, . Central neck dissection in papillary thyroid carcinoma: results of a retrospective study. Int J Surg. 2014;12 Suppl 1:S57-62. PMID: 24862662.24862662
75 Hyun SM, Song HY, Kim SY, Nam SY, Roh JL, Han MW, . Impact of combined prophylactic unilateral central neck dissection and hemithyroidectomy in patients with papillary thyroid microcarcinoma. Annals of surgical oncology. 2012 Feb;19(2):591-6. PMID: 21837525.21837525
76 Son YI, Jeong HS, Baek CH, Chung MK, Ryu J, Chung JH, . Extent of prophylactic lymph node dissection in the central neck area of the patients with papillary thyroid carcinoma: comparison of limited versus comprehensive lymph node dissection in a 2-year safety study. Annals of surgical oncology. 2008 Jul;15(7):2020-6. PMID: 18459004.18459004
77 Viola D, Materazzi G, Valerio L, Molinaro E, Agate L, Faviana P, . Prophylactic central compartment lymph node dissection in papillary thyroid carcinoma: clinical implications derived from the first prospective randomized controlled single institution study. J Clin Endocrinol Metab 2015 Jan 15:jc20143825. PMID: 25590215.25590215
78 Conzo G, Calo PG, Sinisi AA, De Bellis A, Pasquali D, Iorio S, . Impact of prophylactic central compartment neck dissection on locoregional recurrence of differentiated thyroid cancer in clinically node-negative patients: a retrospective study of a large clinical series. Surgery. 2014 Jun;155(6):998-1005. PMID: 24856120.24856120
79 Chang YW, Kim HS, Kim HY, Lee JB, Bae JW, Son GS. Should central lymph node dissection be considered for all papillary thyroid microcarcinoma? Asian journal of surgery / Asian Surgical Association. 2015 Apr 22. PMID: 25913730.25913730
80 Del Rio P, Maestroni U, Sianesi M, Viani L, Vicente D, Stojadinovic A, . Minimally invasive video-assisted thyroidectomy for papillary thyroid cancer: a prospective 5-year follow-up study. Tumori 2015 Mar-Apr;101(2):144-7. PMID: 25791536.25791536
81 Donatini G, Castagnet M, Desurmont T, Rudolph N, Othman D, Kraimps JL. Partial Thyroidectomy for Papillary Thyroid Microcarcinoma: Is Completion Total Thyroidectomy Indicated? World J Surg 2015 Nov 6. PMID: 26546190.26546190
82 Kwan WY, Chow TL, Choi CY, Lam SH. Complication rates of central compartment dissection in papillary thyroid cancer. ANZ J Surg. 2015 Apr;85(4):274-8. PMID: 23890372.23890372
83 Ahn D, Sohn JH, Park JY. Surgical complications and recurrence after central neck dissection in cN0 papillary thyroid carcinoma. Auris, nasus, larynx. 2014 Feb;41(1):63-8. PMID: 23886706.23886706
84 Boute P, Merlin J, Biet A, Cuvelier P, Strunski V, Page C. Morbidity of central compartment dissection for differentiated thyroid carcinoma of the follicular epithelium. Eur Ann Otorhinolaryngol Head Neck Dis. 2013 Nov;130(5):245-9. PMID: 23835075.23835075
85 Caliskan M, Park JH, Jeong JS, Lee CR, Park SK, Kang SW, . Role of prophylactic ipsilateral central compartment lymph node dissection in papillary thyroid microcarcinoma. Endocrine journal. 2012;59(4):305-11. PMID: 22240889.22240889
86 Calo PG, Medas F, Pisano G, Boi F, Baghino G, Mariotti S, . Differentiated thyroid cancer: indications and extent of central neck dissection--our experience. Int J Surg Oncol. 2013;2013:625193. PMID: 24282633.24282633
87 Chaplin JM, O'Brien CJ, McNeil EB, Haghighi K. Application of prognostic scoring systems in differentiated thyroid carcinoma. Aust N Z J Surg. 1999 Sep;69(9):625-8. PMID: 10515332.10515332
88 Cirocchi R, Boselli C, Guarino S, Sanguinetti A, Trastulli S, Desiderio J, . Total thyroidectomy with ultrasonic dissector for cancer: multicentric experience. World journal of surgical oncology. 2012;10:70. PMID: 22540914.22540914
89 Giordano D, Valcavi R, Thompson GB, Pedroni C, Renna L, Gradoni P, . Complications of central neck dissection in patients with papillary thyroid carcinoma: results of a study on 1087 patients and review of the literature. Thyroid. 2012 Sep;22(9):911-7. PMID: 22827494.22827494
90 Hartl DM, Mamelle E, Borget I, Leboulleux S, Mirghani H, Schlumberger M. Influence of prophylactic neck dissection on rate of retreatment for papillary thyroid carcinoma. World journal of surgery. 2013 Aug;37(8):1951-8. PMID: 23677562.23677562
91 Lee YS, Nam KH, Chung WY, Chang HS, Park CS. Postoperative complications of thyroid cancer in a single center experience. J Korean Med Sci. 2010 Apr;25(4):541-5. PMID: 20357995.20357995
92 Moo TA, Umunna B, Kato M, Butriago D, Kundel A, Lee JA, . Ipsilateral versus bilateral central neck lymph node dissection in papillary thyroid carcinoma. Annals of surgery. 2009 Sep;250(3):403-8. PMID: 19661784.19661784
93 Palestini N, Borasi A, Cestino L, Freddi M, Odasso C, Robecchi A. Is central neck dissection a safe procedure in the treatment of papillary thyroid cancer? Our experience. Langenbecks Arch Surg. 2008 Sep;393(5):693-8. PMID: 18592264.18592264
94 Raffaelli M, De Crea C, Sessa L, Giustacchini P, Revelli L, Bellantone C, . Prospective evaluation of total thyroidectomy versus ipsilateral versus bilateral central neck dissection in patients with clinically node-negative papillary thyroid carcinoma. Surgery. 2012 Dec;152(6):957-64. PMID: 23158170.23158170
95 Raj MD, Grodski S, Martin SA, Yeung M, Serpell JW. The role of fine-needle aspiration cytology in the surgical management of thyroid cancer. ANZ J Surg. 2010 Nov;80(11):827-30. PMID: 20969692.20969692
96 Shindo ML, Sinha UK, Rice DH. Safety of thyroidectomy in residency: a review of 186 consecutive cases. Laryngoscope. 1995 Nov;105(11):1173-5. PMID: 7475870.7475870
97 Sim R, Soo KC. Surgical treatment of thyroid cancer: the Singapore General Hospital experience. J R Coll Surg Edinb. 1998 Aug;43(4):239-43. PMID: 9735646.9735646
98 So YK, Son YI, Hong SD, Seo MY, Baek CH, Jeong HS, . Subclinical lymph node metastasis in papillary thyroid microcarcinoma: a study of 551 resections. Surgery. 2010 Sep;148(3):526-31. PMID: 20189620.20189620
99 Spear SA, Theler J, Sorensen DM. Complications after the surgical treatment of malignant thyroid disease. Mil Med. 2008 Apr;173(4):399-402. PMID: 18472632.18472632
100 Sywak M, Cornford L, Roach P, Stalberg P, Sidhu S, Delbridge L. Routine ipsilateral level VI lymphadenectomy reduces postoperative thyroglobulin levels in papillary thyroid cancer. Surgery. 2006 Dec;140(6):1000-5; discussion 5-7. PMID: 17188149.17188149
101 Yassa L, Cibas ES, Benson CB, Frates MC, Doubilet PM, Gawande AA, . Long-term assessment of a multidisciplinary approach to thyroid nodule diagnostic evaluation. Cancer. 2007 Dec 25;111(6):508-16. PMID: 17999413.17999413
102 Kim BS, Kang KH, Kang H, Park SJ. Central neck dissection using a bilateral axillo-breast approach for robotic thyroidectomy: comparison with conventional open procedure after propensity score matching. Surgical laparoscopy, endoscopy & percutaneous techniques. 2014 Feb;24(1):67-72. PMID: 24487161.24487161
103 Kim WW, Kim JS, Hur SM, Kim SH, Lee SK, Choi JH, . Is robotic surgery superior to endoscopic and open surgeries in thyroid cancer? World journal of surgery. 2011 Apr;35(4):779-84. PMID: 21253726.21253726
104 Shah MD, Witterick IJ, Eski SJ, Pinto R, Freeman JL. Quality of life in patients undergoing thyroid surgery. J Otolaryngol. 2006 Aug;35(4):209-15. PMID: 17176794.17176794
105 Francis D, Pearce E, Ni S, Garrett C, Penson D. Epidemiology of vocal fold paralyses after total thyroidectomy for well-differentiated thyroid cancer in a Medicare population. Otolaryngol Head Neck Surg. 2014 Apr;150(4):548-57. PMID: 24482349.24482349
106 Kwan WY, Chow TL, Choi CY, Lam SH. Complication rates of central compartment dissection in papillary thyroid cancer. ANZ J Surg 2013 Jul 26. PMID: 23890372.23890372
107 Zerey M, Prabhu AS, Newcomb WL, Lincourt AE, Kercher KW, Heniford BT. Short-term outcomes after unilateral versus complete thyroidectomy for malignancy: a national perspective. American surgeon. 2009 Jan;75(1):20-4. PMID: 19213391.19213391
108 Hundahl SA, Cady B, Cunningham MP, Mazzaferri E, McKee RF, Rosai J, . Initial results from a prospective cohort study of 5583 cases of thyroid carcinoma treated in the united states during 1996. U.S. and German Thyroid Cancer Study Group. An American College of Surgeons Commission on Cancer Patient Care Evaluation study. Cancer. 2000 Jul 1;89(1):202-17. PMID: 10897019.10897019
109 Holzer S, Reiners C, Mann K, Bamberg M, Rothmund M, Dudeck J, . Patterns of care for patients with primary differentiated carcinoma of the thyroid gland treated in Germany during 1996. U.S. and German Thyroid Cancer Group. Cancer. 2000 Jul 1;89(1):192-201. PMID: 10897018.10897018
110 Brown AP, Chen J, Hitchcock YJ, Szabo A, Shrieve DC, Tward JD. The risk of second primary malignancies up to three decades after the treatment of differentiated thyroid cancer. J Clin Endocrinol Metab. 2008 Feb;93(2):504-15. PMID: 18029468.18029468
111 Lang BH, Wong IO, Wong KP, Cowling BJ, Wan KY. Risk of second primary malignancy in differentiated thyroid carcinoma treated with radioactive iodine therapy. Surgery. 2012 Jun;151(6):844-50. PMID: 22341041.22341041
112 Hakala TT, Sand JA, Jukkola A, Huhtala HS, Metso S, Kellokumpu-Lehtinen PL. Increased risk of certain second primary malignancies in patients treated for well-differentiated thyroid cancer. Int J Clin Oncol 2015 Sep 26. PMID: 26410770.26410770
113 Khang AR, Cho SW, Choi HS, Ahn HY, Yoo WS, Kim KW, . The risk of second primary malignancy is increased in differentiated thyroid cancer patients with a cumulative (131)I dose over 37 GBq. Clinical endocrinology. 2015 Jul;83(1):117-23. PMID: 25115234.25115234
114 Lin CY, Lin CL, Huang WS, Kao CH. Risk of Breast Cancer in Patients With Thyroid Cancer Receiving or Not Receiving I-131 Treatment: A Nationwide Population-based Cohort Study. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. 2015 Dec 30. PMID: 26719377.26719377
115 Seo GH, Cho YY, Chung JH, Kim SW. Increased Risk of Leukemia After Radioactive Iodine Therapy in Patients with Thyroid Cancer: A Nationwide, Population-Based Study in Korea. Thyroid. 2015 Aug;25(8):927-34. PMID: 26133388.26133388
116 Ronckers CM, McCarron P, Ron E. Thyroid cancer and multiple primary tumors in the SEER cancer registries. Int J Cancer. 2005 Nov 1;117(2):281-8. PMID: 15880372.15880372
117 Hyer S, Kong A, Pratt B, Harmer C. Salivary gland toxicity after radioiodine therapy for thyroid cancer. Clin Oncol (R Coll Radiol). 2007 Feb;19(1):83-6. PMID: 17305259.17305259
118 Ish-Shalom S, Durleshter L, Segal E, Nagler RM. Sialochemical and oxidative analyses in radioactive I131-treated patients with thyroid carcinoma. European journal of endocrinology / European Federation of Endocrine Societies [serial on the Internet]. 2008; (5): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/362/CN-00631362/frame.html.
119 Jeong SY, Kim HW, Lee SW, Ahn BC, Lee J. Salivary gland function 5 years after radioactive iodine ablation in patients with differentiated thyroid cancer: direct comparison of pre- and postablation scintigraphies and their relation to xerostomia symptoms. Thyroid. 2013 May;23(5):609-16. PMID: 23153322.23153322
120 Solans R, Bosch JA, Galofre P, Porta F, Rosello J, Selva-O'Callagan A, . Salivary and lacrimal gland dysfunction (sicca syndrome) after radioiodine therapy. Journal of nuclear medicine. 2001 May;42(5):738-43. PMID: 11337569.11337569
121 Grewal RK, Larson SM, Pentlow CE, Pentlow KS, Gonen M, Qualey R, . Salivary gland side effects commonly develop several weeks after initial radioactive iodine ablation. Journal of nuclear medicine. 2009 Oct;50(10):1605-10. PMID: 19759114.19759114
122 Ryu CH, Ryu J, Ryu YM, Lee YJ, Lee EK, Kim SK, . Administration of Radioactive Iodine Therapy Within 1 Year After Total Thyroidectomy Does Not Affect Vocal Function. Journal of nuclear medicine. 2015 Oct;56(10):1480-6. PMID: 26272814.26272814
123 Lin CM, Doyle P, Tsan YT, Lee CH, Wang JD, Chen PC, . 131I treatment for thyroid cancer and risk of developing primary hyperparathyroidism: a cohort study. Eur J Nucl Med Mol Imaging. 2014 Feb;41(2):253-9. PMID: 23982456.23982456
124 Wu JX, Young S, Ro K, Li N, Leung AM, Chiu HK, . Reproductive outcomes and nononcologic complications after radioactive iodine ablation for well-differentiated thyroid cancer. Thyroid. 2015 Jan;25(1):133-8. PMID: 25289542.25289542
125 Lang BH, Wong KP. Risk factors for nonsynchronous second primary malignancy and related death in patients with differentiated thyroid carcinoma. Annals of surgical oncology. 2011 Dec;18(13):3559-65. PMID: 21573833.21573833
126 Jeannon JP, Orabi AA, Bruch GA, Abdalsalam HA, Simo R. Diagnosis of recurrent laryngeal nerve palsy after thyroidectomy: a systematic review. International journal of clinical practice. 2009 Apr;63(4):624-9. PMID: 19335706.19335706
127 Shan CX, Zhang W, Jiang DZ, Zheng XM, Liu S, Qiu M. Routine central neck dissection in differentiated thyroid carcinoma: a systematic review and meta-analysis. Laryngoscope. 2012 Apr;122(4):797-804. PMID: 22294492.22294492
128 Loyo M, Tufano RP, Gourin CG. National trends in thyroid surgery and the effect of volume on short-term outcomes. The Laryngoscope. 2013;123(8):2056-63. PMID.23737403
129 Gourin CG, Tufano RP, Forastiere AA, Koch WM, Pawlik TM, Bristow RE. Volume-based trends in thyroid surgery. Archives of Otolaryngology–Head & Neck Surgery. 2010;136(12):1191-8. PMID.21173367
130 Brown T, Sidhu S, Gill A, Robinson B, Learoyd D, Sywak M, . Increasing incidence of thyroid cancer is due to increased pathologic detection. Surgery. 2008 Dec;144(6):1038-43; discussion 43. PMID: 19041015.19041015
131 Rubino C, de Vathaire F, Dottorini ME, Hall P, Schvartz C, Couette JE, . Second primary malignancies in thyroid cancer patients. Br J Cancer. 2003 Nov 3;89(9):1638-44. PMID: 14583762.14583762
132 Sawka AM, Lakra DC, Lea J, Alshehri B, Tsang RW, Brierley JD, . A systematic review examining the effects of therapeutic radioactive iodine on ovarian function and future pregnancy in female thyroid cancer survivors. Clinical endocrinology. 2008 Sep;69(3):479-90. PMID: 18284643.18284643
133 Sawka AM, Lea J, Alshehri B, Straus S, Tsang RW, Brierley JD, . A systematic review of the gonadal effects of therapeutic radioactive iodine in male thyroid cancer survivors. Clinical endocrinology. 2008 Apr;68(4):610-7. PMID: 17973944.17973944
134 Cappelli C, Castellano M, Pirola I, Gandossi E, De Martino E, Cumetti D, . Thyroid nodule shape suggests malignancy. European Journal of Endocrinology. 2006 Jul;155(1):27-31. PMID: 16793946.16793946
135 Gul K, Ersoy R, Dirikoc A, Korukluoglu B, Ersoy PE, Aydin R, . Ultrasonographic evaluation of thyroid nodules: comparison of ultrasonographic, cytological, and histopathological findings. Endocrine. 2009 Dec;36(3):464-72. PMID: 19859839.19859839
136 Seo H, Na DG, Kim JH, Kim KW, Yoon JW. Ultrasound-Based Risk Stratification for Malignancy in Thyroid Nodules: A Four-Tier Categorization System. Eur Radiol 2015 Feb 14. PMID: 25680723.25680723
137 Brito JP, Gionfriddo MR, Al Nofal A, Boehmer KR, Leppin AL, Reading C, . The accuracy of thyroid nodule ultrasound to predict thyroid cancer: systematic review and meta-analysis. J Clin Endocrinol Metab. 2014 Apr;99(4):1253-63. PMID: 24276450.24276450
138 Moon WJ, Jung SL, Lee JH, Na DG, Baek JH, Lee YH, . Benign and malignant thyroid nodules: US differentiation--multicenter retrospective study. Radiology. 2008 Jun;247(3):762-70. PMID: 18403624.18403624
139 Kim JY, Lee CH, Kim SY, Jeon WK, Kang JH, An SK, . Radiologic and pathologic findings of nonpalpable thyroid carcinomas detected by ultrasonography in a medical screening center. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. 2008 Feb;27(2):215-23. PMID: 18204012.18204012
140 Bongiovanni M, Spitale A, Faquin WC, Mazzucchelli L, Baloch ZW. The Bethesda System for Reporting Thyroid Cytopathology: a meta-analysis. Acta Cytol. 2012;56(4):333-9. PMID: 22846422.22846422
141 Cibas ES, Ali SZ. The Bethesda system for reporting thyroid cytopathology. Am J Clin Pathol. 2009;132(5):658-65. PMID.19846805
142 Vashishta R, Mahalingam-Dhingra A, Lander L, Shin EJ, Shah RK. Thyroidectomy outcomes: a national perspective. Otolaryngol Head Neck Surg. 2012 Dec;147(6):1027-34. PMID: 22807486.22807486
143 Carter JL, Coletti RJ, Harris RP. Quantifying and monitoring overdiagnosis in cancer screening: a systematic review of methods. Bmj. 2015;350:g7773. PMID.25569206
144 Welch HG, Black WC. Overdiagnosis in cancer. J Natl Cancer Inst. 2010 May 5;102(9):605-13. PMID: 20413742.20413742
145 Brito JP, Morris JC, Montori VM. Thyroid cancer: zealous imaging has increased detection and treatment of low risk tumours. Bmj. 2013;347:f4706. PMID.23982465
146 La Vecchia C, Bosetti C, Malvezzi M, Garavello W, Bertuccio P, Levi F, . Author's reply to thyroid cancer: An epidemic of disease or an epidemic of diagnosis? Int J Cancer. 2014 Nov 1. PMID: 25363708.25363708
147 Ho AS, Davies L, Nixon IJ, Palmer FL, Wang LY, Patel SG, . Increasing diagnosis of subclinical thyroid cancers leads to spurious improvements in survival rates. Cancer 2015 Feb 24. PMID: 25712809.25633122
148 Davies L, Welch HG. Increasing incidence of thyroid cancer in the United States, 1973-2002. Jama. 2006 May 10;295(18):2164-7. PMID: 16684987.16684987
149 Leenhardt L, Grosclaude P, Cherie-Challine L, Thyroid Cancer C. Increased incidence of thyroid carcinoma in france: a true epidemic or thyroid nodule management effects? Report from the French Thyroid Cancer Committee. Thyroid. 2004 Dec;14(12):1056-60. PMID: 15650358.15650358
150 Burgess JR. Temporal trends for thyroid carcinoma in Australia: an increasing incidence of papillary thyroid carcinoma (1982-1997). Thyroid. 2002 Feb;12(2):141-9. PMID: 11916283.11916283
151 Liu S, Semenciw R, Ugnat AM, Mao Y. Increasing thyroid cancer incidence in Canada, 1970-1996: time trends and age-period-cohort effects. Br J Cancer. 2001 Nov 2;85(9):1335-9. PMID: 11720471.11720471
152 Davies L, Ouellette M, Hunter M, Welch HG. The increasing incidence of small thyroid cancers: where are the cases coming from? Laryngoscope. 2010 Dec;120(12):2446-51. PMID: 21108428.21108428
153 Morris LG, Myssiorek D. Improved detection does not fully explain the rising incidence of well-differentiated thyroid cancer: a population-based analysis. Am J Surg. 2010 Oct;200(4):454-61. PMID: 20561605.20561605
154 Enewold L, Zhu K, Ron E, Marrogi AJ, Stojadinovic A, Peoples GE, . Rising thyroid cancer incidence in the United States by demographic and tumor characteristics, 1980-2005. Cancer Epidemiol Biomarkers Prev. 2009 Mar;18(3):784-91. PMID: 19240234.19240234
155 Chen AY, Jemal A, Ward EM. Increasing incidence of differentiated thyroid cancer in the United States, 1988-2005. Cancer. 2009 Aug 15;115(16):3801-7. PMID: 19598221.19598221
156 Morris LG, Sikora AG, Tosteson TD, Davies L. The increasing incidence of thyroid cancer: the influence of access to care. Thyroid. 2013 Jul;23(7):885-91. PMID: 23517343.23517343
157 Durante C, Costante G, Lucisano G, Bruno R, Meringolo D, Paciaroni A, . The natural history of benign thyroid nodules. Jama. 2015 Mar 3;313(9):926-35. PMID: 25734734.25734734
158 Noguchi S, Yamashita H, Uchino S, Watanabe S. Papillary microcarcinoma. World journal of surgery. 2008 May;32(5):747-53. PMID: 18264828.18264828
159 Yu XM, Wan Y, Sippel RS, Chen H. Should all papillary thyroid microcarcinomas be aggressively treated? An analysis of 18,445 cases. Annals of surgery. 2011 Oct;254(4):653-60. PMID: 21876434.21876434
160 Tuttle M. Clinicopathologic staging of differentiated thyroid cancer. [Internet] UpToDate 2011 [cited 2016 April 6]; Available from: http://cursoenarm.net/UPTODATE/contents/mobipreview.htm?10/39/10879?source=related_link.
161 Son EJ, Kim E-K, Kwak JY, Hong SW, Chang H-S. Positive predictive values of sonographic features of solid thyroid nodule. Clinical imaging. 2010 Mar-Apr;34(2):127-33. PMID: 20189077.20189077
162 Lang BH-H. Incidental thyroid carcinoma by FDG-PET/CT: a study of clinicopathological characteristics. Annals of surgical oncology. 2011 Feb;18(2):472-8. PMID: 2074032020740320