# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jennifer Croswell, MD, MPH, formerly of AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Gunjan Tykodi, MD, for expert consultation; Todd Hannon, MLS, and Smyth Lai, MLS, for creating and conducting the literature searches; Elizabeth L. Hess, MS, ELS(D), for editorial assistance; Ning X. Smith, PhD, and Brittany Burda, MPH, for assistance with meta-analyses; and Louise Davies, MD, MS, Hyeong Sik Ahn, MD, PhD, Edward G. Grant, MD, and Mike Tuttle, MD, for their expert feedback on this report; and Barry Kramer, MD, MPH, Dawn Holman, MPH, and Monica C. Skarulis, MD, who provided expert review of this report.