# Chapter 4 Discussion

## Summary of Evidence

In theory, screening for thyroid cancer could result in early detection of malignant nodules that can be treated more effectively, and with less harm, than if detected later or with symptomatic identification of thyroid cancer. However, we found no direct evidence to support this logic. To date there are no trials evaluating the (net) benefit of thyroid cancer screening (KQ 1) and, because most cases of thyroid cancer have a long latency period, screening trials of the benefit on patient health outcomes (i.e., morbidity and mortality) are unlikely to be conducted.

Well-designed studies evaluating the diagnostic accuracy of palpation or ultrasound in screening relevant populations (e.g., unselected or asymptomatic persons) are extremely limited (KQ 2). Two older Finnish studies, which were included in the prior review to support the 1996 USPSTF recommendation, demonstrated very low sensitivity of the neck examination to detect thyroid nodules, but these studies were limited to a single examiner.^55, 56^ Two small South Korean studies evaluated the diagnostic accuracy of various sonographic features with ultrasound in a screening population.^57, 58^ In those studies, using any one of several malignant sonographic characteristics (i.e., microcalcification, taller rather than wider, irregular shape, ill-defined or spiculated margin, a solid component with marked hypoechogenicity) could have high sensitivity (94.3%) but not specificity (and thus false-positive results) to detect cancer, whereas using a combination of two or more of these characteristics could have both high sensitivity (94.8%) and specificity (86.6%). These two studies, however, did not provide followup on most patients without malignant sonographic characteristics and thus likely overestimate the true sensitivity. Many other studies with similar study designs were excluded because they were not conducted or not reported to be conducted in a screening population. These two studies confirmed that these sonographic characteristics are most predictive of thyroid cancer but that the precision regarding the diagnostic accuracy of each characteristic varies (see “Diagnostic Accuracy of Ultrasound and FNA” below).

Potential harms of thyroid cancer screening are due primarily to subsequent diagnostic procedures and treatment. The major concerns for harms in thyroid cancer screening are “unnecessary” diagnostic procedures and treatments resulting from a false-positive finding and, more important, overdiagnosis (i.e., persons diagnosed with indolent cancer that would have never caused any suffering or death). We found very limited evidence to evaluate the potential harms of screening or FNA (KQ 3). One study suggested that, in practice, many persons (24%) with abnormal ultrasound findings go on to receive unnecessary FNA (i.e., do not meet current-day criteria and thus would not be expected to have a high risk of malignancy). Two studies suggested that there are no major harms of FNA, even though the procedure can result in localized hematomas or, very rarely, implantation of cancer along the needle tract.^66, 67^ Nonetheless, FNA is generally regarded as a safe procedure when performed by an experienced clinician;^33-35, 37^ the main potential harm is diagnostic inaccuracy or nondiagnostic samples leading to repeat procedures or unnecessary surgery (see “Diagnostic Accuracy of Ultrasound and FNA” below). We found no direct evidence (i.e., studies comparing screening with no screening) to evaluate the magnitude or effect of thyroid cancer screening on overdiagnosis. However, because this is such an important issue for thyroid cancer screening—and for many, the main reason in the argument against thyroid cancer screening—we have included a discussion of the supporting evidence below (see “Overdiagnosis”).

We found no studies that evaluated if treatment of earlier-stage or screen-detected cancer compared with symptomatic cancer improves patient health outcomes (KQ 4). It is still unclear if immediate surgery, versus observation, improves patient health outcomes for small, well-differentiated thyroid cancer. We found one large study using SEER data that found very good 20-year survival rates in both treated and untreated persons with papillary thyroid cancer, albeit higher in treated persons.^69^ In this study, the untreated group was a self-selected minority (1% of the studied population) that differed in measured (and likely unmeasured) potential confounders for which the study did not adjust. It is therefore unclear if differences in survival were due to treatment rather than a case mix of patients who self-selected to be treated (or not). Nonetheless, this study demonstrates that the overwhelming majority of persons diagnosed with papillary cancer in the United States will get surgery. One Japanese study found no deaths after an average of 6 years of followup among persons who opted for observation of papillary microcarcinoma compared with two deaths among persons who opted for immediate surgery.^70, 72^ Ultimately, 56 out of 162 persons in the observation group had surgical treatment.^71^ Again, this study did not adjust for confounders.

In contrast, we found a relatively large body of observational literature describing harms of treatment with surgery and RAI (KQ 5). These studies generally included a mixture of patients, likely not from screening alone. Limited data from included screening studies, however, suggest that a substantial proportion of screen-detected cancer cases include extrathyroidal extension^61^ or lymph node metastases^54, 59-61^ at the time of detection, therefore warranting various interventions comparable with those in the treatment studies we identified. In addition, the rate of surgical harms did not appear to vary by study-level averages of proxies for prognosis (e.g., age, tumor size, tumor stage). We found that permanent surgical complications were not uncommon. Our pooled analysis showed that thyroidectomies were associated with 2 to 6 cases of permanent hypoparathyroidism and 1 to 2 cases of permanent recurrent laryngeal nerve palsy per 100 surgeries. The rate of hypoparathyroidism appears to be more variable with lymph node dissection. Our review is generally consistent with findings of existing systematic reviews. Jeannon et al^126^ reviewed 27 studies and estimated the incidence of permanent recurrent laryngeal nerve palsy at 2.3 percent, and Shan et al^127^ reviewed 16 studies and found no substantive increased risk of permanent hypoparathyroidism or recurrent laryngeal nerve palsy due to thyroidectomy with lymph node dissection compared with thyroidectomy alone. Limitations in the included primary literature did not allow for assessment of the effect of surgical volume on the variation of surgical harms across studies. However, evidence from nonincluded studies (not specific to thyroid cancer) suggests that surgeons with higher case volumes have lower rates of case complications, but even experienced surgeons have complication rates consistent with estimates in our review.^5, 128, 129^ Other serious harms may include death, airway injury, cardiopulmonary events, wound complications, and infection but are not commonly reported.

RAI is not routinely employed as treatment of thyroid cancer but is considered for persons with high-risk cancer.^5^ Radiation doses vary and generally correspond to the indication for RAI, such that lower doses (1.11 GBq or 30 mCi) are used for ablation and higher doses (≤5.5 GBq or 150 mCi) are used for adjuvant therapy for known or suspected residual disease.^5^ Two studies using SEER data found an excess cancer risk of about 12 or 13 cancer cases per 10,000 person-years; however, neither reported the radiation dose. Smaller studies that reported radiation dose demonstrated an association with excess cancer risk at clinically used doses of RAI; however, differences in study designs and variable reporting on radiation dose limits our understanding of the magnitude and precision of this small excess risk. Our findings are consistent with older excluded literature. A 2009 systematic review by Sawka et al^46^ that estimated the risk of second primary malignancies after RAI treatment of thyroid cancer included two large studies, one by Brown et al^130^ using a U.S. cohort (included in our review) and another by Rubino et al^131^ using three European cohorts (n=6,841) (excluded because treatment dates were as early as 1934). The average radiation dose reported in the European cohorts was approximately 6 GBq (or 162 mCi), and the calculated excess absolute risk of secondary malignancies with approximately 1 GBq or 27 mCi was about 15 cancer cases (14.4 solid and 0.8 hematologic) per 100,000 person-years. Six studies showed that RAI (mean dose, 2.96 to 5.3 GBq or 80 to 142 mCi) is associated with permanent dry mouth (2.3% to 35%), which can adversely affect quality of life and increase the risk of dental disease.^117-122^ Although RAI can affect gonadal function, we found no evidence (including three older excluded studies) to suggest that lower doses of radiation from RAI result in male or female infertility. Our findings are consistent with existing systematic reviews that have examined the effects of RAI on gonadal function in men and women.^132, 133^

## Key Contextual Issues

### Diagnostic Accuracy of Ultrasound and FNA

#### Ultrasound

Our review was limited to diagnostic accuracy studies of screening the thyroid by ultrasound in unselected or asymptomatic persons, in which all or a random subset of screen-negative persons also received a reference standard (i.e., histology). Therefore, many studies evaluating the diagnostic accuracy of thyroid ultrasound (e.g., studies limited to persons with known thyroid nodules) and a rather large body of literature on the diagnostic accuracy of various ultrasound characteristics (e.g., nodule shape, margins, echogenicity, calcifications) for malignancy were excluded. Several studies have shown that certain ultrasound characteristics, in combination with nodule size, could help to determine the risk of malignancy and therefore potentially reduce unnecessary FNA testing.^40, 134-138^

Brito et al^137^ reviewed 31 studies on diagnostic accuracy (not in screening populations) published from 1985 to 2012 and showed that the three ultrasound characteristics most predictive of thyroid cancer malignancy were taller than wide shape, internal calcifications, and infiltrative margins.^137^ Taller than wide shape had a sensitivity of 0.53 (95% CI, 0.50 to 0.56) and specificity of 0.93 (95% CI, 0.91 to 0.94), internal calcifications had a sensitivity of 0.54 (95% CI, 0.52 to 0.56) and specificity of 0.81 (95% CI, 0.80 to 0.82), and infiltrative margins had a sensitivity of 0.56 (95% CI, 0.50 to 0.60) and specificity of 0.79 (95% CI, 0.77 to 0.80). Brito also showed that nodules with spongiform or cystic features (though present in only about 2% of nodules) were most likely benign. Nodule size alone was not an accurate predictor of malignancy, and the review did not evaluate accuracy based on multiple characteristics. Smith-Bindman et al^40^ conducted a retrospective case-control study of 11,618 thyroid ultrasounds done at the University of California, San Francisco from 2000 to 2005. In a multivariable model, only three characteristics remained statistically significant predictors of thyroid cancer: microcalcifications (odds ratio [OR], 8.1 [95% CI, 3.8 to 17.3]), nodule size 2 cm or larger (OR, 3.6 [95% CI, 1.7 to 7.6]), and entirely solid composition (OR, 4.0 [95% CI, 1.7 to 9.2]). Additional large studies out of Korea,^136, 138^ Turkey,^135^ and Italy^134^ demonstrated that nodules with calcifications, taller than wide shape, irregular margins, and hypoechoic patterns are the most predictive of thyroid cancer malignancy. The sensitivity of each of these characteristics to characterize malignant nodules varied widely between studies, from 44 to 86 percent for microcalcifications, 40 to 76 percent for taller than wide shape, 48 to 90 percent for irregular margins, and 41 to 87 percent for hypoechogenicity.^134, 135, 138^ Specificity ranged from 54 to 90 percent for microcalcifications, 60 to 91 percent for taller than wide shape, 81 to 92 percent for irregular margins, and 47 to 92 percent for hypoechogenicity.^134, 135, 138^ Several, but not all, sensitivity and specificity results from our two included studies for KQ 2^57, 58, 139^ fall within these wide ranges, further emphasizing the wide variability in diagnostic accuracy for these characteristics.^57, 58^

Published in 2015, the ATA's evidence-based guidelines on the management of thyroid nodules and differentiated thyroid cancer strongly recommends FNA for nodules larger than 1 cm with highly suspicious sonographic patterns, including a solid hypoechoic nodule or a solid hypoechoic component in a partially cystic nodule with either irregular margins, microcalcifications, taller than wide shape, or disrupted rim calcifications with small extrusive hypoechoic soft tissue component or extrathyroidal extension.^5^ The ATA guidelines also strongly recommend FNA for nodules at least 1 cm in size with intermediate suspicious sonographic patterns, including a hypoechoic solid nodule with a smooth regular margin and without microcalcifications, extrathyroidal extension, or taller than wide shape, although this latter recommendation was based on lower-quality evidence.

#### FNA

FNA is a quick, low-risk, and reliable procedure and currently the best method available for determining which thyroid nodules should be surgically removed or observed over time. Nonetheless, FNA is not perfect. The 2015 ATA guidelines recommend that FNA cytology be classified using the Bethesda System to reduce variability in reporting.^5^ The Bethesda System categories are 1) nondiagnostic or unsatisfactory, 2) benign, 3) AUS/FLUS, 4) follicular neoplasm or suspicious for follicular neoplasm, 6) suspicious for malignancy, or 6) malignant. Patients who have nodules with initial nondiagnostic results should have a repeat FNA with ultrasound guidance. Patients with malignant nodules should be recommended for thyroid surgery. Management of indeterminate nodules (AUS/FLUS, follicular neoplasm, or suspicious for malignancy) is more controversial and may involve molecular testing, repeat FNA, and/or surgical excision depending on the patient's risk factors, the ultrasound characteristics of the nodules, and patient preference.

A 2012 systematic review of eight studies reported diagnostic accuracy among 25,445 FNAs of thyroid nodules.^140^ Overall, 6,362 (25%) FNAs resulted in surgery, with the proportion varying from 11.8 to 45.1 percent across the studies. The overall sensitivity and specificity of FNA for detecting malignancy were 97.0 and 50.7 percent, respectively,^140^ when considering the Bethesda System categories of follicular neoplasm, suspicious for malignancy, and malignant as positive. The sensitivity and specificity increased to 97.2 and 60.2 percent, respectively, when also including AUS/FLUS results (9.6% of all FNAs) as positive. The positive predictive value for AUS/FLUS alone was 15.9 percent, and 39.2 percent of these cases ultimately went on to surgery. The 2015 ATA guidelines state that only 7 percent of all thyroid FNAs^5, 141^ are expected to have this result; however, Bongiovonni^140^ showed that the percentage of FNAs with AUS/FLUS results from eight studies ranged widely, from 0.8 to 27.2 percent. Large percentages of indeterminate FNA results as well as variability in the management of these indeterminate findings could ultimately result in unnecessary surgery and overtreatment of thyroid nodules. In the United States alone, 59,478 persons underwent thyroidectomy in an inpatient setting in 2009.^142^ While 18,008 (30.3%) of those operations were for thyroid cancer, the remainder were benign conditions, including nontoxic nodular goiter (36.0%) and benign neoplasms (11.2 %).

### Overdiagnosis

Overdiagnosis of thyroid cancer occurs when a thyroid malignancy is diagnosed but would not have caused symptoms or death during a patient's lifetime.^143^ Overdiagnosis occurs because some thyroid tumors grow so slowly that the cancer never progresses (and sometimes regresses) or progresses at such a slow pace that the person dies of other causes before the cancer is symptomatic. Welch and Black^144^ proposed two prerequisites for overdiagnosis, both of which are met by thyroid cancer: 1) the existence of a disease reservoir or a substantial number of subclinical cancer cases, and 2) a method to detect these subclinical cancer cases via screening. One of the major harms from overdiagnosis is overtreatment, or the overuse of procedures that may result in treatment harms without (or only marginally) improving patient outcomes. According to SEER data, 98.8 percent of persons with thyroid cancer diagnosed from 1973 to 2005 underwent definitive treatment.^69^ Overdiagnosis may also lead to preventable harms, such as increased patient anxiety, potential complications or adverse effects from treatment (as we reported), and increased health care costs^145^ without benefit to the patient. However, at present, there is no clear way to determine which cases of thyroid cancer would actually require treatment to improve patient survival and which would not.

Although overdiagnosis is arguably the most important harm of thyroid cancer screening, it is not addressed by our review of harms of screening (KQ 3) due to limitations in the evidence base. To accurately estimate overdiagnosis, studies must compare screened and unscreened groups.^143^ We found no studies that compared screened and unscreened groups with incidence or overdiagnosis of thyroid cancer as an outcome. A recent review by Carter et al^143^ provided an overview of the types of study designs needed to accurately quantify overdiagnosis in cancer screening, none of which is available for thyroid cancer. The four types of study designs are modeling studies, pathological and imaging studies, ecological and cohort studies, and followup of RCTs. Modeling studies compare the way cancer would hypothetically occur with and without screening. Biases may limit the quality of modeling studies and include a lack of direct evidence to support modeling assumptions, validation analyses, or generalizability. Pathology and imaging studies determine the extent of overdiagnosis-based characteristics seen in imaging or pathology studies, such as tumor growth rate. These studies assume that pathology or imaging characteristics are strongly correlated with cancer morbidity or mortality, which may be a difficult assumption to apply to thyroid cancer because it has not been determined which tumor characteristics are more predictive of mortality than others, particularly for papillary carcinomas. Ecological and cohort studies typically follow persons through cancer screening programs and compare the cancer incidence with unscreened control groups. These studies are subject to selection bias and confounding from control group selection (studies typically use historical controls or controls from different geographic areas without screening programs) or lead-time bias from insufficient followup time. Followup from RCTs comparing screening with no screening may be the least-biased study design for assessing overdiagnosis; however, this type of study is rare, even for other types of cancer.

#### Incidence and Mortality Data

The best evidence we have to suggest that overdiagnosis is a problem with thyroid cancer comes from studies showing a rising incidence in thyroid cancer detection over time with no corresponding change in the mortality rate.^2, 47, 69, 146-148^ Several studies by Davies and Welch^2, 69, 148^ have used SEER data to estimate the incidence of thyroid cancer and cancer-related mortality in the United States since 1973. The most recent estimates, published in 2014, showed that the incidence of thyroid cancer increased from 4.9 cases per 100,000 persons in 1975 to 14.3 cases per 100,000 persons in 2009, representing an absolute increase of 9.4 (95% CI, 8.9 to 9.9) cases per 100,000 persons.^2^ When only cases of papillary cancer were examined, the absolute increase over the same time period was 9.1 (95% CI, 8.6 to 9.6) cases per 100,000 persons^2^; thus, cases of papillary cancer have accounted for the majority of the increased incidence among all cases of thyroid cancer. These increases were 3 to 4 times greater in women than in men. The size distribution of diagnosed tumors has shifted toward smaller lesions, with the proportion of tumors smaller than 1 cm that were diagnosed increasing from 25 percent in 1988 to 1989 to 39 percent in 2008 to 2009.^2^ During the same time period, the rate of thyroid cancer mortality remained stable (approximately 0.5 deaths per 100,000 persons).^2, 148^ Ho et al^147^ conducted a similar analysis using SEER data and found nearly identical thyroid cancer incidence and mortality rates over time. They also noted that the 10-year disease-specific survival for patients diagnosed from 1983 to 1999 increased from 95.4 to 98.6 percent (p=0.002), which may reflect, in part, that small, asymptomatic cancer accounts for most new diagnoses. Neither of these studies reported mortality by histologic type, which is an important element to consider given that patients with medullary and anaplastic cancer have much higher mortality rates than patients with differentiated cancer.^1^

Data from other countries have shown similar findings. A summary report using data from the Cancer Incidence in Five Continents database showed steady increases in thyroid cancer incidence in 12 selected countries from 1960 to 2007, which, again, was primarily driven by a rise in papillary carcinoma diagnoses.^146^ Mortality data from the World Health Organization showed that the mortality rate from 2000 to 2010 either stabilized around 0.2 deaths per 100,000 men and 0.6 deaths per 100,000 women or declined by 2 to 3 percent per year for men and 2 to 5 percent per year for women. The declines are likely related to changes in both risk factors (due to improvements in diet, reductions in iodine deficiency, and medical use of ionizing radiation over the last couple of decades in some countries) and cancer detection (resulting in overdiagnosis of cancer with a favorable prognosis). The best example that illustrates the problem of overdiagnosis of thyroid cancer comes from South Korea, which has had an organized cancer screening program since 1999.^47^ Although the program did not officially include thyroid cancer screening, providers frequently offered thyroid screening with ultrasound for a small additional cost. In 2011, the rate of thyroid cancer diagnoses was 15 times the rate in 1993,^47^ while the rate of thyroid cancer mortality remained stable. In 2011 alone, more than 40,000 persons were diagnosed with thyroid cancer, whereas fewer than 400 died. Nearly every person diagnosed with thyroid cancer underwent surgical treatment. One study noted that the tumors excised decreased in size over time: the proportion of tumors excised that were smaller than 1 cm increased from 14 percent in 1995 to 56 percent in 2005.^61^ Increases in thyroid cancer incidence ranging from 3.2 to 6.2 percent per year in men and 3.5 to 8.1 percent in women were noted in France, Australia, and Canada from the early 1980s to the late 1990s, although none of these countries implemented thyroid cancer screening as did South Korea.^149-151^ These studies also noted that the majority of the increase in incidence was due to an increase in cases of papillary thyroid carcinoma or microcarcinoma.

Several studies have evaluated whether the increased incidence in thyroid cancer is a result of increased detection (e.g., through increased imaging) or a true increase in risk factors for thyroid cancer (e.g., due to exposure to ionizing radiation). Davies et al^152^ conducted a small (n=279) study to identify examinations that led to detecting cases of asymptomatic cancer. The results showed that 46 percent (n=44 of 95) of identified cases of cancer were first noted on surgical evaluation following detection of a nodule during a routine examination (i.e., asymptomatic), imaging for an unrelated cause, or diagnostic workup for other problems where the thyroid might be involved (e.g., patient complaining of fatigue). The majority of these cases of “asymptomatic” cancer were papillary (n=37), and the mean tumor size was 1.9 cm (range, 0.2 to 10 cm), whereas the mean tumor size of cases of symptomatic papillary cancer was 2.4 cm (range, 0.2 to 8 cm). These results are consistent with the epidemiologic studies described above that noted that the increased incidence of thyroid cancer was due to increased diagnoses of small papillary tumors.

However, a review by Pellegriti et al^18^ noted that while the largest increase in thyroid cancer incidence occurred among tumors smaller than 1 cm, smaller increases have occurred among larger tumors. For example, a study using SEER data showed that the incidence of thyroid tumors 2 to 4 cm in size increased 4.6 percent (95% CI, 3.5 to 5.7) per year from 1995 to 2006 and that of larger tumors increased 4.1 percent (95% CI, 3.4 to 4.8) per year from 1983 to 2006.^153^ A second SEER study showed that from 1983 to 2006, papillary thyroid tumors smaller than 1 cm, 1.1 to 2 cm, 2.1 to 5 cm, and larger than 5 cm increased by 19.3, 12.3, 10.3, and 12.0 percent per year, respectively.^41^ A third SEER study showed that from 1992 to 2005, approximately 50 percent of the overall increase in papillary cancer incidence was from tumors 1 cm or smaller, 30 percent from tumors 1.1 to 2 cm, and 20 percent from larger tumors.^154^

Pellegriti et al^18^ also pointed out that an increase in incidence solely due to increased detection should have affected all histologic types and sexes equally. As we noted above, prior studies primarily noted increases among cases of papillary cancer and larger increases in incidence in women than men.^2, 147, 149-151^ Additional studies, such as the study by Chen et al,^155^ used SEER data to demonstrate that increases in incidence by tumor size differed between men and women. From 1988 to 2005, the incidence of tumors smaller than 1 cm increased by 4 percent (95% CI, 0.8 to 7.3) per year in men and by 8.6 percent (95% CI, 7.8 to 9.5) per year in women. During the same time period, the incidence of thyroid tumors 1.0 to 2.9 cm in size increased by 5.5 percent (95% CI, 4.2 to 6.8) in men and by 0.4 percent (95% CI, -3.0 to 3.8) in women. Enewold et al,^154^ also using SEER data, demonstrated that the incidence rate of thyroid cancer varied by race/ethnicity, sex, and histology. Papillary cancer was the only histologic type to see a significant increase in the rate from 1980 to 2005, but the increase differed by race/ethnicity and sex (8.0%, 2.7%, 3.80%, and 1.16% per 100,000 person-years for white women, white men, black women, and black men, respectively).

In the United States, the increased incidence of thyroid cancer over time may also be related to increased access to care. This hypothesis is supported by a study that used SEER data from 1973 to 2009 linked to U.S. Census data from 2000 to demonstrate that thyroid cancer incidence was positively correlated with income level, education, and employment.^156^ Another study, which used data from 1999 to 2009 from the U.S. Cancer Statistics Report linked to Lifescript doctor review data and administrative patient claims data, showed that the incidence of thyroid cancer was significantly correlated with the density of endocrinologists.^43^ Incidence varied from 4.7 per 100,000 person-years in Oklahoma to 9.1 per 100,000 person-years in Rhode Island, and much of the variation in incidence by U.S. State could be explained by the density of endocrinologists and general surgeons as well as the use of neck ultrasounds.

Pellegriti et al^18^ also reviewed whether changes in potential risk factors for thyroid carcinoma are related to thyroid cancer incidence, which could suggest that some of the increased incidence is real and not related to overdiagnosis. Pellegriti et al noted that in the United States, the use of medical imaging such as CT scans and x-ray has increased dramatically and that individual doses of ionizing radiation from these examinations doubled from 1980 to 2006. Additional elements of diet, lifestyle, and pollution (e.g., iodine intake, food or environmental contaminants) may influence the risk of thyroid cancer, but these aspects have not been studied carefully.^18^ Thus, limited evidence exists for an external cause of increased thyroid cancer incidence beyond increased detection and diagnosis.

#### Autopsy Data

Autopsy studies have provided additional evidence on overdiagnosis of thyroid cancer. A 2014 review by Lee et al^30^ summarized 15 studies published from 1969 to 2005 on latent thyroid cancer discovered at autopsy. Of 8,619 thyroid glands obtained at autopsy, 989 (11.5%) were positive for papillary thyroid carcinoma. The proportion of cases of papillary thyroid cancer varied widely, from 1.0 to 35.6 percent. The majority of the tumors were tiny (diameter <1 to 3 mm), and women and men were equally likely to have papillary cancer diagnosed on autopsy. The authors compared the autopsy diagnoses with 1,355 papillary microcarcinomas diagnosed clinically at their institution; most patients diagnosed clinically (67.3%) had tumors larger than 0.5 cm, and women were 11 times more likely than men to be diagnosed. Comparisons between the latent cancer cases diagnosed on autopsy and the papillary microcarcinomas diagnosed clinically are likely subject to selection bias, but the autopsy studies clearly demonstrate that a proportion of thyroid cancer cases would likely never result in symptoms or mortality.

#### Natural History Data

Studies describing the natural history of thyroid nodules and malignancies also lend evidence to the problem of overdiagnosis in thyroid cancer. The 2015 ATA guidelines note that benign nodule growth has been variably defined across studies and that there is no good cutoff to use for percent change in size when determining whether to conduct repeat FNA on nodules previously diagnosed as benign.^5^ Durante et al^157^ describe 5-year followup of 992 patients with benign thyroid nodules (size, 0.4 to 4 cm). In 686 patients (69%), the size of the nodules remained stable; in 184 patients (18.5%), the size of one or more nodules decreased; and in 153 patients (15.4%), the size of one or more nodules increased by 20 percent or more (the groups were not mutually exclusive because some persons had more than one nodule). Ultimately, only five patients were diagnosed with thyroid malignancy. There are currently no studies with followup of benign nodules beyond 5 years. Studies with longer followup are needed to help determine whether indefinite followup of nodules is necessary.

Nodule growth was evaluated in persons with thyroid cancer by Ito et al.^71^ Among 162 persons with papillary microcarcinoma who opted for observation instead of immediate surgical treatment, within 1 year the tumor increased in size by 2 mm or more in 20 patients (15.3%), decreased in size by 2 mm or more in 18 patients (13.8%), or did not change in 92 patients (70.8%). After 5 years of followup, 72.3 percent of tumors did not increase in size. Ultimately, 56 patients went on to have surgery, only 13 of whom had an increase in tumor size of 2 mm or more.

Another study, of 2,070 patients with papillary microcarcinoma, looked at recurrence-free survival up to 35 years after diagnosis and found that the survival rate was 96.7 percent for patients with tumors 5 mm or smaller and 86.0 percent for patients with tumors 6 to 10 mm in size (p<0.0001).^158^ In a multivariable survival model, neither patient age nor sex was predictive of disease-free survival. A total of 73 patients experienced recurrence at a median time of 10.3 years. A large SEER study evaluated recurrence and mortality outcomes among 18,445 patients with papillary microcarcinoma; at 15 years, the overall survival rate was 90.7 percent and the disease-specific survival rate was 99.3 percent. In multivariable survival models, patient characteristics related to poorer overall survival included age older than 45 years (hazard ratio [HR], 6.18 [95% CI, 4.80 to 7.97]), male sex (HR, 1.74 [95% CI, 1.44 to 2.11]), and African American race (HR, 2.56 [95% CI, 1.88 to 3.47]).^159^ A total of 49 patients died of thyroid cancer. Using SEER data, Davies et al^69^ estimated the rate of papillary thyroid cancer–specific survival by whether the patients received definitive treatment. The 10-year survival rate was 99 percent among 29,789 persons who had received definitive treatment and 97 percent among 440 persons who did not. In the United States, data from single institutions have demonstrated that the overwhelming majority of thyroid cancer diagnoses are stage I papillary cancer, with 20-year survival approximating 100 percent.^160^ These data highlight the slow-growing nature of thyroid tumors and the low potential for recurrence or mortality due to thyroid cancer, particularly papillary tumors and microcarcinoma. However, data on the survival of patients who never receive treatment are very limited. As Ho et al^147^ pointed out, the high survival rates of patients with thyroid cancer may be a result of length bias as increasing numbers of subclinical thyroid cancer cases are diagnosed, thereby shifting survival curves toward longer survival.

## Limitations of the Review

Our review was designed to support the USPSTF in making a recommendation regarding screening for thyroid cancer such that our inclusion criteria reflected decisions about identifying the most applicable evidence for our primary stakeholder. We did not include studies primarily focused on cohorts exposed to high doses of radiation due to environmental disasters. In addition, we did not review the diagnostic accuracy of ultrasound or ultrasound characteristics to detect thyroid cancer in nonscreening populations, primarily due to referral bias, although we provide a summary of this literature (see “Diagnostic Accuracy of Ultrasound”). For our review of overdiagnosis, our inclusion criteria required studies that compared screened versus unscreened persons. However, because these types of studies do not exist, we summarize the supporting literature (see “Overdiagnosis”).

Because our review focused on the benefit of treatment versus observation or the treatment of asymptomatic versus symptomatic disease, we excluded studies evaluating the comparative benefits and harms of treatment (i.e., the most effective or safest treatment). We also excluded harms not directly related to surgery or RAI (e.g., subsequent harms from suppressive doses of thyroxine). We excluded older studies that examined harms of RAI, as radiation doses have changed over time. Nonetheless, we acknowledge that, over time, surgical techniques, RAI doses, and the case mix of persons undergoing surgery and/or RAI have changed; such included studies still may not accurately reflect modern-day practice. Given our primary audience and resource limitations, we limited our review to evidence conducted in countries with the most appropriate applicability to U.S. practice and to articles published in English. We do not believe these criteria resulted in omission of any key evidence.

Due to the sparse data for most of the KQs, we were limited to nonquantitative analyses. Our meta-analyses to pool surgical harms had high statistical heterogeneity for outcomes of hypoparathyroidism, which we could not explain by using several study-level characteristics.

## Evidence Gaps and Future Research Needs

Overall, there is very little evidence examining the benefit of screening for thyroid cancer. No professional society recommends population-based thyroid cancer screening. Additionally, there is little evidence to support screening in persons with an elevated risk of thyroid cancer. Previously, the USPSTF stated there was insufficient evidence to recommend screening in persons with a personal history of irradiation (and we found no new studies in this review), and the ATA stated in 2015 that there was insufficient evidence to support screening persons with a family history of differentiated thyroid cancer. Although population-based screening trials for thyroid cancer are unlikely, trials or well-designed observational studies to address the benefit of screening in higher-risk populations (e.g., those with a personal history of irradiation or a family history of differentiated thyroid cancer) would be helpful to understand if there is any role at all for screening for thyroid cancer. The use of radiation to treat benign conditions in childhood ended several decades ago, so questions about best practices for screening in this population may not be a priority, but there are smaller subpopulations who have received radiation for diagnostic (e.g., CT scans) or therapeutic (e.g., treatment of hematologic cancer) purposes in childhood, adolescence, or early adulthood, for whom assessing best practices may be relevant.

Given the indolent nature of many cases of thyroid cancer and the risks associated with treatment, trials or well-designed observational studies examining the benefit of early treatment versus observation or surveillance for patients with (smaller) well-differentiated thyroid cancer are also needed. In addition, we need studies to determine which set of prognostic indicators predict aggressive versus indolent disease. Over the past decade, better understanding of the genetic mechanisms of thyroid cancer and the creation of molecular tests to aide in cancer diagnosis have made molecular markers a very promising area of research to help derive a prognosis of thyroid cancer.^5^

## Conclusions

Although an ultrasound of the neck using high-risk sonographic characteristics plus followup cytology from FNA can reasonably identify thyroid cancer, it is still unclear if population-based or targeted screening can decrease mortality rates or improve important patient health outcomes. Screening results in the identification of indolent thyroid cancer which would not have resulted in any morbidity or mortality in a person's lifetime. Treatment of these cases of overdiagnosed cancer can pose real harms, including complications from surgical and RAI treatment. There is a lack of evidence to understand the true magnitude of overdiagnosis as well as the risk markers that predict indolent versus progressive thyroid cancer.