# Chapter 3 Results

## KQ 1 Compared With Not Screening, Does Screening Adults for Thyroid Cancer Lead to a Reduced Risk of Thyroid-Specific Mortality or Morbidity, Reduced All-Cause Mortality, and/or Improved Quality of Life?

We found no studies that met our inclusion criteria for KQ 1. We found no randomized, controlled trials (RCTs) or controlled clinical trials that evaluated the effects of thyroid cancer screening on patient morbidity or mortality compared with no screening. Two cohort studies that compared screened individuals versus a comparator group did not meet our inclusion criteria for KQ 1. One study (n=4,296) of high-risk persons who were previously exposed to radiation was not included because screening was conducted with older technology (i.e., a thyroid scan using ^99^mTc-pertechnetate and a pinhole collimator), and it used a historical control as the comparator group.^53^ One large Japanese cohort study (n=152,651) was excluded because the comparator group consisted of persons who presented with symptoms.^54^

## KQ 2 What Are the Test Performance Characteristics of Screening Tests for Detecting Malignant Thyroid Nodules in Adults?

Ten fair-quality studies met our inclusion criteria for KQ 2 (Table 1). Two studies reported on diagnostic accuracy of palpation to detect nodules,^55, 56^ two on diagnostic accuracy of ultrasound to detect cancer,^57, 58^ four on cancer yield from screening using palpation plus followup ultrasound,^54-56, 59^ four on cancer yield from screening using ultrasound only,^57, 58, 60, 61^ and two older studies on cancer yield from screening adults with a history of childhood irradiation.^62, 63^

Table 1 Included Studies for Key Question 2: Test Performance Characteristics of Screening Tests for Detecting Malignant Thyroid Nodules in Adults

Screening Method | Study, Year, Quality | Country, Recruitment Years | Study Design | N Screened | Mean Age (years) | Women (%) | Diagnostic Accuracy | Cancer Yield
Average-risk population
Palpation | Suehiro, 2006^59^ Fair | Japan 1989-2005 | Retrospective | 46,433 | 49 | 45^*^ | | X
Palpation | Brander, 1991^55^ Fair | Finland 1989-1990 | Prospective | 253 | 35 | 51 | X | X
Palpation | Brander, 1989^56^ Fair | Finland 1988 | Prospective | 101 | 52 | 100 | X | X
Palpation | Ishida, 1988^54^ Fair | Japan 1980-1986 | Prospective | 152,651 | NR | 100 | | X
US | Kim, 2010^57^ Fair | South Korea 2005-2007 | Prospective | 2,079 | 43 | 100 | X
US | Kim, 2008^58^ Fair | South Korea 2004-2006 | Retrospective | 16,352 | 53 | 67 | X
US | Lee, 2003^61^ Fair | South Korea 2003 | Prospective | 697 | 43 | 100 | | X
US | Chung, 2001^60^ Fair | South Korea 1997-1998 | Prospective | 1,401 | 47 | 100 | | X
High-risk population
Palpation + diagnostic followup^†^ | Ron, 1984^62^ Fair | Israel Years NR | Prospective | 443 | 29 | 49 | | X
Palpation + diagnostic followup^‡^ | Shimaoka, 1982^63^ Fair | USA 1977-1980 | Prospective | 1,500 | 39 | 64 | | X

* Percentage of exam visits that were women (calculated).

† Diagnostic followup consisted of technitium-99m thyroid scan and thyroid function tests.

‡ Diagnostic followup consisted of iodine 123 thyroid scan, blood tests, and indirect laryngoscopy.

Abbreviations: KQ=key question; NR=not reported; X=reported; US=ultrasound.

Evidence to inform the true diagnostic accuracy of screening using neck palpation or ultrasound to detect thyroid cancer is limited. In two studies in Finland (n=354) using a single examiner, neck palpation was not sensitive enough to detect thyroid nodules.^55, 56^ On the basis of results of two methodologically limited studies conducted in South Korea (n=243), using selected sonographic features when screening with ultrasound can be specific for detecting thyroid malignancy;^57, 58^ one of these studies suggested that a combination of high-risk sonographic features, such as presence of microcalcifications or irregular shape, can optimize both sensitivity and specificity. Among studies that provided the screening yield, ultrasound-based screening detected a greater proportion of cancer cases than did palpation. The clinical significance (i.e., morbidity and mortality) of cancer detected through either screening method is unknown.

### Diagnostic Accuracy of Palpation to Detect Thyroid Nodules

Two fair-quality prospective studies, both included in the previous review, examined the accuracy of neck palpation to detect thyroid nodules.^55, 56^ These two studies (n=354) were conducted by the same investigator in Finland in the late 1980s. Both studies used a single examiner to screen persons with neck palpation, which was immediately followed by ultrasound as the reference standard. However, only one study reported the diagnostic accuracy of palpation for all screened persons (regardless of the ultrasound results).^55^ In that study, screening by neck palpation was conducted among 253 randomly selected persons ages 20 to 49 years from the community. An abnormal result from neck palpation (i.e., thyroid nodule or diffuse enlargement of the thyroid) was found in 5.1 percent of subjects, whereas an abnormal result from ultrasound was found in 27.3 percent. The sensitivity and specificity of palpation to detect thyroid nodules (size not reported) were 11.6 (95% CI, 5.1 to 21.6) and 97.3 percent (95% CI, 93.8 to 99.1), respectively.^55^ In the other study, screening for thyroid nodules by neck palpation was conducted by a single examiner among 101 women ages 49 to 58 years who attended a mammogram screening program.^56^ The palpation results were reported for the 36 patients with abnormal ultrasound results. The sensitivity of palpation to detect nodules in persons with an abnormal ultrasound result was 27.8 percent. In this study, a second examiner palpated a subset of persons and examination findings were concordant with those of the first examiner in 18 of the 25 cases.

#### Limitations

Both studies are fair-quality prospective studies. However, these older, single-examiner studies were conducted outside the United States, and only one reported results for all persons who underwent examination of the thyroid by palpation. In addition, the number of participants in both studies was relatively small, and no cancer was detected.

### Diagnostic Accuracy of Screening Ultrasound to Detect Thyroid Cancer

The vast majority of studies that examined the diagnostic accuracy of ultrasound to detect thyroid cancer were not (or were not reported to be) conducted in screening populations. These studies were therefore not included for KQ 2 but are summarized in the Discussion section. We identified two fair-quality studies that examined the diagnostic accuracy of screening ultrasound to detect thyroid cancer, neither of which was included in the previous review.^57, 58^ Both studies (n=243) were conducted by the same investigators in South Korea from 2004 to 2007 but had different study designs.

The better quality study prospectively examined the diagnostic accuracy of screening for thyroid cancer by ultrasound in 113 of 2,079 screened women ages 15 to 77 years who attended a breast ultrasound clinic.^57^ Seventy-seven of the screened women (3.7%) revealed one or more malignant sonographic characteristics (e.g., presence of microcalcifications, irregular shape, ill-defined or microlobulated margin, marked hypoechogenecity, orientation of taller than wide). These 77 women and a small, nonrandomly selected subset of 36 screened women with probable benign ultrasound findings underwent ultrasound-guided FNA and either surgical confirmation or clinical followup at 2 years (depending on the FNA results). Among these 113 women who underwent FNA, 53 women were diagnosed with papillary thyroid cancer. The sensitivity and specificity of having one or more malignant features on screening ultrasound were 94.3 (95% CI, 84.3 to 98.8) and 55.0 percent (95% CI, 41.6 to 67.9), respectively (Table 2). Most screened women, however, did not undergo any further followup, including 756 women whose ultrasound results revealed a nonsuspicious nodule or other abnormalities and 1,209 women whose results showed normal-appearing glands.

Table 2 Key Question 2 Results: Diagnostic Accuracy of Screening Ultrasound

Study, Year, Quality | N Analyzed | Characteristic | Sensitivity % (95% CI) | Specificity % (95% CI)
Kim, 2010^57^ Fair | 113 persons | ≥1 characteristics: | 94.3% | 55.0%
Kim, 2010^57^ Fair | 113 persons | Microcalcification | 34.0% (21.5- 48.3)^*^ | 83.3% (71.5-91.7)^*^
Kim, 2010^57^ Fair | 113 persons | Irregular shape | 88.7% (77.0-95.7)^*^ | 63.3% (49.9-75.4)^*^
Kim, 2010^57^ Fair | 113 persons | Taller-than-wide shape | 67.9% (53.7-80.1)^*^ | 80.0% (67.7-89.2)^*^
Kim, 2010^57^ Fair | 113 persons | Ill-defined or microlobulated margin | 86.8% (74.7-94.5)^*^ | 68.3% (55.0-79.7)^*^
Kim, 2010^57^ Fair | 113 persons | Marked hypoechogenicity | 52.8% (38.6-66.7)^*^ | 86.7% (75.4-94.1)^*^
Kim, 2008^58^ Fair | 140 nodules | ≥2 characteristics: | 94.8% | 86.6%
Kim, 2008^58^ Fair | 140 nodules | Microcalcification | 70.7% (57.3-81.9) | 98.8% (93.4-99.8)
Kim, 2008^58^ Fair | 140 nodules | Taller-than-wide or irregular shape | 55.2% (41.5-68.3) | 89% (80.2-94.8)
Kim, 2008^58^ Fair | 140 nodules | Spiculated margin | 48.3% (35-61.8) | 97.6% (91.4-99.6)
Kim, 2008^58^ Fair | 140 nodules | Marked hypoechogenicity | 55.2% (41.5-68.3) | 96.3% (89.7-99.2)
Kim, 2008^58^ Fair | 140 nodules | Solid | 93.1% (83.3-98) | 51.2% (39.9-62.4)

* Calculated confidence intervals.

Note: Both studies report accuracy only among patients who had at least one study-defined malignant ultrasound characteristic, providing no followup on the vast majority (n=18,188) of screened individuals who did not have these characteristics.

Abbreviations: KQ=key question; CI=confidence interval.

The other study was a retrospective analysis of 130 individuals from a series of 16,352 asymptomatic persons who referred themselves to thyroid cancer screening.^58^ A total of 1,009 screened persons had a sonographic lesion with one or more malignant features and were followed up with FNA. Malignant sonographic characteristics were defined as presence of microcalcifications, marked hypoechogenicity, well-defined spiculated margins, or solid rather than cystic nodule. The study sample included 58 of 150 lesions classified as malignant (all papillary thyroid cancer) and 82 of 823 lesions classified as benign by FNA results, for a total of 140 nodules in 130 persons. The 352 lesions with indeterminate or nondiagnostic FNA results were excluded from further analysis. The malignant lesions were diagnostically confirmed after surgical pathology, and the included benign lesions were all followed and confirmed to have no change in size by ultrasound or repeat FNA after at least 2 years. Among these 140 nodules, the sensitivity and specificity of having two or more malignant features on screening ultrasound were 94.8 and 86.6 percent, respectively (95% CI values could not be calculated) (Table 2). The authors found that the solid sonographic characteristic was sensitive (93.1%) but not specific (51.2%) for detecting malignancy, as opposed to other sonographic characteristics (i.e., microcalcifications, marked hypoechogenecity, and spiculated margins) that were specific, but less sensitive, for detecting malignancy. A total of 15,343 persons with no lesions or benign-appearing lesions had no followup after the initial screening with ultrasound.

#### Limitations

Both of these studies were fair-quality diagnostic accuracy studies conducted outside the United States. Both studies reported accuracy only among patients who had at least one study-defined malignant ultrasound characteristic and did not follow up on the vast majority (n=18,188) of screened individuals without these characteristics. Due to this study design, the potential amount of false-negative cases is generally unknown and estimates of sensitivity are likely overestimated. Despite the inherent limitations of the study design, we included these studies because they represent the only evidence of the accuracy of screening ultrasound in explicitly asymptomatic populations.

### Yield of Screening for Thyroid Cancer

We found 10 studies that reported the yield of thyroid cancer cases from screening: four from palpation plus followup ultrasound,^54-56, 59^ four from ultrasound only,^57, 58, 60, 61^ and two older studies from palpation plus followup thyroid imaging using iodine or technetium in adults with a history of childhood irradiation^63, 64^ (Table 3). Four fair-quality studies, two in Japan (n=199,084) and two in Finland (n=352), reported the yield of thyroid cancer cases from screening palpation followed by ultrasound (if applicable) from 1980 to 2005.^54-56, 59^ Overall, from 0 to 4.3 thyroid cancer cases were detected per 1,000 persons, and 90 percent of cases (372/415) were revealed to be papillary thyroid cancer. Three fair-quality prospective studies and one fair-quality retrospective study (n=20,521) on ultrasound screening for thyroid cancer were conducted in South Korea from 1997 to 2007,^57, 58, 60, 61^ three of which were exclusively among women who presented for breast cancer screening or followup.^57, 60, 61^ In these four studies, 9.2 to 30.3 thyroid cancer cases were detected per 1,000 persons, and all but one case was diagnosed as papillary thyroid cancer. Studies were inconsistent in whether they reported the size and stage of screen-detected cancer. One study reported that 43 percent of ultrasound screen-detected patients had extrathyroidal extension.^61^ All four studies reported that 33 to 63 percent of patients with screen-detected thyroid cancer had lymph node metastases, with the highest percent detected by palpation and the lowest percent detected by ultrasound.^54, 59-61^

Table 3 Key Question 2 Results: Cancer Yield From Thyroid Cancer Screening

Screening Method | Study, Year, Quality | N Analyzed | Cancer Yield per 1,000 Persons | Histology | Cancer Diagnosis | Malignant Tumors With Positive Lymph Node Metastases, %
Average-risk population
Palpation | Suehiro, 2006^59^ Fair | 46,433 | 4.3 | Papillary, follicular | Based on surgical pathology or metastatic disease on clinical followup | Men: 58 Women: 38
Palpation | Brander, 1991^55^ Fair | 253 | 0 | NA | Based on FNA cytology | NA
Palpation | Brander, 1989^56^ Fair | 99 | 0 | NA | Based on FNA cytology | NA
Palpation | Ishida, 1988^54^ Fair | 152,651 | 1.4 | Papillary, follicular, and 1 medullary | Based on surgical pathology | 63
US | Kim, 2010^57^ Fair | 2,079 | 25.5 | Papillary only | Based on FNA cytology | NR
US | Kim, 2008^58^ Fair | 16,352 | 9.2 | Papillary only | Based on FNA cytology | NR
US | Lee, 2003^61^ Fair | 693 | 30.3 | Papillary only | Based on surgical pathology | 33
US | Chung, 2001^60^ Fair | 1,397 | 26.5 | Papillary and 1 insular | Malignant on FNA biopsy and confirmed with surgical pathology | 41
High-risk population
Palpation + diagnostic followup^*^ | Ron, 1984^62^ Fair | 443 | 0 | NA | Based on surgical pathology | NA
Palpation + diagnostic followup^†^ | Shimaoka, 1982^63^ Fair | 1,500 | 11.3 | NR | Based on surgical pathology | NR

* Diagnostic followup consisted of thyroid scan with technetium-99m and thyroid function tests.

† Diagnostic followup consisted of thyroid imaging by iodine 123 thyroid scan, blood tests, and indirect laryngoscopy.

Abbreviations: KQ=key question; US=ultrasonography; FNA=fine-needle aspiration; NA=not applicable; NR=not reported.

Two fair-quality prospective studies, one conducted in the United States (n=1,500) and the other in Israel (n=443), reported the yield of thyroid cancer in persons who had been treated with irradiation in childhood.^63, 64^ Most of the subjects had been exposed to irradiation to the head and neck for benign conditions (which is no longer practiced). Initial screening in these two cohorts was by palpation; patients with palpable nodules then received thyroid imaging using iodine or technetium radioactive tracer with blood testing, including thyroid function tests. No cancer cases were detected in the smaller study, and 11.3 thyroid cancer cases per 1,000 persons were detected in the larger U.S. study. The histology of the cancer cases was not reported.

#### Limitations

The majority of these studies allow for calculation of cancer yield but not test performance. Across the studies, there was some variation in how cancer was identified and defined using histology from FNA, surgery, or both. Cancer yield varied by screening modality; however, differences in population characteristics (e.g., age, sex, personal history of irradiation) may have contributed to this variation.

## KQ 3 What Are the Harms of Screening for Thyroid Cancer in Adults?

We found three studies that met our inclusion criteria for KQ 3 (Table 4). We found no studies that examined the harms of thyroid cancer screening with palpation or ultrasound and no studies that directly examined the effects of overdiagnosis in a screened versus unscreened group. A number of other study designs may indirectly inform the clinical importance and magnitude of overdiagnosis in thyroid cancer screening; these studies are summarized in the Discussion section of this report. Overall, there is very limited evidence to evaluate the potential harms of screening for thyroid cancer, including harms of diagnostic followup with FNA. One small U.S. study found that about a quarter of persons who had undergone FNA of a thyroid nodule did not meet the Society of Radiologists in Ultrasound (SRU) recommendation for FNA.^65^ Nonetheless, we found no evidence to suggest serious harms to patients from ultrasound-guided FNA.

Table 4 Included Studies and Results for Key Question 3: Harms of Screening and Diagnostic Fine-Needle Aspiration

Study, Year, Quality | Country, Years Recruitment | Study Design | N | Mean Age (years) | Women (%) | Study Aim | Outcome
Hobbs, 2014^65^ Fair | USA 2010-2011 | Retrospective | 400 | 55 | 83 | To determine the proportion of thyroid nodules undergoing ultrasound-guided FNA that do not meet Society of Radiologists in Ultrasound recommendations from 2005^*^ | Persons undergoing FNA not meeting Society of Radiologists in Ultrasound recommendations: 96/400 (24.0%)
Abu-Yousef, 2011^67^ Fair | USA 2006-2007 | Retrospective | 582^†^ | 56 | 71 | To determine whether there is a significantly increased incidence of bleeding complications from ultrasound-guided FNA of neck masses in patients on antithrombotic or anticoagulant therapy (compared to patients not on therapy) | Major complications (hospitalization or intervention required): 0/582 (0%) Post-procedural hematoma: 5/582^‡^ (0.9%)
Ito, 2005^66^ Fair | Japan 1990-2002 | Retrospective | 4,912 | NR^§^ | NR^§^ | To investigate the relationship between needle tract implantation of papillary thyroid cancer and clinicopathological characteristics | Tumor implantation: 7/4,912 (0.14%)

* FNA is appropriate for nodules that have a maximum diameter of 1 cm or larger and have microcalcifications; nodules that are 1.5 cm or larger and are solid or have coarse calcifications; nodules that are 2 cm or larger and are mixed solid and cystic; and nodules with substantial growth since the prior ultrasound.

† n for thyroid masses only.

‡ Difference in incidence of hematomas between persons who were on antiplatelet or anticoagulant therapy versus persons not on therapy not statistically significant.

§ Data reported for 10 persons with outcomes: mean age 65 years and 90% female.

Abbreviations: FNA=fine-needle aspiration; KQ=key question; NR=not reported.

Two fair-quality retrospective studies evaluated the harms of FNA of thyroid nodules.^66, 67^ One large study at an institution in Japan reported the number of cases of needle tract implantation of papillary thyroid cancer from FNA.^66^ This study found 7 cases of tumor on the line of needle insertion in a total of 4,912 persons who had undergone ultrasound-guided FNA from 1990 to 2002. Subjects with needle tract implantation were older (age ≥50 years) and had a high incidence of poorly differentiated cancer and extrathyroidal extension of the tumor. It is unclear what effect, if any, this complication had on patient morbidity or mortality. A second study at a single institution in the United States evaluated if bleeding complications due to FNA were related to antiplatelet or anticoagulant therapy in a cohort of 582 patients.^67^ About a quarter of the patients were taking antiplatelet or anticoagulant medications; five of them developed a hematoma after ultrasound-guided FNA, as detected by “immediate” postprocedural ultrasound. There was no statistically significant difference in the incidence of hematoma between persons taking or not taking antiplatelet or anticoagulant medications, albeit the number of outcomes was small. This study found no major bleeding complications (e.g., bleeding requiring hospitalization) in the cohort who had undergone ultrasound-guided FNA for a thyroid mass.

Another fair-quality retrospective study was designed to determine the proportion of FNAs of thyroid nodules that did not meet clinical guideline recommendations and therefore would be considered “unnecessary” diagnostic workup.^65^ This U.S. study included 400 consecutive subjects with thyroid nodules who subsequently received ultrasound-guided FNA at a single institution. Ninety-six (24%) subjects had FNA of a nodule that did not meet the SRU recommendation published in 2005.^68^ The SRU recommends FNA for nodules that have a maximum diameter of 1.0 cm or larger and have microcalcifications, nodules 1.5 cm or larger and are solid or have coarse calcifications, nodules 2.0 cm or larger and are mixed solid and cystic, and nodules with substantial growth since a prior assessment using ultrasound.

### Limitations

Although they met our review's inclusion criteria, these fair-quality retrospective studies did not report serious harms to patients (e.g., health outcomes resulting from needle tract implantation, hematoma, or “overuse” of FNA). The SRU recommendation varies slightly from the most recent guidelines set by the ATA. It is unclear what proportion of FNAs would be considered “unnecessary” using the ATA's current recommendations.

## KQ 4 Does Treatment of Screen-Detected Thyroid Cancer Reduce Thyroid-Specific Mortality or Morbidity, Reduce All-Cause Mortality, and/or Improve Quality of Life?

We found two unique studies (reported in five articles)^69-73^ that met our inclusion criteria for KQ 4 (Table 5). We found no trials designed to evaluate if earlier treatment or treatment of screen-detected, well-differentiated thyroid cancer results in better patient outcomes compared with observation (i.e., delayed treatment) or treatment of symptomatic, well-differentiated thyroid cancer. Due to major limitations in the study designs (e.g., lack of adjustment for confounders), it is uncertain if earlier or immediate treatment versus delayed or no surgical treatment improves patient outcomes for papillary carcinoma or papillary microcarcinoma.

Table 5 Included Studies and Results for Key Question 4: Treatment Effectiveness of Screen-Detected Thyroid Cancer on Patient Health Outcomes

Study, Year, Quality | Country, Years Recruitment | Study Design, Histology | Group | N | Mean Age (years) | Women (%) | Length of Followup (mean range in years) | Thyroid Cancer-Specific Deaths (%) | Thyroid Cancer-Specific Survival (95%CI)
Davies, 2010^69^ Fair | USA 1973-2005 | Retrospective observational Papillary | IG | 35,223 | 46 | 77 | 7.6 (0-32) | 161/35,223 (0.45%) | 20-year survival: 99% (93% to 100%) ^*^10-year survival: Recommended: 99.5% (99.4% to 99.6%)
Davies, 2010^69^ Fair | USA 1973-2005 | Retrospective observational Papillary | CG | 440 | 51 | 81 | 5.9 (0-31) | 6/440 (1.4%) ^*^Recommended: 4/216 (1.9%) ^*^Not recommended: 1/165 (0.6%) (p=0.10) | 20-year survival: 97% (96% to 100%) 10-year survival: ^*^Recommended: 98.1% (95.9% to 100%) ^*^Not recommended: 99.3% (97.8% to 100%)
Davies, 2010^69^ Fair | USA 1973-2005 | Retrospective observational Papillary | IG vs. CG | | p<0.001 | p=0.06 | p<0.001 | p=0.09 | 20-year p<0.001
Oda, 2016^73^ Ito, 2014^72,†^ Ito, 2010^70^ Ito, 2003^71^ Fair | Japan 1993-2004 | Prospective observational Papillary microcarcinomas | IG | 1,055 | 52 | 91 | 6.3 (0.08-15.3) | 2/1,055 (0.2%) | NR
Oda, 2016^73^ Ito, 2014^72,†^ Ito, 2010^70^ Ito, 2003^71^ Fair | Japan 1993-2004 | Prospective observational Papillary microcarcinomas | CG | 340 | NR | 92 | 6.2 (1.5-15.6) | 0/340 (0%) | NR
Oda, 2016^73^ Ito, 2014^72,†^ Ito, 2010^70^ Ito, 2003^71^ Fair | Japan 2005-2013 | Prospective observational Papillary microcarcinomas | IG | 974 | 55^‡^ | 88 | 3.9^‡^ (1.0-9.7) | 0/974 (0%) | NR
Oda, 2016^73^ Ito, 2014^72,†^ Ito, 2010^70^ Ito, 2003^71^ Fair | Japan 2005-2013 | Prospective observational Papillary microcarcinomas | CG | 1179 | 57^‡^ | 88 | 3.9^‡^ (1.0-9.7) | 0/1179 (0%) | NR

* Subset of population (1988-2005) that had treatment recommendation as a variable and refers to SEER classification: Recommended=recommended to be treated; Not recommended (NR)=not recommended to be treated.

† Recurrence in the observation group is reported in this study.

‡ Median.

Abbreviations: CG=control or comparator group, no (immediate) surgical treatment; IG=intervention group, surgical treatment; KQ=key question.

One fair-quality retrospective observational study using SEER data from 1973 to 2005 compared survival rates of persons treated versus not treated for papillary thyroid cancer.^69^ Treatment included partial or total thyroidectomy, with or without postoperative RAI ablation. In total, 35,663 persons were analyzed; only 440 (1.2%) had not been treated. Compared with treated patients, untreated patients were older (mean age, 51 vs. 46 years), had a shorter length of followup (mean, 5.9 vs. 7.6 years), had more missing data on tumor size (46% vs. 16% undocumented size), and had a smaller proportion of small tumors (≤1 cm) (13% vs. 40%). Overall, untreated persons had a slightly worse 20-year survival rate compared with treated persons (97% vs. 99%; p<0.001). These results were not adjusted for age, sex, tumor size, or any other potential confounders between treated and untreated persons, which limited our ability to compare the effect of treatment (vs. a case mix of patients) on patient outcomes. In a subgroup analysis limited to the 381 untreated patients from 1983 to 2005, patients who were recommended for treatment had a slightly lower 10-year survival rate than those who were not recommended for treatment (98.1% vs. 99.3%; p<0.001). In comparison, treated patients had a 10-year survival rate of 99.5 percent. Survival rates were not adjusted for other important confounders.

One fair-quality prospective study (reported in four separate articles) in Japan conducted from 1993 to 2013 examined the recurrence of disease in and the survival rate of persons with papillary microcarcinoma who opted for immediate surgery versus observation or active surveillance.^70-73^ From 1993 to 2004, 1,395 persons were analyzed, 340 of whom opted for observation with ultrasound once or twice per year.^70^ Thirty-two percent (n=109) of those who opted for observation ultimately had surgery. After approximately 6 years of followup, two persons in the immediate surgery group and no persons in the observation group had died. Three percent (32/1,055) of subjects in the immediate surgery group experienced disease recurrence, and no subjects in the observation group developed distant metastases. An additional 2,153 persons were diagnosed with papillary microcarcinoma from 2005 to 2013, 1,179 of whom opted for active surveillance and 974 of whom opted for immediate surgery.^73^ Only 8 percent (n=94) of those who opted for observation ultimately had surgery. After approximately 4 years of followup, no patients in either group developed distant metastases or died from thyroid cancer. Again, patients self-selected into one of two groups; therefore, the observation group had several statistically significant differences compared with the immediate surgery group at baseline, and outcomes were not adjusted for any confounders.

### Limitations

Although these fair-quality observational studies met our review's inclusion criteria, neither was adequately designed to evaluate the benefit of early surgical treatment versus observation (i.e., delayed or no surgery). Both studies had minimal or no adjustment for potential confounders that could have affected the decision for treatment versus observation of thyroid cancer.

## KQ 5 What Are the Harms of Treating Screen-Detected Thyroid Cancer?

Fifty-two studies met our inclusion criteria for KQ 5. Thirty-six studies reported on surgical harms (i.e., total or partial thyroidectomy [including lobectomy], with or without lymph node dissection) (Table 6) and 16 studies reported on RAI harms (Table 7). Due to changes in the dose of RAI and the case mix of persons receiving RAI over time, we excluded older studies that addressed the long-term sequelae of RAI but summarize these studies in the Discussion section of this report. Overall, permanent surgical harms, hypoparathyroidism, and recurrent laryngeal nerve palsy are not uncommon. The rate of permanent hypoparathyroidism varies widely; best estimates are from 2 to 6 events per 100 thyroidectomies and are more variable with lymph node dissection. The rate of permanent recurrent laryngeal nerve palsy is less variable and estimated at 1 or 2 events per 100 surgeries (including with lymph node dissection). Other serious surgical harms include death, adverse cardiopulmonary events, airway injury, wound complications, and infection. Having thyroid cancer is associated with an increased risk of second primary malignancies; however, best evidence suggests that treatment of differentiated thyroid cancer with RAI is independently associated with a small increase in second primary malignancies, although differences in study designs and variable reporting on radiation doses limit our understanding of the magnitude and precision of this small excess risk. Nonetheless, studies demonstrate that common clinically used doses of RAI are associated with an increased risk of both second solid and hematologic malignancies. RAI treatment is also associated with increased permanent adverse effects to the salivary gland, such as dry mouth.

Table 6 Included Studies for Key Question 5: Harms of Surgical Treatment of Screen-Detected Thyroid Cancer

Author, Year, Quality | Country, Recruiting Years | Study Design | N | Mean Age (years) | Women (%) | Permanent Hypoparathyroidism | Permanent RLN Palsy | Other Serious Harms
Oda, 2016^73^ Fair | Japan 2005-2013 | Prospective observational | 974^*^ | 56 | 88 | X | X | Wound infection
Chang, 2015^79^ Fair | South Korea 2002-2013 | Retrospective observational | 613 | 46 | 91 | X | X | Hematoma requiring reoperation
Del Rio, 2015^80^ Fair | Italy 2005-2007 | Prospective observational | 105 | 59 | 82 | X | NR | NR
Donatini, 2015^81^ Fair | France 1991-2015 | Prospective observational | 880 | 48 | 81 | X | X | NR
Kwan, 2015^82^ Fair | Hong Kong 1995-2011 | Retrospective observational | 105 | 51 | 78 | X | X | Airway injury
Viola, 2015^77^ Fair | Italy 2008-2010 | RCT | 181 | 45 | 75 | X | NR | NR
Ahn, 2014^83^ Fair | South Korea 2000-2007 | Retrospective observational | 361 | 48 | 85 | X | X | NR
Conzo, 2014^78^ Fair | Italy 1998-2005 | Retrospective observational | 752 | 45 | 80 | X | X | Hematoma requiring reoperation
Francis, 2014^105^ Fair | USA 1991-2009 | Retrospective observational | 5,670 | 74 | 69 | NR | X | NR
Kim, 2014^102^ Fair | South Korea 2011-2012 | Retrospective observational | 515 | 46 | 82 | X | X | Wound infection
Tartaglia, 2014^74^ Fair | Italy 2000-2010 | Retrospective observational | 347 | 48 | 78 | X | X | NR
Boute, 2013^84^ Fair | France 1998-2009 | Retrospective observational | 83 | 51 | 55 | X | X | NR
Calo, 2013^86^ Fair | Italy 2002-2008 | Retrospective observational | 215 | 51 | 81 | X | X | Hematoma requiring reoperation
Hartl, 2013^90^ Fair | France 1995-2010 | Retrospective observational | 246 | 46 | 78 | X | X | NR
Caliskan, 2012^85^ Fair | South Korea 2000-2005 | Retrospective observational | 842 | 46 | 91 | X | NR | Tracheal injury
Cirocchi, 2012^88^ Fair | Italy 2009-2010 | CCT | 321 | NR | 55 | X | X | Wound infection
Giordano, 2012^89^ Fair | Italy 1997-2010 | Retrospective observational | 1,087 | NR | NR | X | X | NR
Hyun, 2012^75,‡^ Fair | South Korea 2002-2009 | Retrospective observational | 152 | 47 | 81 | X | NR | NR
Raffaelli, 2012^94^ Fair | Italy 2008-2010 | CCT | 186 | 43 | 80 | X | X | NR
Kim 2011^103^ Fair | South Korea 2008-2009 | Retrospective observational | 302 | 52 | 75 | X | X | Wound infection, chyle fistula
Lee, 2010^91^ Fair | South Korea 2006-2007 | Retrospective observational | 2,636 | 47 | 86 | X | X | NR
Raj, 2010^95^ Fair | Australia 1993-2008 | Retrospective observational | 125 | 48 | 76 | X | X | NR
So, 2010^98^ Fair | South Korea 2005-2009 | Retrospective observational | 551 | 50 | 80 | X | X | Hematoma requiring reoperation
Moo, 2009^92^ Fair | USA 2003-2009 | Prospective observational | 116 | 47 | 76 | X | X | NR
Zerey, 2009^§,107^ Fair | USA 1999-2003 | Retrospective observational | 13,854 | 48 | 76 | NR | NR | Wound infection, tracheal or laryngeal perforation, esophageal perforation, adverse cardiopulmonary event (i.e., MI, CVA, PE), pneumonia, renal failure, same-stay mortality
Palestini, 2008^93^ Fair | Italy 2000-2006 | Retrospective observational | 305 | 47 | 73 | X | X | NR
Son, 2008^76^ Fair | South Korea 2003-2005 | Retrospective observational | 114 | 48 | 75 | X | X | NR
Spear, 2008^99^ Fair | USA 1996-2000 | Retrospective observational | 82 | 42^†^ | 70 | X | X | Phrenic nerve injury
Yassa, 2007^101^ Fair | USA 1995-2004^‡^ | Retrospective observational | 2,587 | 50 | 88 | X | X | NR
Shah, 2006^§,104^ Fair | Canada 2002-2003 | Prospective observational | 76 | 46 | 82 | X | NR | NR
Sywak, 2006^100^ Fair | Australia 1995-2005 | Retrospective observational | 447 | 42 | 72 | X | X | Wound infection
Holzer, 2000^109,§^ Fair | Germany 1996 | Prospective observational | 2,376 | 51^†^ | 77 | NR | NR | Wound infection
Hundahl, 2000^108,§^ Fair | USA 1996 | Prospective observational | 5,584 | 45^†^ | 75 | NR | NR | Wound infection, airway problem, postoperative death
Chaplin, 1999^87^ Fair | Australia NR | Retrospective observational | 175 | 45^†^ | 70 | X | X | NR
Sim, 1998^97^ Fair | Singapore 1988-1994 | Retrospective observational | 149 | 45^†^ | 75 | X | X | NR
Shindo, 1995^96^ Fair | USA 1989-1994 | Retrospective observational | 181 | NR | 90 | X | X | NR

* N analyzed for persons evaluated for surgical harms; total study population was 2,153.

† Median or calculated based on median.

‡ 2002-2004 for surgical harms data.

§ Not included in meta-analysis because study does not report permanent hypoparathyroidism or RLN palsy, or it does not clearly define outcomes as permanent or temporary.

Abbreviations: CCT=controlled clinical trial; CVA=cerebrovascular accident; KQ=key question; NR=not reported; RCT=randomized, controlled trial; RLN=recurrent laryngeal nerve; MI=myocardial infarction; PE=pulmonary embolus; X=reported.

Table 7 Included Studies for Key Question 5: Harms of RAI Treatment of Screen-Detected Thyroid Cancer

Author, Year, Quality | Country, Recruiting Years | Study Design | N | Mean Age (Years) | Women (%) | Second Primary Malignancy | Salivary Gland Harms | Other Serious Harms
Hakala, 2015^112^ Fair | Finland 1981-2002 | Retrospective observational | 910 | 49 | 82 | X | NR | NR
Khang, 2015^113^ Fair | South Korea 1976-2010 | Retrospective observational | 2,468 | 46 | 84 | X | NR | NR
Lin, 2015^114^ Fair | Taiwan 2000-2008 | Prospective observational | 10,361 | 46 | 100 | X | NR | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | Retrospective observational | 211,360 | 48 | 82 | X | NR | NR
Lang, 2012^111^ Lang, 2011^125^ Fair | Hong Kong 1971-2009 | Retrospective observational | 895 | 47 | 81 | X | NR | NR
Iyer, 2011^45^ Fair | USA 1973-2006 | Retrospective observational | 37,176 | NR | NR | X | NR | NR
Brown, 2008^110^ Fair | USA 1973-2002 | Retrospective observational | 28,286^*^ | 42^†^ | 76 | X | NR | NR
Ronckers, 2005^116^ Fair | USA 1973-2000 | Prospective observational | 29,456 | 43^†^ | 75 | X | NR | NR
Ryu, 2015 ^122^ Fair | South Korea 2010 | Prospective observational | 160 | 49 | 81 | NR | X | NR
Jeong, 2013^119^ Fair | South Korea 2003-2006 | Prospective observational | 213 | 47 | 91 | NR | X | NR
Grewal, 2009^121^ Fair | USA 1995-2003 | Retrospective observational | 262 | 45 | 66 | NR | X | NR
Ish-Shalom, 2008^118^ Fair | Israel NR | Prospective observational | 40 | 48 | 100 | NR | X | NR
Hyer, 2007^117^ Fair | UK NR | Prospective observational | 76 | 51 | 75 | NR | X | NR
Solans, 2001^120^ Fair | Spain 1990-1995 | Prospective observational | 79 | 46 | 86 | NR | X^‡^ | NR
Wu, 2015^124^ Fair | USA 1999-2008 | Retrospective observational | 18,850^§^ | 47 | 100 | NR | NR | Reproductive outcomes^‖^
Lin, 2014^123^ Good | Taiwan 1997-2008 | Retrospective observational | 8,946 | 44 | 81 | NR | NR | Hyperparathyroidism

* 28,286 is the total number included in the RAI analysis; total n for the study is 30,278.

† Median.

‡ Study also reported dry eyes.

§ Total cohort included 25,333 persons; the reproductive outcomes subset included 18,850 women.

‖ Birthrate and median time to first delivery.

Abbreviations: KQ=key question; NR=not reported; X=reported.

### Surgical Harms

We found 36 studies that reported surgical harms, 32 studies of permanent hypoparathyroidism (hypocalcemia),^73-104^ 28 studies of permanent recurrent laryngeal nerve palsy (vocal cord paralysis),^73, 74, 76, 78-84, 86-103, 105, 106^ two studies of surgical mortality,^107, 108^ and 15 studies of other major surgical harms^73, 78, 79, 82, 85, 86, 88, 98-100, 102, 103, 107-109^ (Table 8).

Table 8 Results for Key Question 5: Harms of Surgical Treatment of Screen-Detected Thyroid Cancer

Study, Year, Quality | Treatment Arm | LN Indication | LN Side | Histology | Mean Tumor Size Category (cm) | Lymph Node Metastases (%) | N | N (%) Hypoparathyroidism | N (%) RLN Palsy
Oda, 2016^*,73^ Fair | All | NR | NR | Micropapillary | 0-1.0 | 0 | 974 | 16 (2) | 2 (0.2)
Chang, 2015^79^ Fair | All | NR | Ipsilateral and bilateral | Micropapillary | 0-1.0 | 39 | 613 | 2 (0) | 2 (0)
Del Rio, 2015^80^ Fair | All | NR | NR | Papillary | 1.1-2.0 | NR | 105 | 0 (0) | NR
Donatini, 2015^81^ Fair | Less than TT | NR | NR | Micropapillary | 0-1.0 | 1 | 69 | 0 (0) | 0 (0)
Donatini, 2015^81^ Fair | TT | NR | NR | Micropapillary | 0-1.0 | 14 | 251 | 5 (2) | 3 (1)
Kwan, 2015^82^ Fair | TT | NA | NA | Papillary | 1.1-2.0^‡^ | NR | 51 | 1 (2) | 1 (2)
Kwan, 2015^82^ Fair | TT+ LND | Prophylactic | Ipsilateral and bilateral | Papillary | 2.1-4.0^‡^ | NR | 53 | 2 (4) | 0 (0)
Viola, 2015^77^ Fair | TT | NA | NA | Papillary | 1.1-2.0 | 7 | 88 | 7 (8) | NR
Viola, 2015^77^ Fair | TT+ LND | Prophylactic | Bilateral | Papillary | 1.1-2.0 | 46 | 93 | 18 (19) | NR
Ahn, 2014^83^ Fair | TT | NA | NA | Papillary | 1.1-2.0 | NR | 291 | 13 (4) | 8 (3)
Ahn, 2014^83^ Fair | TT+ LND | Prophylactic | NR | Papillary | 2.1-4.0 | 64 | 70 | 8 (11) | 1 (1)
Conzo, 2014^78^ Fair | TT | NA | NA | Differentiated | 1.1-2.0 | NR | 390 | 4 (1) | 3 (1)
Conzo, 2014^78^ Fair | TT+ LND | Prophylactic | Bilateral | Differentiated | 1.1-2.0 | NR | 362 | 13 (4) | 6 (2)
Francis, 2014^105^ Fair | TT | NA | NA | Mixed (all) | Unable to determine | NR | 5,670^†^ | NR | 119 (2) ^†^
Kim, 2014^102^ Fair | TT+ LND | Prophylactic and therapeutic | Ipsilateral and bilateral | Papillary | 0-1.0 | 42 | 392 | 0 (0) | 1 (0)
Tartaglia, 2014^74^ Fair | TT | NA | NA | Papillary | 1.1-2.0 | NR | 284 | 27 (10) | 8 (3)
Tartaglia, 2014^74^ Fair | TT+ LND | NR | NR | Papillary | 1.1-2.0 | NR | 63 | 16 (25) | 1 (2)
Boute, 2013^84^ Fair | TT | NA | NA | Differentiated | Unable to determine | 44 | 22 | 2 (9) | 1 (5)
Boute, 2013^84^ Fair | TT+ LND | NR | NR | Differentiated | Unable to determine | 44 | 61 | 4 (7) | 2 (3)
Calo, 2013^86^ Fair | TT | NA | NA | Differentiated | 1.1-2.0 | NR | 169 | 8 (5) | 0 (0) ^†^
Calo, 2013^86^ Fair | TT+ LND | Prophylactic | NR | Differentiated | 1.1-2.0 | NR | 46 | 5 (11) | 0 (0) ^†^
Hartl, 2013^90^ Fair | TT | NA | NA | Papillary | 2.1-4.0^‡^ | NR | 91 | 6 (7) ^†^ | 2 (2) ^†^
Hartl, 2013^90^ Fair | TT+ LND | Prophylactic | Ipsilateral and bilateral | Papillary | 2.1-4.0^‡^ | 52 | 155 | 4 (3) ^†^ | 2 (1) ^†^
Caliskan, 2012^85^ Fair | Less than TT+ LND | Prophylactic | Ipsilateral | Micropapillary | 0-1.0^‡^ | 26 | 414 | 0 (0) | NR
Caliskan, 2012^85^ Fair | TT+ LND | Prophylactic | Ipsilateral | Micropapillary | 0-1.0^‡^ | 26 | 428 | 11 (3) | NR
Cirocchi, 2012^88^ Fair | TT+ LND | NR | NR | Differentiated | 1.1-2.0^‡^ | NR | 120 | 2 (2) | 2 (2)
Giordano, 2012^89^ Fair | TT | NA | NA | Papillary | Unable to determine | NR | 394 | 25 (6) | 4 (1)
Giordano, 2012^89^ Fair | TT+ LND | Prophylactic | Ipsilateral | Papillary | Unable to determine | NR | 385 | 27 (7) | 2 (1)
Giordano, 2012^89^ Fair | TT+ LND | Prophylactic | Bilateral | Papillary | Unable to determine | NR | 308 | 50 (16) | 7 (2)
Hyun, 2012^75^ Fair | Less than TT | NA | NA | Micropapillary | 0-1.0 | NR | 87 | 0 (0) ^¶^ | NR
Hyun, 2012^75^ Fair | Less than TT+ LND | Prophylactic | Ipsilateral | Micropapillary | 0-1.0 | 29 | 65 | 0 (0)^¶^ | NR
Raffaelli, 2012^94^ Fair | TT | NA | NA | Papillary | 1.1-2.0 | 10 | 62 | 0 (0)^†^ | 0 (0)^†^
Raffaelli, 2012^94^ Fair | TT+LND | Prophylactic | Ipsilateral | Papillary | 1.1-2.0 | 29 | 62 | 0 (0)^†^ | 1 (2)^†^
Raffaelli, 2012^94^ Fair | TT+LND | Prophylactic | Bilateral | Papillary | 1.1-2.0 | 42 | 62 | 1 (2)^†^ | 0 (0)^†^
Kim, 2011^103^ Fair | TT+LND | Prophylactic | Ipsilateral | Micropapillary | 0-1.0 | NR | 138 | 4 (3) | 0 (0)
Lee, 2010^91^ Fair | Less than TT+LND | Prophylactic and therapeutic | NR | Mixed (all) | 0-1.0 | NR | 636 | 0 (0) | NR
Lee, 2010^91^ Fair | TT+LND | Prophylactic and therapeutic | NR | Mixed (all) | 0-1.0 | NR | 1,390 | 4 (0) | 3 (0)
Lee, 2010^91^ Fair | TT+LND | Therapeutic | Ipsilateral | Mixed (all) | 1.1-2.0 | NR | 513 | 3 (1) | 1 (0)
Lee, 2010^91^ Fair | TT+LND | Therapeutic | Bilateral | Mixed (all) | 1.1-2.0 | NR | 97 | 1 (1) | NR
Raj, 2010^95^ Fair | All | NR | NR | Mixed (all) | Unable to determine | 1 | 125 | 0 (0)^†^ | 1 (1)^†^
So, 2010^98^ Fair | All | Prophylactic | Bilateral | Micropapillary | 0-1.0 | 37 | 551 | 6 (1) | 7 (1)
Moo, 2009^92^ Fair | TT+LND | Prophylactic | Ipsilateral | Papillary | Unable to determine | NR | 12 | 0 (0) | 0 (0)
Moo, 2009^92^ Fair | TT+LND | Prophylactic | Bilateral | Papillary | 1.1-2.0 | 45 | 104 | 0 (0) | 0 (0)
Zerey, 2009^107^ Fair | Less than TT | NA | NA | NR | Unable to determine | NR | 4,238 | NR^¶^ | NR^¶^
Zerey, 2009^107^ Fair | TT | NA | NA | NR | Unable to determine | NR | 9,616 | NR^¶^ | NR^¶^
Palestini, 2008^93^ Fair | TT | NA | NA | Papillary | 0-1.0 | NR | 148 | 4 (3) | 2 (1)^†^
Palestini, 2008^93^ Fair | TT+LND | Prophylactic | Ipsilateral | Papillary | 1.1-2.0 | 22 | 93 | 0 (0) | 0 (0)^†^
Palestini, 2008^93^ Fair | TT+LND | Therapeutic | Bilateral | Papillary | 2.1-4.0 | 72 | 64 | 0 (0) | 0 (0)^†^
Son, 2008^161^ Fair | TT+LND | Prophylactic | Ipsilateral | Papillary | 1.1-2.0 | NR | 56 | 1 (2) | 0 (0)
Son, 2008^161^ Fair | TT+LND | Prophylactic | Bilateral | Papillary | 1.1-2.0 | NR | 58 | 3 (5) | 1 (2)
Spear, 2008^99^ Fair | All | NR | NR | Mixed (all) | 2.1-4.0^‡^ | 13 | 81 | 2 (2) | 1 (1)
Yassa, 2007^101^ Fair | Less than TT | NA | NA | NR | 2.1-4.0 | NR | 296 | 2 (1)^†^ | 1 (0)^†^
Shah, 2006^104^ Fair | All | NR | Ipsilateral and bilateral | Mixed (all) | Unable to determine | 9 | 65 | 12 (18)^¶^ | NR
Sywak, 2006^100^ Fair | TT | NA | NA | Papillary | 2.1-4.0 | NR | 391 | 2 (1) | 4 (1)^†^
Sywak, 2006^100^ Fair | TT+LND | Prophylactic | Ipsilateral | Papillary | 1.1-2.0 | NR | 56 | 1 (2) | 0 (0)^†^
Holzer, 2000^109^ Fair | All | NR | NR | Differentiated | 2.1-4.0^‡^ | NR | 2,376 | NR^¶^ | NR^¶^
Hundahl, 2000^108^ Fair | Less than TT (lobectomy) | NA | NA | Mixed (all) | 1.1-2.0^‡^ | NR | 903 | NR^¶^ | NR^¶^
Hundahl, 2000^108^ Fair | Less than TT (near-total) | NA | NA | Mixed (all) | 1.1-2.0^‡^ | NR | 840 | NR^¶^ | NR^¶^
Hundahl, 2000^108^ Fair | TT | NA | NA | Mixed (all) | 1.1-2.0^‡^ | NR | 1,928 | NR^¶^ | NR^¶^
Hundahl, 2000^108^ Fair | TT+LND | NR | NR | Mixed (all) | 1.1-2.0^‡^ | NR | 1,464 | NR^¶^ | NR^¶^
Chaplin, 1999^87^ Fair | TT | NA | NA | Differentiated | 2.1-4.0^‡^ | NR | 103 | 2 (2)^†^ | 1 (1)^†^
Sim, 1998^97^ Fair | All | NR | NR | Mixed (all) | Unable to determine | NR | 141 | 4 (3) | 4 (3)
Shindo, 1995^96^ Fair | All | NA | NA | NR | Unable to determine | NR | 156 | 8 (5) ^§^ | NR
Shindo, 1995^96^ Fair | All | NA | NA | NR | Unable to determine | NR | 326 | NR | 3 (1)^†^

* N analyzed for persons evaluated for surgical harms; total study population was 2,153.

† Followup not defined.

‡ Calculated.

§ Followup ≤6 months.

¶ Not included in meta-analysis because study does not report permanent hypoparathyroidism or RLN palsy, or it does not clearly define outcomes as permanent or temporary.

Note: Studies with “All” for treatment arm indicate mixed surgery types ranging from less than total thyroidectomy to total thyroidectomy with or without lymph node dissection, and outcomes were not reported separately by surgery type.

Abbreviations: KQ=key question; LND=lymph node dissection; NA=not applicable; NR=not reported; RLN=recurrent laryngeal nerve; TT=total thyroidectomy.

Studies reporting permanent or serious surgical harms were quite varied. The majority of studies were retrospective observational studies, although we also included three trials.^77, 88, 94^ Cohort size ranged from 76 to 13,854 persons. Only seven studies were conducted in the United States.^92, 96, 99, 101, 105, 107, 108^ Most of the studies included persons who had undergone surgery for thyroid cancer in the 1990s and 2000s. The average age of subjects was in the mid-40s to early 50s, with a predominance of women. The main surgeries evaluated were total or partial thyroidectomy, with or without lymph node dissection. Two studies reported surgical harms from partial thyroidectomy alone.^75, 81^ Lymph node dissection could be unilateral, bilateral, or not specified, as well as prophylactic, therapeutic, or not specified. Overall, there were 64 study arms in 36 studies. There was some variation in how permanent harm was defined, but it was generally defined as the adverse outcome persisting beyond 6 months.

Overall, there was large variation in the rate of permanent hypoparathyroidism due to total or partial thyroidectomy without lymph node dissection (15 study arms); the 95% CI of the pooled estimate ranged from 2 to 6 events per 100 surgeries (I^2^=73%) (Figure 2). The rate of permanent hypoparathyroidism from thyroidectomy with lymph node dissection was even more varied (I^2^=73%); the 95% CI for unilateral neck dissection (10 study arms) ranged from 1 to 4 events per 100 surgeries and, for bilateral neck dissection (9 study arms), from 1 to 10 events per 100 surgeries (I^2^=91%) (Figure 3). Given the very high statistical heterogeneity, it may be misleading to quantitatively pool rates of hypoparathyroidism across studies. A study by Viola et al,^77^ an outlier for hypoparathyroidism from total thyroidectomy with bilateral lymph node dissection, was an RCT that used the “most sensitive methods available” to determine hypocalcemia. However, other studies with comparatively high estimates of permanent hypoparathyroidism from lymph node dissection did not differ notably from the other included studies in study design, population, setting, tumor, intervention, or outcome characteristics.^83, 86, 89^ The rate of hypoparathyroidism did not seem to vary by year, setting, country, study-level proxy for more advanced tumors (average age, tumor size, histology), indication for lymph node dissection (prophylactic vs. therapeutic), or definition of “permanent” outcomes. In these pooled analyses, we excluded studies that did not distinguish between permanent and temporary harms. Both the funnel plots and Egger's test suggested biased estimates due to smaller studies. Smaller studies in general appeared to report fewer events.

Figure 2 Key Question 5 Results: Permanent Hypoparathyroidism From Surgery, Stratified by Type of Thyroidectomy

Note: Tumor size=calculated mean tumor size.

Abbreviations: CI=confidence interval; RE=random effects; FE=fixed effects.

Figure 2 is a forest plot depicting the event rate of permanent hypoparathyroidism by type of thyroidectomy. There is large variation in the rate of permanent hypoparathyroidism due to total or partial thyroidectomy without lymph node dissection (15 study arms): the 95% CI of the pooled estimate ranges from 2 to 6 events per 100 surgeries (I2=73%).

Figure 3 Key Question 5 Results: Permanent Hypoparathyroidism From Surgery, Stratified by Type of Lymph Node Dissection

Note: Tumor size=calculated mean tumor size.

Abbreviations: CI=confidence interval; RE=random effects; FE=fixed effects.

Figure 3 is a forest plot depicting the event rate of permanent hypoparathyroidism stratified by unilateral, bilateral, and laterality not specified. The rate of permanent hypoparathyroidism from thyroidectomy with lymph node dissection is varied (I2=73%), with the 95% CI for unilateral neck dissection (10 study arms) ranging from 1 to 4 events per 100 surgeries and the 95% CI for bilateral neck dissection (9 study arms) ranging from 1 to 10 events per 100 surgeries (I2=91%).

In contrast, there was little variation in the rates of permanent recurrent laryngeal nerve palsy due to thyroidectomy, with or without lymph node dissection. The 95% CI for recurrent laryngeal nerve palsy from thyroidectomy without lymph node dissection (14 study arms) was 1 to 2 events per 100 surgeries (I^2^=13%) (Figure 4). Estimates were similar for thyroidectomy with lymph node dissection (33 study arms) (Figure 5).

Figure 4 Key Question 5 Results: Permanent Recurrent Laryngeal Nerve Palsy From Surgery, Stratified by Type of Thyroidectomy

Note: Tumor size=calculated mean tumor size.

Abbreviations: CI=confidence interval; RE=random effects; FE=fixed effects.

Figure 4 is a forest plot depicting the event rate of permanent recurrent laryngeal nerve palsy from surgery stratified by type of thyroidectomy. There is little variation in the rates of permanent recurrent laryngeal nerve palsy due to thyroidectomy, with or without lymph node dissection. The 95% CI for recurrent laryngeal nerve palsy from thyroidectomy without lymph node dissection (14 study arms) was 1 to 2 events per 100 surgeries (I2=13%).

Figure 5 Key Question 5 Results: Permanent Recurrent Laryngeal Nerve Palsy From Surgery, Stratified by Type of Lymph Node Dissection

Note: Tumor size=calculated mean tumor size.

Abbreviations: CI=confidence interval; RE=random effects; FE=fixed effects.

Figure 5 is a forest plot depicting the event rate of permanent recurrent laryngeal nerve palsy from surgery stratified by lymph node dissection. There is little variation in the rates of permanent recurrent laryngeal nerve palsy due to type of lymph node dissection. The 95% CI for recurrent laryngeal nerve palsy from unilateral thyroidectomy (8 study arms) was 0 to 1 events per 100 surgeries and the 95% CI for bilateral neck dissection (7 study arms) ranged from 1 to 2 events per 100 surgeries.

One fair-quality prospective study (n=2,153) by Oda et al^73^ evaluated the differential surgical harms between persons who received immediate surgery (n=974) versus active surveillance (n=1,179) for papillary microcarcinoma. Persons who received active surveillance self-selected to be followed by serial neck ultrasound and laboratory testing. Ultimately, 94 of the 1,179 persons in the active surveillance group had surgery. Median followup was 47 months (range, 12 to 116 months). Permanent hypoparathyroidism was more common in the immediate surgery group (16/974) than in the active surveillance group (1/1,179) (p<0.0001). Recurrent laryngeal nerve palsy was uncommon and therefore not different between the two groups (2 vs. 0 events in the immediate surgery vs. active surveillance groups). The difference in surgical harms resulted from the lower number of persons in the active surveillance group going on to surgery.

Two fair-quality studies reported on surgical mortality.^107, 108^ A large prospective observational cohort study in the United States of 5,584 persons with thyroid cancer who had undergone surgical treatment in 1996 found 15 deaths (0.3%) within 30 days, five of which were persons with undifferentiated or anaplastic cancer.^108^ Surgical mortality did not differ by type of surgical procedure, albeit the number of deaths was too low to make any meaningful conclusions. In a large retrospective study in the United States of 13,854 persons with thyroid cancer who had undergone surgery in 1999 to 2003, the same-stay mortality rate was 0.2 percent among those who had undergone lobectomy (9/4,238 patients) and 0.1 percent among those who had undergone total thyroidectomy (12/9,616 patients) (p=0.22).^107^ The study did not report mortality by type or stage of cancer. However, it did report other serious perioperative harms, including myocardial infarction, cerebrovascular accident, pulmonary embolus, pneumonia, airway injury (including tracheal injury), chyle leak, bleeding or hematoma requiring reoperation, and wound complications or infections. Because these harms were not consistently reported or defined, we do not discuss them further here.

#### Limitations

No studies reported serious adverse events not necessarily related to surgery (e.g., death, cardiopulmonary events) in an untreated control group. Clinical and statistical heterogeneity limited confidence in pooled estimates of permanent hypoparathyroidism. The studies did not allow us to evaluate if surgical experience or surgical volume influenced the rate of permanent surgical complications. Statistical tests for publication bias for pooled analyses of hypoparathyroidism suggested biased estimates due to small studies. Pooled estimates may underestimate complications of hypoparathyroidism.

### RAI Harms

We found 16 studies that reported harms of RAI. Eight studies addressed the risk of second primary malignancies,^45, 110-116^ six addressed permanent adverse effects on salivary glands,^117-122^ one focused on hyperparathyroidism,^123^ and one on reproductive harms^124^ (Table 9).

Table 9 Results for Key Question 5: Harms of RAI Treatment of Screen-Detected Thyroid Cancer

Author, Year, Quality | Country, Recruiting Years | N | Radiation Dose (mean or median) | Followup Duration (years) | Permanent Outcomes
Second Primary Malignancy | | | | | N outcomes/N population; incidence per 10,000 person-years; excess risk per 10,000 person-years compared with controls without thyroid cancer
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | Second primary malignancy diagnosed at least 12 months after thyroid cancer diagnosis:
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | | N | Incidence | Excess risk^†^
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | All: | 109/910 | 77.3 | N/A
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | Stratified by RAI dose:
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | >3.7 GBq RAI: | 27/214 | 93.8 | 25.3
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | ≤3.7 GBq RAI: | 56/526 | 67.4 | -4.6
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | No RAI: | 26/170 | 89.1 | 29.2
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | | p=NR | p=NR | p=NR
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | Rate ratio for second primary malignancy at any site vs. controls^‡^ without thyroid cancer:
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | >3.7 GBq RAI: | 1.37 (95% CI, 0.90 to 2.09)
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | ≤3.7 GBq RAI: | 0.94 (95% CI, 0.70 to 1.25)
Hakala, 2015^112^ Fair | Finland 1981-2002 | 910^*^ | Median: 3.7 GBq (100 mCi) Mean: 5.3 GBq (143.2 mCi) | Mean: 16.2 | No RAI: | 1.49 (95% CI, 0.96 to 2.30)
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | Nonthyroid second primary malignancy diagnosed ≥12 months after thyroid cancer diagnosis or RAI treatment:
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | | N | Incidence | Excess risk^†^
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | All: | 61/2468 | 27.9^†^ | N/A
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | Stratified by RAI dose:
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | ≥37 GBq RAI: | 11/69 | 131.4 | 101.4
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 22.3–36.9 GBq RAI: | 2/44 | 54.6 | 24.6
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 5.56–22.2 GBq RAI: | 6/302 | 19.0 | -11.1
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 1.1–5.55 GBq RAI: | 18/981 | 23.7 | -6.4
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | No RAI: | 24/1072 | 30.9 | 0.9
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | | p=NR | p=NR | p=NR
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | Adjusted odds ratio^‡^ for second primary malignancy at any site:
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | ≥37 GBq RAI: | 5.54 (95% CI, 2.64 to 11.63)
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 22.3–36.9 GBq RAI: | 2.04 (95% CI, 0.48 to 8.70)
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 5.56–22.2 GBq RAI: | 0.67 (95% CI, 0.27 to 1.66)
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | 1.1-5–55 GBq RAI: | 0.87 (95% CI, 0.47 to 1.62)
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | No RAI: | reference
Khang, 2015^113^ Fair | South Korea 1976-2010 | 2468 | Mean: 5.1 GBq (137.8 mCi) | Median: 7.0 | | p<0.001
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | Breast cancer diagnosed after thyroid cancer diagnosis:
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | | N | Incidence | Excess risk^†^
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | All: | 129/10,361 | 18.6 | N/A
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | Stratified by RAI dose:
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | >4.44 GBq RAI: | 30/2848 | 15.8 | 2.7
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | ≤4.44 GBq RAI: | 61/4221 | 21.0 | 7.9
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | No RAI: | 38/3,292 | 17.7 | 4.6
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | | p=NR | p=NR | p=NR
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | Adjusted hazard ratio^§^ for breast cancer diagnosis:
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | >4.44 GBq RAI: | 0.90 (95% CI, 0.56 to 1.46)
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | ≤4.44 GBq RAI: | 1.18 (95% CI, 0.79 to 1.77)
Lin, 2015^114^ Fair | Taiwan 2000-2008 | 10,361 | NR | Median: 6.5 | No RAI: | reference
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | Leukemia diagnosed after thyroid cancer surgery or RAI treatment:
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | | N | Incidence^†^ | Excess risk
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | All: | 72/211,360 | 1.3 | N/A
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | Stratified by RAI dose:
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | >5.5 GBq RAI: | 15/23,356 | 2.1 | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | 3.7–5.5 GBq RAI: | 21/28,441 | 3.0 | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | 1.1–3.7 GBq RAI: | 6/28,397 | 0.9 | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | ≤1.1 GBq RAI: | 4/23,547 | 0.6 | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | No RAI: | 26/107,619 | 1.0 | NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | | p=NR | p=0.001 | p=NR
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | Adjusted hazard ratios^¶^ for leukemia diagnosis:
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | >5.5 GBq RAI: | 2.08 (95% CI, 1.09 to 3.94)
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | 3.7–5.5 GBq RAI: | 3.09 (95% CI, 1.74 to 5.51)
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | 1.1–3.7 GBq RAI: | 0.88 (95% CI, 0.36 to 2.14)
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | ≤1.1 GBq RAI: | 0.62 (95% CI, 0.22 to 1.77)
Seo, 2015^115^ Fair | South Korea 2008-2013 | 211,360 | Mean: 3.7 GBq (100 mCi) | Median:2.4^†^ | No RAI: | reference
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | Nonthyroid second primary malignancy diagnosed ≥12 months after thyroid cancer diagnosis:
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | | N | Incidence | Excess risk
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | All: | 64/895 | 61.5^†^ | N/A
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | Stratified by RAI use:
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | RAI: | 56/643 | NR | NR
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | No RAI: | 8/252 | NR | NR
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | | p=0.004 | p=NR | p=NR
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | Standardized incidence ratio^¶^ for second primary malignancy at any site vs. the general population:
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | RAI: | 1.51 (95% CI, 1.14 to 1.96)
Lang, 2012^111^ Lang, 2011^162^ Fair | Hong Kong 1971-2009 | 895 | 3 GBq^\\^ (80 mCi) | Median: 7.8 | No RAI: | 0.84 (95% CI, 0.36 to 1.66)
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | Second primary malignancy diagnosed ≥6 months after thyroid cancer diagnosis:
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | | N | Incidence | Excess risk
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | All: | 3,223/37,176 | 67.0^†^ | N/A
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | Stratified by RAI use:
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | RAI: | NR | NR | 11.9
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | No RAI: | NR | NR | NR
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | | p=NR | p=NR | p=NR
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | Standardized incidence ratio^**^ for second primary malignancy at any site vs. a reference cohort of identical age, sex, race, and time:
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | RAI: | 1.18 (95% CI, 1.10 to 1.25)
Iyer, 2011^45^ Fair | USA 1973-2006 | 37,176 | NR | Mean: 11^†^ | No RAI: | 1.02 (95% CI, 0.98 to 1.06)
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | Nonthyroid second primary malignancy diagnosed ≥2 months after thyroid cancer diagnosis:
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | | N | Incidence | Excess risk
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | All: | 2,191/28,286 | 74.9^†^ | N/A
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | Stratified by RAI:
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | RAI: | 618/10,257 | 75.8 | 13.3
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | No RAI: | 1,573/18,029 | 74.6 | 3.5
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | | p=NR | p=NR | p≤0.05
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | Standardized incidence ratio^††^ for second primary malignancy at any site vs. the general population:
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | RAI: | 1.21 (95% CI, 1.12 to 1.31)
Brown, 2008^110^ Fair | USA 1973-2002 | 28,286 | NR | Mean: 10 | No RAI: | 1.05 (95% CI, 1.00 to 1.10)
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | Second primary malignancy diagnosed ≥2 months after thyroid cancer diagnosis:
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | | N | Incidence | Excess risk
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | All: | 2,214/29,456 | 78.9^†^ | 7.6
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | Stratified by RAI from 1988–2000 only (N=17,055):
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | RAI: | 236/6,745 | NR | NR
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | No RAI: | 394/8,951 | NR | NR
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | | p<0.05 | p=NR | p=NR
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | Standardized incidence ratio^‡‡^ for second primary malignancy at any site vs. the general population:
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | RAI: | 1.14 (95% CI, NR)
Ronckers, 2005^116^ Fair | USA 1973-2000 | 29,456 | NR | Median: 7.9 | No RAI: | 1.19 (95% CI, NR but excludes 1)
Salivary gland
Ryu, 2015^122^ Fair | South Korea 2010 | 160 | Range: Low dose: 1.1-2.2 GBq (29.7-59.5 mCi) High dose: ≥3.7 GBq (≥100 mCi) | Minimum: 1 | RAI treatment and dose had no effect on vocal function (as a result of salivary gland dysfunction).
Jeong, 2013^119^ Fair | South Korea 2003-2006 | 213 | Mean^\\^: 5.1 GBq (138 mCi) | Mean: 5 | RAI: dry mouth 35/213 (16.4%) No RAI: NA
Grewal, 2009^121^ Fair | USA 1995-2003 | 262 | Mean^\\^: 5.3 GBq (142 mCi) | Mean: 7 | RAI: Any: 13/262 (15%) Dry mouth: 6/262 (2%) Salivary gland swelling: 2/262 (1%) Alterations in taste: 3/262 (1%) Salivary gland pain: 1/262 (0%) Tear-duct blockage: 2/262 (1%)^§§^ No RAI: NA
Ish-Shalom, 2008^118^ Fair | Israel NR | 40 | Mean^\\†^: 4.0 GBq (109 mCi) | Mean: 8.4 | RAI: Dry mouth complaints: 8/23 (35%) (p=0.21) Difficulty swallowing: 5/23 (22%) (p=0.05) Alterations in taste: 3/23 (13%) (p=0.18) No RAI: Dry mouth complaints: 3/17 (18%) Difficulty swallowing: 0/17 (0%) Alterations in taste: 0/17 (0%)
Hyer, 2007^117^ Fair | UK NR | 76 | 3 GBq^\\^ (80 mCi) | Minimum: 2 | RAI: Dry mouth: 16/76 (21%) No RAI: NA
Solans, 2001^120^ Fair | Spain 1990-1995 | 79 | Range^\\^: 925 MBq to 18.5 GBq (25-500 mCi) | 3 | RAI: Dry mouth: 12/79 (15%) Dry eyes: 11/79 (14%) No RAI: NA
Other
Wu, 2015^124^ Fair | USA 1999-2008 | 18,850 | NR (California Cancer Registry) | Median: 4 | Birthrate^¶¶^: Did not differ overall between groups (p=0.81) by age (adjusted p-value reported) per 1,000 women-years Median time to first delivery following initial presentation: RAI: 34.5 months No RAI: 26.1 months p<0.0001
Lin, 2014^123^ Good | Taiwan 1997-2008 | 8,946 | Median^†^: 3.7 GBq (100 mCi) | Mean: 5 | Primary hyperparathyroidism: RAI: 4/6,153 patients or 27,318 person-years No RAI: 4/2,793 patients or 10,930 person-years Hazard ratio: 0.35 (95% CI, 0.09 to 1.42)

* 910 analyzed; 920 originally included in study.

† Calculated.

‡ Adjusted for age at thyroid cancer diagnosis, sex, years of diagnosis, pathology, and RAI dose.

§ Adjusted for age, all comorbidities, hormone therapy, mammography, ultrasonography, radiotherapy, chemotherapy, and thyroxine supplement.

¶ Adjusted for age and sex.

\\ Standard radiation dose of initial treatment, subsequent therapy administered as needed.

** Adjusted for age, sex, race, and time.

†† Adjusted for age, sex, and race.

‡‡ Adjusted for ethnic group, sex, age, and time.

§§ Corrected with surgery at 2 and 4 years after surgery.

¶¶ Study also reported rates of nasolacrimal duct stenosis.

Abbreviations: KQ=key question; RAI=radioactive iodine ablation; NA=not applicable; NR=not reported.

Note: 1 GBq=27.03 mCi.

Table 10 Summary of Evidence, by Key Question

Test or intervention | # Studies (k), Sample size (n), Design | Summary of Findings^*^ | Body of Evidence Limitations^†^ | Quality | Applicability
KQ 1: Effectiveness
NA | k=0 | No trials have evaluated the impact of screening for thyroid cancer on patient morbidity or mortality. | NA | NA | NA
KQ 2: Diagnostic accuracy
Palpation | k=2 n=354 Prospective diagnostic accuracy k=4 n=201,027 Pro/retrospective cohort | 2 older Finnish studies found that neck palpation was not sensitive (11.6% to 27.8%) in detecting nodules compared with ultrasound. 4 studies found the yield of cancer ranged from 0 to 4.3 cases per 1,000 persons. 2 additional studies in adults with a history of irradiation found the yield of cancer ranged from 0 to 11.3 cases per 1,000 persons. | Only 2 small studies reported diagnostic accuracy; 1 study did not follow up all persons with neck palpations. No evidence of reporting bias. | Fair | Poor: diagnostic accuracy studies are old and use a single examiner
Ultrasound | k=2 n=243 Pro/retrospective diagnostic accuracy k=2 n=2,094 Pro/retrospective cohort | 2 South Korean studies found that using any 1 of several malignant sonographic characteristics can be highly sensitive (94.3%) in detecting cancer and that using a combination (≥2) of these characteristics can be both highly sensitive (94.8%) and specific (86.6%). In 4 South Korean studies, the yield of cancer ranged from 9.2 to 30.3 cases per 1,000 persons. | Only 2 small studies reported diagnostic accuracy, neither of which followed up with the vast majority of screened individuals, such that the reported sensitivities are likely overestimates. No evidence of reporting bias. | Fair | Fair: both diagnostic accuracy studies conducted in South Korea by the same investigators, 1 of which included women only
KQ 3: Screening harms
Ultrasound | k=1 n=400 Retrospective cohort | 1 U.S. study found that 24% of persons underwent FNA of a nodule that did not meet the Society of Radiologists in Ultrasound criteria for FNA. | Only 1 study. | Fair | Poor: single-institution; standards for referral to FNA have changed
Ultrasound-guided FNA | k=2 n=5,494 Retrospective cohort | 1 Japanese study (n=4,912) observed 7 cases of needle tract implantation of papillary thyroid cancer with FNA. It is unclear what impact, if any, this had on patient outcomes. 1 U.S. study observed hematomas from FNA but no major bleeding complications requiring hospitalization. | One study for each type of harm. Possible reporting bias. | Fair | Fair: both single-institution studies
KQ 4: Treatment benefit
Surgery | k=2 n=39,211 Pro/retrospective cohort | 1 U.S. study using SEER data found that, overall, untreated persons with papillary thyroid cancer had a slightly worse 20-year survival rate (97%) than did treated persons (99%) (p<0.001). 1 Japanese study found no deaths in persons with papillary microcarcinoma who opted for ultrasound observation vs. 2 deaths in persons who opted for immediate surgery. | Studies were not designed to evaluate the comparative benefit of treatment vs. no or delayed treatment. Lack of adjustment for confounders such that it is unclear if differences in survival are due to differences in treatment vs. case mix of persons. No evidence of reporting bias. | Fair to poor | Fair: U.S. study includes persons treated in 1970s and 1980s; Japanese study includes persons with papillary microcarcinoma
KQ 5: Treatment harms
Surgery | k=36 n=43,295 Pro/retrospective cohort | The rate of permanent hypoparathyroidism varied widely; best estimates were 2 to 6 events per 100 thyroidectomies and were more variable with lymph node dissection. The rate of recurrent laryngeal nerve palsy was less variable, estimated at 1 to 2 events per 100 surgeries (with or without lymph node dissection). | Possible publication bias for hypoparathyroidism but not recurrent laryngeal nerve palsy outcomes. The driver of the wide variation of estimates is unclear. | Fair | Fair: indication for type of surgery and case mix of patients going on to surgery have changed over time
RAI | k=16 n=291,796^‡^ Pro/retrospective cohort | Treatment with RAI for differentiated thyroid cancer is associated with a small increase in primary second malignancies: approximately 12 to 13 excess cancers per 10,000 patients. Smaller studies demonstrate an association of excess cancers at clinically used doses. Other commonly reported permanent harms from RAI include dry mouth, ranging from 2.3 to 35% of persons. | Differences in study designs and variable reporting on radiation doses limits our understanding of the magnitude and precision around risk of second primary malignancies. No evidence-reporting bias for commonly reported adverse outcomes. | Fair | Fair: indication and radiation dose of RAI have changed over time

* Includes consistency and precision.

† Includes reporting bias.

‡ Calculated sample size includes only the largest study using SEER data so as to avoid double-counting studies with overlapping populations.

Abbreviations: CI=confidence interval; FNA=fine-needle aspiration; k=number of studies; n=number; NA=not applicable; RAI=radioactive iodine.

Eight fair-quality retrospective studies (n=320,912) examined the incidence of second primary malignancies in persons with differentiated thyroid cancer being treated or not treated with RAI.^45, 110, 116^ Three of the studies were conducted using SEER data, none of which reported the indication for, nor the dose of, radiation from RAI. The largest of these three studies (n=37,176) included persons with papillary thyroid cancer and used SEER data from 13 registries with data from 1973 to 2006.^45^ Second primary malignancy was defined as a solid or hematologic cancer diagnosed more than 6 months after the index thyroid cancer was diagnosed. With an average of 11 years of followup (408,750 person-years), patients who received RAI experienced an excess absolute risk of 11.9 cancer cases per 10,000 person-years compared with a reference cohort. The standardized incidence ratio (SIR), the ratio of observed to expected second primary malignancies, was 1.18 (95% CI, 1.10 to 1.25) among persons who received RAI compared with a reference population of identical age, sex, race/ethnicity, and time. For persons who did not receive RAI, the SIR was 1.02 (95% CI, 0.98 to 1.06) compared with the same reference population. The second study (n=28,286) included persons with papillary or follicular thyroid cancer using SEER data from 1973 to 2002.^110^ Second primary malignancy was defined as cancer diagnosed more than 2 months after the index thyroid cancer. With an average of 10 years of followup (292,490 person-years), patients who received RAI had an excess absolute risk of 13.3 cancer cases per 10,000 person-years compared with a reference cohort (the general U.S. population). The SIR for second primary malignancies at any site in persons who received RAI was 1.21 (95% CI, 1.12 to 1.31) compared with the general U.S. population. Among persons who did not receive RAI, the SIR was 1.05 (95% CI, 1.00 to 1.10) compared with the general U.S. population. The third SEER study (n=29,456) included persons with thyroid cancer of any histology diagnosed from 1973 to 2000.^116^ Second primary malignancy was defined as any cancer diagnosed at least 2 months after the index thyroid cancer, which included newly diagnosed thyroid cancer. On average, there was about 8 years of followup (280,580 person-years). This study did not report the number of excess cancer cases by RAI exposure status. In a subgroup of persons from 1988 to 2000, the SIR for second primary malignancies at any site in those who received RAI was 1.14 (95% CI not reported) compared with a reference population of identical age, sex, race/ethnicity, and time. The SIR for second primary malignancies appeared to be similar in persons who did not receive RAI (1.19 [95% CI not reported]), although the statistical significance between groups was not reported. It is unclear what accounts for the difference in findings in this study compared with the previous two SEER studies. However, the primary aim of the study was not to determine the excess risk of second primary malignancy from RAI, and it differs from the other two SEER studies in three main ways: 1) it was not limited to papillary cancer, 2) it included thyroid cancer as a second primary malignancy, and 3) it had shorter followup for assessment of second primary malignancy.

Three smaller studies (n=4,273), from South Korea,^113^ Finland,^112^ and Hong Kong^111, 125^ also examined the incidence of second primary malignancies in persons with differentiated thyroid cancer being treated or not treated with RAI. These studies generally reported the cumulative radiation doses in gigabecquerel (GBq) units (1 GBq=27.03 mCi). Radiation doses in clinical practice vary and generally correspond to the indication for RAI, such that lower doses (1.11 GBq) are used for ablation and higher doses (≤5.5 GBq) are used for adjuvant therapy for known or suspected residual disease.^5^ The largest study (n=2,468) included persons with differentiated thyroid cancer with at least 1 year of followup after thyroidectomy at a national university hospital in South Korea from 1976 to 2010. Second primary malignancy was defined as a nonsynchronous, nonthyroidal malignancy diagnosed at least 12 months after the index thyroid cancer diagnosis or RAI treatment. With an average of 7 years of followup (total person-years not reported), patients who received the highest cumulative dose of RAI (≥37 GBq) had an excess risk of 101.4 cancer cases per 10,000 person-years compared with the general Korean population. The excess risk decreased with lower cumulative doses (22.3 to 36.9 GBq; 24.6 cancer cases per 10,000 person-years), and no excess risk was observed at cumulative doses below 22.2 GBq. The study from Finland (n=910) included persons treated for differentiated thyroid cancer at one of two university hospitals from 1981 to 2002. Cases were matched to five controls with no prior thyroid cancer (selected from a national population register) on age, sex, and place of residence. Second primary malignancy was defined as an invasive cancer diagnosed at least 12 months after the index thyroid cancer was diagnosed. With an average of 16 years of followup (14,104 person-years) for all cases, patients who received more than the median cumulative dose of RAI (>3.7 GBq) had an excess risk of 25.3 cancer cases per 10,000 person-years compared with the controls. However, persons who did not receive any RAI also had an excess risk of 29.2 cancer cases per 10,000 person-years compared with controls. The third study from Hong Kong (n=895) included persons with papillary or follicular thyroid cancer using data from a single hospital in Hong Kong from 1971 to 2009.^111^ This study used the “standard” ablative dose (3 GBq), but higher doses were considered in the presence of more extensive disease. Second primary malignancy was defined as cancer diagnosed more than 12 months after diagnosis of the index thyroid cancer. With an average of 7.8 years of followup, 8.7 percent of patients who received RAI developed a second primary malignancy versus 3.2 percent of patients who did not receive RAI (p=0.004).

Two additional studies examined the incidence of specific subtypes of second primary malignancies—breast^114^ and leukemia^115^ diagnoses—in persons with thyroid cancer. The study examining the risk of developing breast cancer (n=10,361) included persons with thyroid cancer of any histology from Taiwan who were diagnosed from 2000 to 2008.^114^ Cases were frequency matched to four controls each from national health insurance data based on year of index diagnosis and age. Breast cancer outcomes were included if they were diagnosed after the thyroid index date or completion of RAI treatment, if RAI was received. With a median 6.5 years of followup (69,554 person-years), the excess risk of breast cancer among persons who received a cumulative RAI dose greater than 4.44 GBq was 2.7 cancer cases per 10,000 person-years compared with controls. The excess risk was 7.9 cancer cases per 10,000 person-years among persons who received a cumulative RAI dose of 4.44 GBq or less, and 4.6 cancer cases per 10,000 person-years among persons who did not receive RAI, compared with the same controls. The other study, examining the risk of developing leukemia (n=211,360), included persons with thyroid cancer of any histologic type as reported by the South Korean national health insurance claims database and diagnosed from 2008 to 2013.^115^ Leukemia diagnoses were included if they occurred after the index thyroid cancer or after completion of RAI treatment, if RAI was received. With a median 2.4 years of followup (542,845 person-years), the incidence of leukemia was elevated among persons who received the highest cumulative doses of RAI (2.1 cancer cases per 10,000 person-years among those who received >5.5 GBq and 3.0 cancer cases per 10,000 person-years among those who received 3.7 to 5.5 GBq); incidence was 1.0 case per 10,000 person-years among persons who did not receive RAI (p <0.001 for trend).

One fair-quality retrospective^121^ and five fair-quality prospective studies (n=830) assessed the permanent harms of RAI on the salivary glands.^117-120, 122^ The studies were generally small and had an average followup of 1 to 8.4 years. The mean radiation dose from RAI ranged from 1.1 to 5.3 GBq. The most common adverse effect of RAI to the salivary glands was xerostomia (dry mouth), which ranged from 2.3 to 35 percent. Dry mouth can adversely affect quality of life and vocal function and increase the risk of dental disease. One good-quality retrospective study (n=8,946), which used national data from Taiwan from 1997 to 2008, found no notable difference in the incidence of hyperparathyroidism between persons with papillary or follicular thyroid cancer who had received RAI and those who did not over an average followup of about 5 years.^123^ One fair-quality retrospective study (n=18,850) including a U.S. cohort of persons with papillary or follicular thyroid cancer found no notable difference in the birthrate between women who had received RAI and those who had not.^124^

#### Limitations

Studies evaluating the harms of RAI using SEER data prior to 1987 may include radiation from other modalities, such as brachytherapy. Studies using SEER data did not account for the dose of radiation exposure. Studies reporting dose of radiation exposure varied in study design and ranges/thresholds of radiation doses, limiting direct comparisons. Studies that evaluated the harms of RAI on second primary malignancy and on salivary glands used different study methods, including how adverse outcomes were defined and adjustment (if any) for important known confounders. In addition, most of the studies that evaluated harms to salivary glands did not use a comparator arm (i.e., persons not exposed to RAI).