# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence review to update its 1996 recommendation regarding the effectiveness of thyroid cancer screening in average- and high-risk adults. This review addresses the benefit and harms associated with thyroid cancer screening and treatment of early-stage thyroid cancer.

## Analytic Framework and Key Questions

We developed an analytic framework with five Key Questions (KQs) based on the previous review and a scan of research conducted since the previous review (Figure 1).

1. Compared with not screening, does screening adults for thyroid cancer lead to a reduced risk of thyroid-specific mortality or morbidity, reduced all-cause mortality, and/or improved quality of life?
2. What are the test performance characteristics of screening tests for detecting malignant thyroid nodules in adults?
3. What are the harms of screening for thyroid cancer in adults?
4. Does treatment of screen-detected thyroid cancer reduce thyroid-specific mortality or morbidity, reduce all-cause mortality, and/or improve quality of life?
5. What are the harms of treating screen-detected thyroid cancer?

Figure 1 Analytic Framework and Key Questions

Key Questions

1. Compared with not screening, does screening adults for thyroid cancer lead to a reduced risk of thyroid-specific mortality or morbidity, reduced all-cause mortality, and/or improved quality of life?
2. What are the test performance characteristics of screening tests for detecting malignant thyroid nodules in adults?
3. What are the harms of screening adults for thyroid cancer?
4. Does treatment of screen-detected thyroid cancer reduce thyroid-specific mortality or morbidity, reduce all-cause mortality, and/or improve quality of life?
5. What are the harms of treating screen-detected thyroid cancer?

Figure 1 is an analytic framework that depicts the five Key Questions (KQs) described in the Methods section. Specifically, it illustrates the following questions: 1) Compared with not screening, does screening adults for thyroid cancer lead to a reduced risk of thyroid-specific mortality or morbidity, reduced all-cause mortality, and/or improved quality of life? 2) What are the test performance characteristics of screening tests for detecting malignant thyroid nodules in adults? 3) What are the harms of screening for thyroid cancer in adults? 4) Does treatment of screen-detected thyroid cancer reduce thyroid-specific mortality or morbidity, reduce all-cause mortality, and/or improve quality of life? 5) What are the harms of treating screen-detected thyroid cancer?

## Data Sources and Searches

We worked with a research librarian to develop our search strategy, which was peer reviewed by a second research librarian. We searched Ovid® MEDLINE, the Cochrane Central Register of Controlled Trials, and the publisher supplied segment of PubMed to locate relevant studies for all KQs. We searched for articles published from January 1966 to January 2016. The search strategy is included in Appendix A Table 1. We supplemented our database searches by reviewing reference lists from recent and relevant systematic reviews. We also searched ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform for relevant ongoing trials (Appendix B).

## Study Selection

Two reviewers independently reviewed 10,424 titles and abstracts, using an online platform (Abstrackr^91^), and 707 articles (Appendix A Figure 1) against specified inclusion criteria (Appendix A Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or those we rated as poor quality. Appendix C lists all excluded trials.

For the screening questions (KQs 1–3), we included any studies of asymptomatic adult populations, either at general risk (e.g., unselected) or with prior personal history of radiation exposure. We excluded populations that were selected based on very high radiation exposure due to environmental disasters, inherited genetic syndromes associated with a high risk for developing thyroid cancer, or a personal history of thyroid cancer. We included any screening studies evaluating palpation, ultrasound, or both. Diagnostic accuracy studies of palpation or ultrasound had to include a reference standard (i.e., ultrasound for detection of nodules on palpation, histopathology results from FNA or surgery for detection of cancer on ultrasound). We required diagnostic accuracy studies to apply the chosen reference standard to both screen-positive and screen-negative persons (e.g., all or a random subset of screen-negative persons). Given the limited number of diagnostic accuracy studies, we also included screening studies that described the yield of cases of thyroid cancer. We excluded diagnostic procedures that included enhanced ultrasound-based techniques (e.g., elastography) or FNA. For screening effectiveness (KQ 1), we included any patient health outcome of reduced morbidity or mortality associated with thyroid cancer. For test performance (KQ 2), we included cancer detection rates and measures of diagnostic accuracy (e.g., sensitivity, specificity, positive and negative predictive values). For harms of screening (KQ 3), we included direct harms of palpation and ultrasound, subsequent harms of diagnostic FNA, and measures of overdiagnosis. For overdiagnosis, we looked for studies that compared screened versus unscreened groups. Studies that examined the rising incidence of thyroid cancer over time, the incidence and natural history of thyroid nodules and cancer, and autopsy studies were not included but are summarized in the Discussion section.

For treatment questions (KQs 4, 5), we included any studies of surgery (i.e., complete thyroidectomy, near-total thyroidectomy, lobectomy), with or without lymph node dissection or RAI ablation. We excluded studies of chemotherapy, external-beam radiation therapy, and other nonsurgical ablative treatments other than RAI. To approximate the treatment of screen-detected cancer, we excluded treatment studies among persons with metastatic disease or anaplastic thyroid cancer. We excluded surgical studies for thyroid conditions other than cancer (e.g., multinodular goiter, thyroiditis). For treatment benefit (KQ 4), we required studies to have a control group (e.g., untreated, surveillance, delayed treatment). The most commonly excluded study designs were comparative effectiveness trials or observational studies comparing one active treatment versus another (e.g., thyroidectomy vs. thyroidectomy plus lymph node dissection, robotic vs. conventional surgery). To assess the benefit of treatment, we considered the patient health outcomes of recurrence, mortality, and quality of life. For treatment harms (KQ 5), we did not require a control group for direct procedural harms (e.g., hypoparathyroidism, recurrent laryngeal nerve palsy) but did for other types of harms (e.g., second primary malignancies from RAI). The evolution of standard of care for the diagnostic workup (e.g., use of ultrasound-guided FNA) and treatment of thyroid cancer over time has resulted in a change in the case mix of patients having surgery, lymph node dissection, and/or RAI, as well as improvements in surgical techniques and RAI administered activity (doses) over time. To identify the most applicable evidence, we excluded studies conducted prior to 1990 and single-surgeon case series. We also excluded transient harms and surrogate measures (e.g., luteinizing hormone/follicle-stimulating hormone, salivary markers).

For the greatest applicability to U.S. practice, we focused on studies conducted in developed countries (“very high” development according to the United Nations Human Development Index).^48^ Because of resource constraints, we included only studies that published their results in English.

## Quality Assessment and Data Abstraction

At least two reviewers critically appraised all articles that met the inclusion criteria based on the USPSTF's design-specific quality criteria (Appendix A Table 3).^49^ We supplemented these criteria with the Newcastle-Ottawa Scale for cohort and case-control studies^50^ and Quality Assessment of Diagnostic Accuracy Studies I and II for studies of diagnostic accuracy^51, 52^ (Appendix A Table 3). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear if it met, at least one criterion but had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. The most common fatal flaw for diagnostic studies included application of the reference standard to only those participants who screened positive (verification bias), because when missing data are not random or selective, analysis will generate biased estimates of diagnostic accuracy and generally lead to overestimation of both sensitivity and specificity. We also excluded diagnostic studies if they did not describe the followup of screen-negative persons. We excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, in consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into standardized evidence tables in Microsoft Excel® (Microsoft Corp., Redmond, WA). A second reviewer checked the data for accuracy. Evidence tables were tailored for each KQ and to specific study designs. Tables generally included details on study design and quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity, risk factors for thyroid cancer), screening and treatment details, reference standard or comparator details (if applicable), length of followup, and outcomes (e.g., cancer yield, diagnostic accuracy, harms).

## Data Synthesis

We synthesized results by KQ. We used a standardized summary of evidence table to summarize the overall strength of evidence for each KQ. This table included the number and design of included studies, summary of results, consistency or precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of the findings.

Because of the limited number of studies and the clinical heterogeneity of the studies, we provided a narrative synthesis of results and used summary tables to allow for comparisons across different studies. For screening test performance (KQ 2) of palpation or ultrasound, we prioritized diagnostic accuracy (e.g., sensitivity, specificity) over yield (e.g., cancer incidence) outcomes. For harms of treatment (KQ 5), we stratified results by type of treatment (i.e., type of surgery, RAI). When possible, we conducted quantitative analyses for serious harms, including permanent hypoparathyroidism and permanent recurrent laryngeal nerve palsy. Quantitative analyses were not performed for other serious adverse events, as they were not commonly or consistently reported or defined.

For quantitative analyses, we used random-effects models to estimate rates of serious adverse events. We applied the restricted maximum likelihood estimation method to estimate 95 percent CIs. In subgroup analysis, when the number of studies was less than five, we used the fixed-effects model for the analysis. Analyses were performed using R version 3.2.2 (The R Project for Statistical Computing, Vienna, Austria). We visually inspected plots stratified or ordered by key study characteristics accounting for clinical heterogeneity among studies to see if these characteristics affected rates of surgical complications. Key study characteristics included the type of surgery (e.g., partial thyroidectomy, total thyroidectomy, with or without lymph node dissection, type of lymph node dissection), case mix of patients (e.g., histology of thyroid cancer, average tumor size, average age), setting (e.g., country, year), and type and definition of outcome (e.g., criteria for permanent adverse effect). We were not able to evaluate if study quality (all were fair quality) or surgical experience (experience and surgical volume were not reported in individual studies) affected rates of surgical complications. If mean tumor size was not reported in a study, we calculated the weighted mean tumor size by reported T stage category or tumor size category (if either was available). We assumed that T stage categories were equivalent to the following mean tumor sizes: T1=1.0 cm, T2=3.0 cm, and T3=5.0 cm. To calculate weighted means using tumor size categories that had been chosen by the study authors, we used the sum of the percentage of subjects in each category and multiplied it by the midpoint of each category. The proportion of subjects with advanced disease was based on the highest proportion of study subjects in one of the following categories: stage III–IV, T3–T4, lymph node involvement, or metastasis. We also examined whether pooled effects were biased due to small, imprecise studies having larger than expected effect sizes. We performed tests of publication bias that examined whether the distribution of the effect sizes was symmetric with respect to effect precision using funnel plots and Egger's linear regression method.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion criteria was available for public comment in January 2015. We made no substantive changes to our review methods based on the comments received. A draft version of this report was reviewed by invited content experts and federal partners listed in the acknowledgements. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and, subsequently, as appropriate, addressed in the final version of the report. Additionally, a draft of the full report was posed on the USPSTF Web site from November 22, 2016 through December 26, 2016. There were no changes made to the report based on these comments.

## USPSTF Involvement

We worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues regarding the scope of the final evidence review. This research was funded by the Agency for Healthcare Research and Quality under a contract to support the work of the USPSTF. Agency staff provided oversight for the project, assisted in external review of the draft report, and reviewed the draft report.