# Chapter 1 Introduction

## Condition Definition

Thyroid cancer starts in the thyroid gland, which is located in the front of the neck. The histologic types of thyroid cancer can be categorized into three groups based on their cellular origin and characteristics: cancer derived from the thyroid epithelium, which includes papillary and follicular carcinomas, most commonly differentiated; cancer from parafollicular (C) cells, called medullary carcinomas; and anaplastic carcinomas, the most undifferentiated type.^1, 2^ Papillary microcarcinoma refer to papillary cancer smaller than 1 cm.

## Prevalence and Burden of Disease

Palpable thyroid nodules are common, occurring in approximately 5 percent of U.S. adults age 50 years and older when screened by palpation. The prevalence of thyroid nodules increases to 16 to 68 percent of adults when screened by ultrasound.^3-5^ In contrast, thyroid cancer is uncommon, and the lifetime risk of developing it is 1.1 percent.^6^

Since 1975, the incidence of detected thyroid cancer cases has been rising in the United States for both men and women.^7^ Estimates published in 2014 showed the incidence of thyroid cancer increased from 4.9 cases per 100,000 persons in 1975 to 14.3 cases per 100,000 persons in 2009, representing an absolute increase of 9.4 cases per 100,000 persons (95% confidence interval [CI], 8.9 to 9.9).^2^ However, over time mortality rates have remained stable at about 0.5 deaths per 100,000 persons per year.^6^ According to the Surveillance, Epidemiology, and End Results Program (SEER), there are 13.5 new cases of thyroid cancer per 100,000 persons per year (age-adjusted and based on 2008–2012 cases).^6^ Thyroid cancer is 2 to 3 times more common in women than in men,^1^ and incidence is greater among whites and Asians than among blacks or American Indians/Alaska Natives.^6^ Overall, a total of 601,789 adults were living with thyroid cancer in the United States in 2012.^1, 6^ The American Cancer Society estimated 62,450 new cases of thyroid cancer would be identified in 2015.^8^ One study estimated that if current trends continue, as many as 89,500 cases may be diagnosed in 2019, costing the United States $18.6 to $21.6 billion to treat cancer diagnosed from 2010 to 2019.^9^

Differentiated thyroid cancer accounts for 90 percent of all cases.^10^ Within this category, papillary thyroid cancer accounts for about 70 to 80 percent of cases and follicular cancer accounts for 10 to 15 percent. Papillary microcarcinoma accounts for about 24 percent of thyroid cancer cases in the United States; it is typically found incidentally on imaging studies of the head or neck.^11^ Most cases of differentiated cancer occur in adults ages 30 to 50 years.^12^ Approximately 5 percent of cases of differentiated cancer occur in persons with a family history of thyroid cancer.^13^ Papillary cancer is 3 times more common in women than in men. Hürthle cell is a rare subtype of follicular thyroid cancer, accounting for less than 3 percent of cases, and is no longer classified separately from follicular cancer by the World Health Organization.^14^ Medullary and anaplastic thyroid cancer are much rarer forms, accounting for about 4 and 2 percent of cases of thyroid cancer, respectively. Medullary cancer most often occurs between the ages of 50 and 60 years. Approximately 25 percent of cases of medullary cancer are inherited and 75 percent are sporadic.^15, 16^ Most anaplastic thyroid cancer cases are diagnosed after age 65 years, and the majority of cases occur in women.^17^

## Risk Factors

Risk factors for thyroid cancer include exposure to radiation, family history of thyroid cancer, and inherited genetic syndromes. Other potential risk factors for the development of thyroid cancer include high iodine intake (either from the environment or diet), increased thyroid-stimulating hormone levels, obesity, and exposure to nitrate.^18^

Radiation exposure during childhood up to late adolescence is a well-known risk factor for thyroid cancer. Radiation exposure may come from environmental nuclear disasters (e.g., the Chernobyl accident); medical examinations (e.g., computed tomography [CT] scans, medical or dental x-rays); and medical treatment, including radiation therapy for head and neck cancer and radioactive iodine (RAI) (also called I-131 or 131I) treatment (e.g., for conditions such as hyperthyroidism).^18, 19, 20^ A pooled analysis showed an excess relative risk of thyroid cancer of 7.7 (95% CI, 2.1 to 28.7) per Gy of radiation exposure.^21^

For a better understanding of radiation exposure dose in the United States, the average person is exposed to approximately 3 mSv per year from naturally occurring materials in the environment (note the radiation dose received in Sv is equivalent to the radiation exposure in Gy).^22^ More than 80 million CT scans are performed per year in the United States alone, with an average dose of 2 to 20 mSv per examination.^22^ For solid tumors, including thyroid cancer, observational and molecular studies have noted a linear dose-response relationship for radiation exposure.^21^ There does not appear to be any critical threshold of radiation exposure as a risk factor for thyroid cancer.

Family history of thyroid cancer in a first-degree relative may increase one's risk of nonmedullary thyroid cancer by as much as 5-fold;^13, 23^ inherited genetic syndromes may increase one's risk of thyroid cancer 10-fold.^24^ The prevalence of persons with a family history of thyroid cancer is unknown. Most inherited genetic syndromes are rare. Familial adenomatous polyposis occurs in 1 per 10,000 to 15,000 persons, multiple endocrine neoplasia type 2 occurs in 1 per 30,000 to 50,000 persons, and Carney complex and Cowden syndrome are even rarer. Persons with familial adenomatous polyposis may be recommended for regular thyroid surveillance via palpation and/or ultrasound.^25^ Persons with multiple endocrine neoplasia type 2 are recommended for prophylactic thyroidectomy because they have a 70 to 100 percent chance of developing medullary thyroid cancer during their lifetime.^26^

## Natural History

The majority of cases of thyroid cancer have a very favorable natural history. However, if aggressive thyroid nodules are left untreated, they will grow over time, metastasize (most often to the lymph nodes and lungs), and can ultimately result in death.^27-29^ The natural history varies by the three types of thyroid cancer: differentiated, medullary, and anaplastic.

The 10-year overall survival rates for papillary and follicular thyroid cancer are 93 and 85 percent, respectively, for all stages of the disease.^12^ Approximately 12 percent of thyroid glands are found to be cancerous on autopsy, suggesting that a subset of differentiated cancer cases may be very slow growing and pose little to no risk to the patient.^30^

Historically, one of the most important prognostic factors for differentiated cancer is age older than 45 years.^10^ Other important prognostic factors are larger tumor size and involvement of the lymph node.^28, 31, 32^ Patients younger than age 45 years have a very low likelihood of dying of papillary or follicular cancer, which is classified as stage I or II depending only on whether there are distant metastases.^10^ For patients older than age 45 years, staging for differentiated cancer also accounts for tumor size and lymph node metastases. Spread to lymph nodes in the neck is common for patients with papillary cancer, affecting approximately 50 to more than 75 percent of cases, but less common for patients with follicular cancer, affecting less than 10 percent of cases, as follicular cancer more commonly spreads to the lungs or bones.^33^

The 10-year survival rate for medullary thyroid cancer is 75 percent.^12^ The primary feature of medullary cancer is the production of calcitonin, and levels of calcitonin production may be correlated with prognosis.^34, 35^ The most important prognostic factors include age (patients age >40 or 45 years have poorer prognosis), disease stage (later-stage disease portends a worse outcome), and extent of surgery (patients with a lobectomy have a worse prognosis than those with a total thyroidectomy; the choice is often driven by whether metastatic disease exists).^16, 17, 36^

Anaplastic thyroid cancer is extremely rare but lethal. In 90 percent of incident cases, metastases to the lymph nodes or distant organs are present at the time of diagnosis.^37-39^ Anaplastic thyroid cancer is highly aggressive and has a 1-year survival rate of only 20 percent.^12^

## Screening

There are two primary methods to screen for thyroid cancer: 1) neck palpation during a physical examination, which can identify palpable nodules, and 2) ultrasound, which can identify both palpable and nonpalpable nodules, especially those smaller than 1 cm. Ultrasound can also identify characteristics of a thyroid nodule that help predict whether a nodule is benign or malignant.^40^ Screening with both palpation and ultrasound can also identify abnormal cervical lymph nodes that may represent metastatic thyroid cancer. Screening for thyroid cancer could result in early detection of malignant thyroid nodules that are easily treatable, before the cancer spreads beyond the thyroid gland. Early detection could make treatment more effective, with potentially less harm than if administered later. Potential harms of screening include false-positive results, which may lead to unnecessary diagnostic tests. Screening may also result in overdiagnosis because it can detect very small and/or indolent tumors that might never affect a person's morbidity or mortality.^41, 42^ Overdiagnosis might also lead to overtreatment.^43^

Diagnostic workup of a thyroid nodule typically includes measurement of serum thyroid-stimulating hormone and diagnostic ultrasound of the thyroid and neck (i.e., cervical lymph nodes).^5^ Depending on the results of initial testing, additional laboratory testing and imaging may be conducted. Fine-needle aspiration (FNA), with or without ultrasound guidance, is the procedure of choice when evaluating thyroid nodules to obtain cytology. The American Thyroid Association (ATA) recommends FNA for nodules larger than 1 cm with intermediate or highly suspicious ultrasound features and for nodules larger than 1.5 cm with mildly suspicious ultrasound features. The ATA defines high, intermediate, and mild suspicion as follows:^5^

- High suspicion (malignancy risk of 70% to 90%): solid hypoechoic nodule(s) or solid hypoechoic component in partially cystic nodule(s), with at least one of the following features:
  ○ Irregular margins
  ○ Microcalcifications
  ○ Taller than wide shape
  ○ Disrupted rim calcifications, with a small extrusive hypoechoic soft-tissue component
  ○ Evidence of extrathyroidal extension
- Intermediate suspicion (malignancy risk of 10% to 20%): hypoechoic solid nodule(s) with smooth margins but without:
  ○ Microcalcifications
  ○ Extrathyroidal extension
  ○ Taller than wide shape
- Low suspicion (malignancy risk of 5% to 10%): isoechoic or hyperechoic solid nodule(s), or partially cystic nodule(s) with eccentric uniformly solid areas but without:
  ○ Microcalcifications
  ○ Irregular margin
  ○ Extrathyroidal extension
  ○ Taller than wide shape

FNA cytology, using the Bethesda System for Reporting Thyroid Cytopathology, can be classified as: 1) nondiagnostic/unsatisfactory, 2) benign, 3) atypia of undetermined significance or follicular lesion of undetermined significance (AUS/FLUS), 4) follicular neoplasm or suspicious for follicular neoplasm, 5) suspicious for malignancy, or 6) malignant.^44^ ATA guidelines recommend that persons with nondiagnostic cytology have repeat FNA with ultrasound guidance. Depending on the ultrasound characteristics, persons with indeterminate results (i.e., AUS/FLUS) may undergo additional testing (e.g., molecular testing, repeat FNA) before diagnostic surgery is pursued. Persons with nodules with malignant or suspicious cytology features generally proceed to surgery. Given the low-false negative rate of ultrasound-guided FNA, persons with nodules with a highly suspicious ultrasound pattern and benign FNA cytology are recommended to have repeat ultrasound with FNA in 12 months, whereas those with an intermediately suspicious ultrasound pattern are recommended to have repeat ultrasound in 12 to 24 months.^5^

## Treatment

Surgery is the main form of treatment for thyroid cancer. The type of surgery depends largely on what proportion of the thyroid gland is involved. Surgical options include total thyroidectomy or partial thyroidectomy (the latter is also known as a lobectomy). A partial thyroidectomy may be sufficient as the initial treatment for low-risk differentiated thyroid cancer, and is recommended if surgery is chosen for low-risk papillary microcarcinoma restricted to one lobe of the thyroid.^5^ Complete thyroidectomy (removal of the entire thyroid gland following initial lobectomy) may be performed for patients whose final pathology result comes back as malignant and for whom this diagnosis was not known or suspected preoperatively. Lymphadenectomy (lymph node dissection) may be done to remove lymph nodes that may have signs of thyroid cancer involvement (local lymph node metastasis). Preoperative neck ultrasound for cervical lymph nodes and FNA of sonographically suspicious lymph nodes are recommended to determine the need for therapeutic lymph node dissection.^5^ The ATA recommends consideration of prophylactic lymph node dissection for clinically advanced papillary thyroid cancer without known nodal involvement, but this recommendation is based on low-quality evidence.^5^ The most common permanent serious surgical harms from thyroidectomy, with or without lymph node dissection, include hypoparathyroidism (hypocalcemia) and recurrent laryngeal nerve palsy (vocal cord paralysis).

Additional treatment recommendations generally differ by postoperative disease status, tumor stage, and type of thyroid cancer. RAI is taken orally and absorbed by the thyroid. Postoperative RAI may be used for remnant ablation to destroy any normal remnant thyroid tissue or microscopic foci of cancer that may remain after surgery, which facilitates detection of recurrent disease during followup. RAI may also be used at higher therapeutic doses as adjuvant therapy to treat residual local cancer or metastatic spread outside the neck to improve the disease-free survival or disease recurrence rate in higher-risk patients.^5^ The administered activity (dose) for ablation is lower than that for therapy. RAI is not routinely recommended for patients with low-risk differentiated thyroid cancer due to its adverse effects on, for example, salivary and gonadal function, as well as possible increased risk of second primary malignancies.^45, 46^ However, RAI is routinely recommended for high-risk patients (the ATA defines “high risk” as macroscopic invasion of tumor into the perithyroidal soft tissues; incomplete tumor resection; distant metastases; postoperative serum thyroglobulin level suggestive of distant metastases; pathologic N1 disease with any metastatic lymph node ≥3 cm; or follicular thyroid cancer with extensive vascular invasion).^5, 45, 46^

External-beam radiation therapy and chemotherapy are not typically used in persons with differentiated thyroid cancer unless they have late-stage disease (stage III or IV) that did not respond to RAI therapy. Radiation therapy and chemotherapy are more commonly administered to patients with anaplastic thyroid cancer.

## Current Clinical Practice

We are unaware of any professional medical society that recommends population-based screening for thyroid cancer. Although 2015 ATA management guidelines for adult patients with thyroid nodules and differentiated thyroid cancer do not address population-based screening, they do state that there is insufficient evidence to support screening in persons with a family history of follicular cell–derived, differentiated thyroid cancer.^5^ To date, South Korea appears to be the only country in the world that regularly practices asymptomatic thyroid cancer screening using ultrasound; this practice happened opportunistically as an “add-on” option for persons undergoing sanctioned screening through an organized cancer screening program initiated in 1999.^47^

## Previous U.S. Preventive Services Task Force Recommendation

In 1996, the U.S. Preventive Services Task Force (USPSTF) stated that screening asymptomatic adults or children for thyroid cancer by neck palpation or ultrasound is not recommended (“D” recommendation). It found a lack of evidence that early detection of thyroid cancer improves outcomes and noted that neck palpation had poor sensitivity for detecting lesions, which contributed to a large number of false-positive results and resulted in unnecessary invasive testing. However, for asymptomatic persons with a history of external upper body irradiation in infancy or childhood, the USPSTF had a separate recommendation (“C” recommendation): although it found that there is insufficient evidence to recommend for or against screening in these high-risk persons, recommendations for periodic palpation can be made on other grounds, including patient preference or anxiety regarding increased risk. Insufficient evidence would likely have resulted in an “I” statement using modern grading methods.