# Appendix C Excluded Studies

## Exclusion Codes

### E Codes

E1 Study relevance
E1a Primary aim technology improvements
E2 Study design
E2a Case report or case series
E2b Comparative effectiveness only, no control (untreated arm)
E2c Diagnostic accuracy studies in persons with known nodules
E3 Setting
E3a Not a very high HDI country
E3b Nation with environmental disaster with very high radiation exposure
E4 Population
E4a Previous thyroid cancer
E4b Symptomatic
E4c Inherited genetic syndromes
E4d Thyroid disease
E4e Children ≤ 18
E5 No relevant outcomes or incomplete outcomes
E5a No additional relevant data (primary article included)
E5b Incidentally identified thyroid nodules
E6 Intervention (including outdated technology)
E6a Imaging other than ultrasound
E6b Blood tests
E6c Self-exam
E6d Chemotherapy
E6e External beam radiation therapy
E6f Non-surgical ablative treatment other than Radioactive Iodine Ablation
E6g older treatment study – pre 1980
E6h Single-surgeon practice
E7 Poor Study Quality
E8 Key existing SER with out of date MA
E9 Not in English
E10 Unable to retrieve

1 Abboud B, Sleilaty G, Tannoury J, Daher R, Abadjian G and Ghorra C. Cervical neck dissection without drains in well-differentiated thyroid carcinoma. American surgeon 2011. p. 1624-8.PMID: 22273220. KQ5e3a22273220
2 Abboud B, Tannoury J, Sleilaty G, Daher R, Abadjian G and Ghorra C. Cervical neck dissection without drainage in papillary thyroid carcinoma. Journal of Laryngology & Otology 2013. p. 299-302.PMID: 23374592. KQ5e3a23374592
3 Abel SM, Noyek AM, Freeman JL and Chapnik JS. Nonpalpable occult and metastatic papillary thyroid carcinoma. Laryngoscope 1993. p. 149-55.PMID: 8426505. KQ2E18426505
4 Abu-Eshy SA, Khan AR, Khan GM, al-Humaidi MA, al-Shehri MY and Malatani TS. Thyroid malignancy in multinodular goitre and solitary nodule. Journal of the Royal College of Surgeons of Edinburgh 1995. p. 310-2.PMID: 8523308. KQ3E48523308
5 Acun Z, Cihan A, Ulukent SC, Comert M, Ucan B, Cakmak GK and Cesur A. A randomized prospective study of complications between general surgery residents and attending surgeons in near-total thyroidectomies. Surg Today 2004/12/08 ed2004. p. 997-1001.PMID: 15580380. KQALLE3A15580380
6 Adwok JA. Evaluation and surgical treatment of solitary thyroid nodules. East African Medical Journal 1995. p. 191-3.PMID: 7796774. KQ5E6H7796774
7 Agrawal C, Guthrie L, Sturm MS, Stanek J, Martin L, Henwood-Finley M, Aldrink JH, Olshefski R and O'Brien SH. Comparison of Thyroid Nodule Prevalence by Ultrasound in Childhood Cancer Survivors With and Without Thyroid Radiation Exposure. Journal of Pediatric Hematology/Oncology 2016. p. 43-8.PMID: 26583623. KQ2E4E26583623
8 Ahn HS, Kim HJ and Welch HG. Korea's thyroid-cancer “epidemic”--screening and overdiagnosis. New England journal of medicine 2014. p. 1765-7.PMID: 25372084. KQALLE225372084
9 Ahn HY, Kang AR, Bo YH, Kim KW, Park YJ and Park DJ. The risk of breast cancer is reduced in thyroid cancer patients after radioactive iodine therapy. Boston, MA: Endocr Rev; 2011KQ5E7 (only abstract available)
10 Ahn HY, Min HS, Yeo Y, Ma SH, Hwang Y, An JH, Choi HS, Keam B, Im SA, Park do J, Park IA, Noh DY, Youn YK, Chung JK, Cho BY, Park SK and Park YJ. Radioactive Iodine Therapy Did Not Significantly Increase the Incidence and Recurrence of Subsequent Breast Cancer. Journal of Clinical Endocrinology & Metabolism 2015. p. 3486-93.PMID: 26147607. KQ5E726147607
11 Ahuja AT, Evans RM, Chick W, King WW, Metreweli C and Li AK. Role of ultrasound in the management of thyroid nodules. American journal of surgery 1992. p. 654-7.PMID: 1463118. KQ2E2C, KQ3E41463118
12 Akgul O, Ocak S, Keskek M, Koc M and Tez M. Risk of malignancy in non-diagnostic thyroid fine-needle aspiration biopsy in multinodular goitre patients. Endocrine Regulations 2011. p. 9-12.PMID: 21314205. KQ5e121314205
13 Akslen LA, Haldorsen T, Thoresen SO and Glattre E. Survival and causes of death in thyroid cancer: a population-based study of 2479 cases from Norway. Cancer Research 1991/02/15 ed1991. p. 1234-41.PMID: 1997164. KQ1E2, KQ4E21997164
14 Alexander C, Bader JB, Schaefer A, Finke C and Kirsch CM. Intermediate and long-term side effects of high-dose radioiodine therapy for thyroid carcinoma. Journal of nuclear medicine 1998. p. 1551-4.PMID: 9744341. KQ5E79744341
15 Alexander EK, Heering JP, Benson CB, Frates MC, Doubilet PM, Cibas ES and Marqusee E. Assessment of nondiagnostic ultrasound-guided fine needle aspirations of thyroid nodules. Journal of Clinical Endocrinology & Metabolism 2002. p. 4924-7.PMID: 12414851. KQ3e512414851
16 Almeida JP, Sanabria AE, Lima EN and Kowalski LP. Late side effects of radioactive iodine on salivary gland function in patients with thyroid cancer. Head & neck 2011. p. 686-90.PMID: 21484917. KQ5e3a21484917
17 Almeida JP, Vartanian JG and Kowalski LP. Clinical predictors of quality of life in patients with initial differentiated thyroid cancers.[Erratum appears in Arch Otolaryngol Head Neck Surg. 2009 Jul;135(7):636 Note: Almeida, Juliana [corrected to Almeida, Juliana Pereira]]. Archives of Otolaryngology -- Head & Neck Surgery 2009. p. 342-6.PMID: 19380354. KQ5e3a19380354
18 Al-Qahtani KH, Al Asiri M, Tunio MA, Aljohani NJ, Bayoumi Y, Fatani H and AlHadab A. “Adjuvant Radioactive iodine 133 ablation in papillary microcarcinoma of thyroid: Saudi Arabian experience”. Journal of Otolaryngology: Head and Neck Surgery 2015. p. 51.PMID: 26621255. KQ4E2B, KQ5E526621255
19 An JH, Song KH, Kim SK, Park KS, Yoo YB, Yang JH, Hwang TS and Kim DL. RAS mutations in indeterminate thyroid nodules are predictive of the follicular variant of papillary thyroid carcinoma. Clin Endocrinol (Oxf). 2014/08/12 ed2014.PMID: 25109485. KQ2E2C, KQ3E525109485
20 An YS, Yoon JK, Lee SJ, Song HS, Yoon SH and Jo KS. Symptomatic late-onset sialadenitis after radioiodine therapy in thyroid cancer. Annals of nuclear medicine 2013. p. 386-91.PMID: CN-00965525. kq5e423389626
21 Ansari-Lari MA and Westra WH. The prevalence and significance of clinically unsuspected neoplasms in cervical lymph nodes. Head & neck 2003. p. 841-7.PMID: 12966508. KQ5e512966508
22 Appetecchia M and Solivetti FM. The association of colour flow Doppler sonography and conventional ultrasonography improves the diagnosis of thyroid carcinoma. Hormone Research 2006. p. 249-56.PMID: 17016052. KQ2e2c17016052
23 Ardito G, Revelli L, Giustozzi E, Salvatori M, Fadda G, Ardito F, Avenia N, Ferretti A, Rampin L, Chondrogiannis S, Colletti PM and Rubello D. Aggressive papillary thyroid microcarcinoma: prognostic factors and therapeutic strategy. Clinical nuclear medicine 2013. p. 25-8.PMID: 23242040. KQ4e523242040
24 Ashcraft MW and Van Herle AJ. Management of thyroid nodules. II: Scanning techniques, thyroid suppressive therapy, and fine needle aspiration. Head & Neck Surgery. 1981/03/01 ed1981. p. 297-322.PMID: 6163751. KQALLE26163751
25 Atli M, Akgul M, Saryal M, Daglar G, Yasti AC and Kama NA. Thyroid incidentalomas: prediction of malignancy and management. International surgery 2006. p. 237-44.PMID: 16967687. KQ2E416967687
26 Auer G, Backdahl M, Falkmer U, Grimelius L, Lundell G and Wallin G. Follicular tumors of the thyroid gland: diagnosis, clinical aspects and nuclear DNA analysis. World journal of surgery 1992. p. 589-94.PMID: 1413829. KQ5E21413829
27 Ayala C, Navarro E, Rodriguez JR, Silva H, Venegas E and Astorga R. Conception after iodine-131 therapy for differentiated thyroid cancer. Thyroid 1998. p. 1009-11.PMID: 9848714. KQ5E6G9848714
28 Azizi G, Keller JM, Mayo ML, Piper K, Puett D, Earp KM and Malchoff CD. Thyroid Nodules and Shear Wave Elastography: A New Tool in Thyroid Cancer Detection. Ultrasound in medicine & biology 2015. p. 2855-65.PMID: 26277203. KQ2E2C26277203
29 Bae U, Dighe M, Dubinsky T, Minoshima S, Shamdasani V and Kim Y. Ultrasound thyroid elastography using carotid artery pulsation: preliminary study. Journal of ultrasound in medicine 2007. p. 797-805.PMID: 17526611. KQ2e6a17526611
30 Baier ND, Hahn PF, Gervais DA, Samir A, Halpern EF, Mueller PR and Harisinghani MG. Fine-needle aspiration biopsy of thyroid nodules: experience in a cohort of 944 patients. AJR. American Journal of Roentgenology 2009. p. 1175-9.PMID: 19770344. KQ3e519770344
31 Baloch Z, LiVolsi VA, Jain P, Jain R, Aljada I, Mandel S, Langer JE and Gupta PK. Role of repeat fine-needle aspiration biopsy (FNAB) in the management of thyroid nodules. Diagnostic Cytopathology 2003. p. 203-6.PMID: 14506672. KQ3E514506672
32 Barczynski M, Konturek A, Stopa M and Nowak W. Prophylactic central neck dissection for papillary thyroid cancer. British journal of surgery 2013. p. 410-8.PMID: 23188784. KQ4E2B, KQ5E6H23188784
33 Bellantone R, Lombardi CP, Raffaelli M, Traini E, De Crea C, Rossi ED and Fadda G. Management of cystic or predominantly cystic thyroid nodules: the role of ultrasound-guided fine-needle aspiration biopsy. Thyroid 2004. p. 43-7.PMID: 15009913. KQ3e515009913
34 Bergenfelz A, Jansson S, Kristoffersson A, Martensson H, Reihner E, Wallin G and Lausen I. Complications to thyroid surgery: results as reported in a database from a multicenter audit comprising 3,660 patients. Langenbecks Archives of Surgery 2008. p. 667-73.PMID: 18633639. KQ5e4b18633639
35 Bergholm U, Adami HO, Bergstrom R, Johansson H, Lundell G, Telenius-Berg M and Akerstrom G. Clinical characteristics in sporadic and familial medullary thyroid carcinoma. A nationwide study of 249 patients in Sweden from 1959 through 1981. Cancer 1989/03/15 ed1989. p. 1196-204.PMID: 2563669. KQ2E6, KQ3E62563669
36 Berker D, Aydin Y, Ustun I, Gul K, Tutuncu Y, Isik S, Delibasi T and Guler S. The value of fine-needle aspiration biopsy in subcentimeter thyroid nodules. Thyroid 2008. p. 603-8.PMID: 18578608. KQ3e3a18578608
37 Berthe E, Henry-Amar M, Michels JJ, Rame JP, Berthet P, Babin E, Icard P, Samama G, Galateau-Sallé F, Mahoudeau J and Bardet S. Risk of second primary cancer following differentiated thyroid cancer. European journal of nuclear medicine and molecular imaging 2004. p. 685-91.PMID: CN-00488978. KQ5e6g14747959
38 Besic N, Zgajnar J, Hocevar M and Petric R. Extent of thyroidectomy and lymphadenectomy in 254 patients with papillary thyroid microcarcinoma: a single-institution experience. Ann Surg Oncol 2009/02/04 ed2009. p. 920-8.PMID: 19189188. KQ1E2B, KQ4E2B, KQ5E6H19189188
39 Bhatkar SV, Rajan MG and Samuel AM. Screening for microalbuminuria by RIA in 131I-treated thyroid cancer patients. Nuclear Medicine Communications 1996. p. 536-9.PMID: 8822754. KQ5E58822754
40 BK R, Judhan R, Chong B, Ubert A, AbuRahma Z, Mangano W and Thompson S. False-negative results with the Bethesda System of reporting thyroid cytopathology: predictors of malignancy in thyroid nodules classified as benign by cytopathologic evaluation. American surgeon 2014. p. 811-6.PMID: 25105404. KQ3e4d, KQ5e4d25105404
41 Bogdanova TI, Zurnadzhy LY, Greenebaum E, McConnell RJ, Robbins J, Epstein OV, Olijnyk VA, Hatch M, Zablotska LB and Tronko MD. A cohort study of thyroid cancer and other thyroid diseases after the Chornobyl accident: pathology analysis of thyroid cancer cases in Ukraine detected during the first screening (1998-2000). Cancer 2006. p. 2559-66.PMID: 17083123. KQ2e3a, KQ3e3a17083123
42 Bohacek L, Milas M, Mitchell J, Siperstein A and Berber E. Diagnostic accuracy of surgeon-performed ultrasound-guided fine-needle aspiration of thyroid nodules. Annals of surgical oncology 2012. p. 45-51.PMID: 21633868. KQ3e621633868
43 Boice JD, Jr., Berg G, Bjelkengren G, Ericsson UB, Hallquist A, Lidberg M, Lundell G, Mattsson A and Tennvall J. Leukaemia incidence after iodine-131 exposure. Lancet 1992. p. 1-4.PMID: 1351599. KQ4E2B, KQ5E6G1351599
44 Bononi M, Amore Bonapasta S, Vari A, Scarpini M, Cesare A, Miccini M, Meucci M and Tocchi A. Incidence and circumstances of cervical hematoma complicating thyroidectomy and its relationship to postoperative vomiting. Head & neck 2010. p. 1173-7.PMID: CN-00772056. kq5e520029984
45 Bononi M, Tocchi A, Cangemi V, Vecchione A, Giovagnoli MR, De Cesare A, Fiori E, Volpino P, Brozzetti S, Meucci M, Scozzafava S and Cavallaro A. Lymph node dissection in papillary or follicular thyroid carcinoma. Anticancer Research 2004. p. 2439-42.PMID: 15330196. KQ5e6h15330196
46 Bozec A, Dassonville O, Chamorey E, Poissonnet G, Sudaka A, Peyrottes I, Ettore F, Haudebourg J, Bussiere F, Benisvy D, Marcy PY, Sadoul JL, Hofman P, Lassale S, Vallicioni J, Demard F and Santini J. Clinical impact of cervical lymph node involvement and central neck dissection in patients with papillary thyroid carcinoma: a retrospective analysis of 368 cases. European archives of oto-rhino-laryngology 2011. p. 1205-12.PMID: 21607578. KQ5E1021607578
47 Brandao CD, Miranda AE, Correa ND, Sieiro Netto L, Corbo R and Vaisman M. Radioiodine therapy and subsequent pregnancy. Arquivos Brasileiros de Endocrinologia e Metabologia 2007. p. 534-40.PMID: 17684613. KQ5e3a17684613
48 Brander A, Viikinkoski P, Tuuhea J, Voutilainen L and Kivisaari L. Clinical versus ultrasound examination of the thyroid gland in common clinical practice. Journal of Clinical Ultrasound 1992. p. 37-42.PMID: 1309541. KQ2E4A1309541
49 Brander A, Viikinkoski P, Tuuhea J, Voutilainen L and Kivisaari L. Clinical versus ultrasound examination of the thyroid gland in common clinical practice. J Clin Ultrasound 1992/01/01 ed1992. p. 37-42.PMID: 1309541. KQ2E4a1309541
50 Brignardello E, Corrias A, Isolato G, Palestini N, Cordero di Montezemolo L, Fagioli F and Boccuzzi G. Ultrasound screening for thyroid carcinoma in childhood cancer survivors: a case series. Journal of Clinical Endocrinology & Metabolism 2008. p. 4840-3.PMID: 18812481. KQ3e418812481
51 Brito JP, Gionfriddo MR, Al Nofal A, Boehmer KR, Leppin AL, Reading C, Callstrom M, Elraiyah TA, Prokop LJ, Stan MN, Murad MH, Morris JC and Montori VM. The accuracy of thyroid nodule ultrasound to predict thyroid cancer: systematic review and meta-analysis. Journal of Clinical Endocrinology & Metabolism 2014. p. 1253-63.PMID: 24276450. KQ2e2c24276450
52 Brito JP, Singh-Ospina N, Gionfriddo MR, Maraka S, Espinosa De Ycaza A, Rodriguez-Gutierrez R, Morris JC, Montori VM and Tuttle RM. Restricting ultrasound thyroid fine needle aspiration biopsy by nodule size: which tumors are we missing? A population-based study. Endocrine 2015/08/10 ed2015.PMID: 26254791. KQ3E526254791
53 Brophy C, Stewart J, O'Donovan N, McCarthy J, Murphy M and Sheahan P. Impact of Microcalcifications on Risk of Malignancy in Thyroid Nodules with Indeterminate or Benign Cytology. Otolaryngology - Head & Neck Surgery 2016. p. 46-51.PMID: 26392026. KQ2E526392026
54 Brownlie BE, Elliot JR, Ayling EM and Turner JG. Bone mineral density in patients receiving suppressive doses of thyroxine for thyroid carcinoma. New Zealand Medical Journal 1993. p. 443-4.PMID: 8233173. KQ2E28233173
55 Bucci A, Shore-Freedman E, Gierlowski T, Mihailescu D, Ron E and Schneider AB. Behavior of small thyroid cancers found by screening radiation-exposed individuals. Journal of Clinical Endocrinology & Metabolism 2001. p. 3711-6.PMID: 11502800. KQ1E6A11502800
56 Burgess JR. Temporal trends for thyroid carcinoma in Australia: an increasing incidence of papillary thyroid carcinoma (1982-1997). Thyroid 2002/03/28 ed2002. p. 141-9.PMID: 11916283. KQALLE111916283
57 Burgess JR and Tucker P. Incidence trends for papillary thyroid carcinoma and their correlation with thyroid surgery and thyroid fine-needle aspirate cytology. Thyroid 2006. p. 47-53.PMID: 16487013. KQ3E5, KQ5e516487013
58 Caglar M, Tuncel M and Alpar R. Scintigraphic evaluation of salivary gland dysfunction in patients with thyroid cancer after radioiodine treatment. Clinical nuclear medicine 2002. p. 767-71.PMID: CN-00410741. KQ5E3A, KQ2E3A12394122
59 Calo PG, Medas F, Loi G, Erdas E, Pisano G and Nicolosi A. Differentiated thyroid cancer in the elderly: our experience. International Journal Of Surgery 2014. p. S140-3.PMID: 25183640. KQ5E525183640
60 Calo PG, Medas F, Santa Cruz R, Podda F, Erdas E, Pisano G and Nicolosi A. Follicular nodules (Thy3) of the thyroid: is total thyroidectomy the best option? BMC Surgery 2014. p. 12.PMID: 24597765. KQ3E124597765
61 Campos Z, Gooding GA and Higgins CB. MRI and ultrasound detection of asymptomatic thyroid nodules in hyperparathyroidism. Journal of Computer Assisted Tomography 1992. p. 615-9.PMID: 1629423. KQ3E4D1629423
62 Canchola AJ, Horn-Ross PL and Purdie DM. Risk of second primary malignancies in women with papillary thyroid cancer. American Journal of Epidemiology 2006/01/20 ed2006. p. 521-7.PMID: 16421240. KQ5E416421240
63 Cannon CR and Replogle WH. Hypocalcemia following hemithyroidectomy. Journal of the Mississippi State Medical Association 2008. p. 265-9.PMID: 19297915. KQ4e2b, KQ5e6h19297915
64 Cappelli C, Castellano M, Pirola I, Gandossi E, De Martino E, Cumetti D, Agosti B and Rosei EA. Thyroid nodule shape suggests malignancy. European Journal of Endocrinology 2006. p. 27-31.PMID: 16793946. KQ2e2c, KQ3e416793946
65 Carpi A, Sagripanti A, Nicolini A, Santini S, Ferrari E, Romani R and Di Coscio G. Large needle aspiration biopsy for reducing the rate of inadequate cytology on fine needle aspiration specimens from palpable thyroid nodules. Biomedicine & Pharmacotherapy 1998. p. 303-7.PMID: 9809173. KQ3E59809173
66 Ceccarelli C, Bencivelli W, Morciano D, Pinchera A and Pacini F. 131I therapy for differentiated thyroid cancer leads to an earlier onset of menopause: results of a retrospective study. Journal of Clinical Endocrinology & Metabolism 2001. p. 3512-5.PMID: 11502772. KQ4E2B, KQ5E511502772
67 Ceccarelli C, Caglieresi C, Moscatelli A, Gavioli S, Santini P, Elisei R and Vitti P. Effects of radioiodine treatment for differentiated thyroid cancer on testis function. Clinical endocrinology 2015. p. 295-9.PMID: 25138547. KQ5e225138547
68 Cerbone G, Spiezia S, Colao A, Di Sarno A, Assanti AP, Lucci R, Siciliani M, Lombardi G and Fenzi G. Power Doppler improves the diagnostic accuracy of color Doppler ultrasonography in cold thyroid nodules: follow-up results. Hormone Research 1999. p. 19-24.PMID: 10640895. KQ2E2C, KQ3E510640895
69 Cerci C, Cerci SS, Eroglu E, Dede M, Kapucuoglu N, Yildiz M and Bulbul M. Thyroid cancer in toxic and non-toxic multinodular goiter. Journal of Postgraduate Medicine 2007. p. 157-60.PMID: 17699987. KQ2e3a, KQ3e3a17699987
70 Chagas JF, Aquino JL, Pascoal MB, Teixeira AS, Ferro MM, Gambaro MC and Dedivitis RA. Multicentricity in the thyroid differentiated carcinoma. Revista Brasileira de Otorrinolaringologia 2009. p. 97-100.PMID: 19488567. KQ4e3a, KQ5e3a19488567
71 Chaikhoutdinov I, Mitzner R and Goldenberg D. Incidental Thyroid Nodules: Incidence, Evaluation, and Outcome. Otolaryngology - Head & Neck Surgery. 2014/03/13 ed2014. p. 939-942.PMID: 24618501. KQ3E524618501
72 Chammas MC, Gerhard R, de Oliveira IR, Widman A, de Barros N, Durazzo M, Ferraz A and Cerri GG. Thyroid nodules: evaluation with power Doppler and duplex Doppler ultrasound. Otolaryngology - Head & Neck Surgery 2005. p. 874-82.PMID: 15944558. KQ2e3a, KQ3e3a15944558
73 Chang TC, Hsiao YL and Kuo MS. Ultrasonographic findings of papillary thyroid carcinoma and their relation to pathologic changes. Journal of the Formosan Medical Association 1994. p. 933-8.PMID: 7633197. KQ2E2, KQ3E27633197
74 Chao TC, Lin JD and Chen MF. Surgical treatment of Hurthle cell tumors of the thyroid. World journal of surgery 2005. p. 164-8.PMID: 15650796. KQ4e2b, KQ5e3a15650796
75 Chen AY, Jemal A and Ward EM. Increasing incidence of differentiated thyroid cancer in the United States, 1988-2005. Cancer. 2009/07/15 ed2009. p. 3801-7.PMID: 19598221. KQALLE219598221
76 Chiang FY, Lu IC, Tsai CJ, Hsiao PJ, Hsu CC and Wu CW. Does extensive dissection of recurrent laryngeal nerve during thyroid operation increase the risk of nerve injury? Evidence from the application of intraoperative neuromonitoring. American journal of otolaryngology 2011. p. 499-503.PMID: CN-00972797. KQ5e4d21306792
77 Chiang FY, Wang LF, Huang YF, Lee KW and Kuo WR. Recurrent laryngeal nerve palsy after thyroidectomy with routine identification of the recurrent laryngeal nerve. Surgery 2005/03/05 ed2005. p. 342-7.PMID: 15746790. KQ5E4D15746790
78 Chisholm EJ, Kulinskaya E and Tolley NS. Systematic review and meta-analysis of the adverse effects of thyroidectomy combined with central neck dissection as compared with thyroidectomy alone. Laryngoscope 2009. p. 1135-9.PMID: 19358241. KQ4e2b, KQ5e819358241
79 Chiu CG, Yao R, Chan SK, Strugnell SS, Bugis S, Irvine R, Anderson D, Walker B, Jones SJ and Wiseman SM. Hemithyroidectomy is the preferred initial operative approach for an indeterminate fine needle aspiration biopsy diagnosis. Canadian Journal of Surgery 2012. p. 191-8.PMID: 22630062. KQ3e2b22630062
80 Chiu WY, Chia NH, Wan SK, Yuen CH and Cheung MT. The investigation and management of thyroid nodules--a retrospective review of 183 cases. Annals of the Academy of Medicine, Singapore 1998. p. 196-9.PMID: 9663309. KQ3E2C9663309
81 Choi SH, Kim EK, Kwak JY, Kim MJ and Son EJ. Interobserver and intraobserver variations in ultrasound assessment of thyroid nodules. Thyroid 2010. p. 167-72.PMID: 19725777. KQ2e2c19725777
82 Choi SY, Woo SH, Shin JH, Choi N, Son YI, Jeong HS, Baek CH and Chung MK. Prevalence and prediction for malignancy of additional thyroid nodules coexisting with proven papillary thyroid microcarcinoma. Otolaryngology - Head & Neck Surgery 2013. p. 53-9.PMID: 23525852. KQ2e2c23525852
83 Choi WJ, Baek JH, Ha EJ, Choi YJ, Hong MJ, Song DE, Sung JY, Yoo H, Jung SL, Lee HY and Lee JH. The ultrasonography features of hyalinizing trabecular tumor of the thyroid gland and the role of fine needle aspiration cytology and core needle biopsy in its diagnosis. Acta Radiologica 2014/09/19 ed2014.PMID: 25232186. KQ3E1, KQ5E125232186
84 Choi WJ, Park JS, Kim KG, Kim SY, Koo HR and Lee YJ. Computerized analysis of calcification of thyroid nodules as visualized by ultrasonography. European journal of radiology 2015. p. 1949-53.PMID: 26137902. KQ2E2C26137902
85 Choi YJ, Baek JH, Baek SH, Shim WH, Lee KD, Lee HS, Shong YK, Ha EJ and Lee JH. Web-Based Malignancy Risk Estimation for Thyroid Nodules Using Ultrasonography Characteristics: Development and Validation of a Predictive Model. Thyroid 2015. p. 1306-12.PMID: 26437963. KQ2E2C26437963
86 Choi YS, Hong SW, Kwak JY, Moon HJ and Kim EK. Clinical and ultrasonographic findings affecting nondiagnostic results upon the second fine needle aspiration for thyroid nodules. Annals of surgical oncology 2012. p. 2304-9.PMID: 22395996. KQ1E4, KQ2E4, KQ3E422395996
87 Christensen SB, Bondeson L, Ericsson UB and Lindholm K. Prediction of malignancy in the solitary thyroid nodule by physical examination, thyroid scan, fine-needle biopsy and serum thyroglobulin. A prospective study of 100 surgically treated patients. Acta Chirurgica Scandinavica 1984. p. 433-9.PMID: 6495973. KQ1E1, KQ2E2C, KQ3E5, KQ4E2B, KQ5E56495973
88 Christensen SB, Ljungberg O and Tibblin S. Surgical treatment of thyroid carcinoma in a defined population: 1960 to 1977. Evaluation of the results after a conservative surgical approach. American journal of surgery 1983. p. 349-54.PMID: 6614326. KQ5E6G6614326
89 Christensen SB, Ljungberg O and Tibblin S. A clinical epidemiologic study of thyroid carcinoma in Malmo, Sweden. Current Problems in Cancer 1984. p. 1-49.PMID: 6488867. KQ3E26488867
90 Christensen SB and Tibblin S. The reliability of the clinical examination of the thyroid gland. A prospective study of 100 consecutive patients surgically treated for hyperparathyroidism. Annales Chirurgiae et Gynaecologiae 1985. p. 151-4.PMID: 4083775. KQ2E4D4083775
91 Chuang SC, Hashibe M, Yu GP, Le AD, Cao W, Hurwitz EL, Rao JY, Neugut AI and Zhang ZF. Radiotherapy for primary thyroid cancer as a risk factor for second primary cancers. Cancer Letters 2006. p. 42-52.PMID: 16039041. KQ5E6E16039041
92 Chukudebelu O, Dias A and Timon C. Changing trends in thyroidectomy. Irish Medical Journal 2012. p. 167-9.PMID: 22973651. KQ5e6h22973651
93 Chung J, Youk JH, Kim JA, Kwak JY, Kim EK, Ryu YH and Son EJ. Initially non-diagnostic ultrasound-guided fine needle aspiration cytology of thyroid nodules: value and management. Acta Radiologica 2012. p. 168-73.PMID: 21969700. KQ2e2c21969700
94 Ciatti S, Bartolozzi C, Cicchi P and Lucarelli E. The role of ultrasonography and ultrasound guided biopsy in the management of patients with cold nodules of the thyroid. Ultrasound in medicine & biology 1983. p. 387-91.PMID: 6400254. KQ2E26400254
95 Clark OH and Duh QY. Thyroid cancer. Medical Clinics of North America 1991/01/01 ed1991. p. 211-34.PMID: 1987444. KQALLE21987444
96 Cohen JP and Cho HT. The role of needle aspiration biopsy in the selection of patients for thyroidectomy. Laryngoscope 1988. p. 35-9.PMID: 3336259. KQ3E5, KQ5E53336259
97 Colombo-Benkmann M, Raff J, Raue F, Klar E and Herfarth C. [Effect of primary surgical therapy on the course of C-cell carcinoma of the thyroid gland]. Langenbecks Archiv für Chirurgie. Supplement. Kongressband. Deutsche Gesellschaft für Chirurgie. Kongress 1998. p. 1041-3.PMID: CN-00335562. KQ4E99931784
98 Colonna M, Grosclaude P, Remontet L, Schvartz C, Mace-Lesech J, Velten M, Guizard A, Tretarre B, Buemi AV, Arveux P and Esteve J. Incidence of thyroid cancer in adults recorded by French cancer registries (1978-1997). European journal of cancer 2002. p. 1762-8.PMID: 12175693. KQ3e212175693
99 Conzo G, Calo PG, Gambardella C, Tartaglia E, Mauriello C, Della Pietra C, Medas F, Santa Cruz R, Podda F, Santini L and Troncone G. Controversies in the surgical management of thyroid follicular neoplasms. Retrospective analysis of 721 patients. International Journal Of Surgery 2014. p. S29-34.PMID: 24859409. KQ5E424859409
100 Cordón C, Fajardo R, Ramírez J and Herrera M. A randomized, prospective, parallel group study comparing the Harmonic Scalpel to electrocautery in thyroidectomy. Surgery 2005. p. 337-41.PMID: CN-00502492. KQ5E6H15746789
101 Corso C, Gomez X, Sanabria A, Vega V, Dominguez LC and Osorio C. Total thyroidectomy versus hemithyroidectomy for patients with follicular neoplasm. A cost-utility analysis. International Journal Of Surgery 2014. p. 837-42.PMID: 25017947. KQ5E3A25017947
102 Creach KM, Siegel BA, Nussenbaum B and Grigsby PW. Radioactive iodine therapy decreases recurrence in thyroid papillary microcarcinoma. Isrn Endocrinology Print 2012. p. 816386.PMID: 22462017. KQ4e2b, KQ5e6h22462017
103 Dal Maso L, Lise M, Zambon P, Falcini F, Crocetti E, Serraino D, Cirilli C, Zanetti R, Vercelli M, Ferretti S, Stracci F, De Lisi V, Busco S, Tagliabue G, Budroni M, Tumino R, Giacomin A, Franceschi S and Group AW. Incidence of thyroid cancer in Italy, 1991-2005: time trends and age-period-cohort effects. Annals of oncology 2011. p. 957-63.PMID: 20952599. KQALLE620952599
104 Davies L, Morris LGT, Haymart M, Chen AY, Goldenberg D, Morris J, Ogilvie JB, Terris DJ, Netterville J, Wong RJ, Randolph G and Committee obotAESS. AMERICAN ASSOCIATION OF CLINICAL ENDOCRINOLOGISTS AND AMERICAN COLLEGE OF ENDOCRINOLOGY DISEASE STATE CLINICAL REVIEW: THE INCREASING INCIDENCE OF THYROID CANCER. Endocrine practice 2015. p. 686-696.PMID: 26135963. KQ3E526135963
105 Davies L, Ouellette M, Hunter M and Welch HG. The increasing incidence of small thyroid cancers: where are the cases coming from? Laryngoscope 2010. p. 2446-51.PMID: 21108428. KQ3e521108428
106 Davies L and Welch HG. Increasing incidence of thyroid cancer in the United States, 1973-2002. Jama 2006. p. 2164-7.PMID: 16684987. KQ3E216684987
107 Davis S. Screening For Thyroid Cancer after the Fukushima Disaster: What Do We Learn From Such An Effort? Epidemiology 2015/10/07 ed2015.PMID: 26441344. KQ1E5
108 De Pasquale L, Bastagli A, Moro GP and Ghilardi G. Thyroid microcarcinoma approach: a ten year experience. Annali Italiani di Chirurgia 2013. p. 533-9.PMID: 24140756. KQ5E524140756
109 de Vathaire F, Schlumberger M, Delisle MJ, Francese C, Challeton C, de la Genardiere E, Meunier F, Parmentier C, Hill C and Sancho-Garnier H. Leukaemias and cancers following iodine-131 administration for thyroid cancer. British Journal of Cancer 1997. p. 734-9.PMID: 9043033. KQ5E6G9043033
110 Debry C, Schmitt E, Senechal G, Siliste CD, Quevauvilliers J and Renou G. [Analysis of complications of thyroid surgery: recurrent paralysis et hypoparathyroidism. On a series of 588 cases]. Ann Otolaryngol Chir Cervicofac. 1995/01/01 ed1995. p. 211-7.PMID: 7503500. KQ5E97503500
111 Del Rio P, Arcuri MF, Ferreri G, Sommaruga L and Sianesi M. The utility of serum PTH assessment 24 hours after total thyroidectomy. Otolaryngology - Head & Neck Surgery 2005. p. 584-6.PMID: 15806050. KQ5e515806050
112 Demeter JG, De Jong SA, Lawrence AM and Paloyan E. Anaplastic thyroid carcinoma: risk factors and outcome. Surgery 1991/12/01 ed1991. p. 956-61; discussion 961-3.PMID: 1745983. KQALLE51745983
113 Demeter JG, Lawrence AM and Paloyan E. Necessity and safety of completion thyroidectomy for differentiated thyroid carcinoma. Surgery 1992. p. 734-7; discussion 737-9.PMID: 1411945. KQ5E21411945
114 Demirel K, Kapucu O, Yucel C, Ozdemir H, Ayvaz G and Taneri F. A comparison of radionuclide thyroid angiography, (99m)Tc-MIBI scintigraphy and power Doppler ultrasonography in the differential diagnosis of solitary cold thyroid nodules. European Journal of Nuclear Medicine & Molecular Imaging 2003. p. 642-50.PMID: 12612810. KQ2e3a12612810
115 Di Filippo B, Schiazzano A, Cappabianca A, Barrella G, Ferraiuolo G and Mastrorilli G. The role or lymphnodal dissection in the treatment of differentiated thyroid cancers. Journal of experimental & clinical cancer research 1998. p. 343-7.PMID: 9894773. KQ4E5, KQ5E59894773
116 Dincer N, Balci S, Yazgan A, Guney G, Ersoy R, Cakir B and Guler G. Follow-up of atypia and follicular lesions of undetermined significance in thyroid fine needle aspiration cytology. Cytopathology 2013. p. 385-90.PMID: 23078633. KQ3e3a23078633
117 Dingle IF, Mishoe AE, Nguyen SA, Overton LJ and Gillespie MB. Salivary morbidity and quality of life following radioactive iodine for well-differentiated thyroid cancer. Otolaryngology - Head & Neck Surgery 2013. p. 746-52.PMID: 23462656. KQ4e5, KQ5e723462656
118 Dixon E, McKinnon JG and Pasieka JL. Feasibility of sentinel lymph node biopsy and lymphatic mapping in nodular thyroid neoplasms. World journal of surgery 2000. p. 1396-401.PMID: 11038213. KQ5E511038213
119 Doci R, Pilotti S, Greco M and Cascinelli N. Long term results of surgical treatment of thyroid cancer. Annales de Radiologie 1977. p. 775-8.PMID: 610548. KQ5E6G610548
120 Doddi S, Chohda E, Maghsoudi S, Sheehan L, Sinha A, Chandak P and Sinha P. The final outcome of indeterminate cytology of thyroid nodules in a District General Hospital. Giornale di Chirurgia 2015. p. 122-7.PMID: 26188757. KQ3E126188757
121 Dodds P. Carcinoma of the thyroid gland in Auckland, New Zealand. Surgery, Gynecology & Obstetrics 1990. p. 27-32.PMID: 2360146. KQ4E5, KQ5E52360146
122 Dottorini ME, Lomuscio G, Mazzucchelli L, Vignati A and Colombo L. Assessment of female fertility and carcinogenesis after iodine-131 therapy for differentiated thyroid carcinoma. J Nucl Med 1995/01/01 ed1995. p. 21-7.PMID: 7799075. KQ5E67799075
123 du Cret RP and Mariash CN. Local reactions to radioiodine in the treatment of thyroid cancer. American Journal of Medicine 1991. p. 217-22.PMID: 1996591. KQ4E2B, KQ5E6G1996591
124 Duncan TD and McCord D. Thyroid carcinoma: criteria in selection of patients for total and subtotal thyroidectomy. Journal of the National Medical Association 1983. p. 401-4.PMID: 6864818. KQ4E2B6864818
125 Durante C, Attard M, Torlontano M, Ronga G, Monzani F, Costante G, Ferdeghini M, Tumino S, Meringolo D, Bruno R, De Toma G, Crocetti U, Montesano T, Dardano A, Lamartina L, Maniglia A, Giacomelli L, Filetti S and Papillary Thyroid Cancer Study G. Identification and optimal postsurgical follow-up of patients with very low-risk papillary thyroid microcarcinomas. Journal of Clinical Endocrinology & Metabolism 2010. p. 4882-8.PMID: 20660054. KQ4e2b20660054
126 Durante C, Costante G, Lucisano G, Bruno R, Meringolo D, Paciaroni A, Puxeddu E, Torlontano M, Tumino S, Attard M, Lamartina L, Nicolucci A and Filetti S. The natural history of benign thyroid nodules. Jama 2015. p. 926-35.PMID: 25734734. KQ3e225734734
127 Ebina A, Sugitani I, Fujimoto Y and Yamada K. Risk-adapted management of papillary thyroid carcinoma according to our own risk group classification system: is thyroid lobectomy the treatment of choice for low-risk patients? Surgery 2014. p. 1579-88; discussion 1588-9.PMID: 25262223. KQ4e2b, KQ5e6h25262223
128 Eden K, Mahon S and Helfand M. Screening high-risk populations for thyroid cancer. Medical & Pediatric Oncology 2001. p. 583-91.PMID: 11340616. KQ2E811340616
129 Edmonds CJ and Smith T. The long-term hazards of the treatment of thyroid cancer with radioiodine. British Journal of Radiology 1986. p. 45-51.PMID: 3947807. KQ5E6G3947807
130 Elliott MS, Gao K, Gupta R, Chua EL, Gargya A and Clark J. Management of incidental and non-incidental papillary thyroid microcarcinoma. Journal of Laryngology & Otology 2013. p. S17-23.PMID: 23544739. KQ3e4, KQ4e2b, KQ5e523544739
131 Elsayed NM and Elkhatib YA. Diagnostic Criteria and Accuracy of Malignant Thyroid Nodules by Ultrasonography and Ultrasound Elastography with Pathologic Correlation. Ultrason Imaging 2015/05/03 ed2015.PMID: 25933616. KQ2E2C25933616
132 Erbil Y, Barbaros U, Salmaslio?lu A, Yanik BT, Bozbora A and Ozarma?an S. The advantage of near-total thyroidectomy to avoid postoperative hypoparathyroidism in benign multinodular goiter. Langenbeck's archives of surgery / Deutsche Gesellschaft für Chirurgie 2006. p. 567-73.PMID: CN-00617490. KQALLE3B
133 Erdem E, Gülçelik M, Kuru B and Alagöl H. Comparison of completion thyroidectomy and primary surgery for differentiated thyroid carcinoma. European Journal of Surgical Oncology (EJSO) 2003. p. 747-749KQ5E3A14602494
134 Eroglu A, Unal M and Kocaoglu H. Total thyroidectomy for differentiated thyroid carcinoma: primary and secondary operations. European journal of surgical oncology 1998. p. 283-7.PMID: 9724994. KQ5E3A9724994
135 F IW, Fawad Khan S, Ur Rehman H and Ahmad Khan I. Role of fine needle aspiration cytology in diagnosis of solitary thyroid nodules. Iranian journal of otorhinolaryngology 2011. p. 111-8.PMID: 24303370. KQ3e3a24303370
136 F P, Jaconi M, Delitala A, Garancini M, Maternini M, Bono F, Giani A, Smith A and San Gerardo Hospital collaborators g. Incidental papillary thyroid carcinoma: diagnostic findings in a series of 287 carcinomas. Endocrine pathology 2014. p. 288-96.PMID: 24997780. KQ3E424997780
137 Fahey TJ, 3rd, Reeve TS and Delbridge L. Increasing incidence and changing presentation of thyroid cancer over a 30-year period. British journal of surgery 1995. p. 518-20.PMID: 7613899. KQ3E5, KQ5E57613899
138 Fallahi B, Adabi K, Majidi M, Fard-Esfahani A, Heshmat R, Larijani B and Haghpanah V. Incidence of second primary malignancies during a long-term surveillance of patients with differentiated thyroid carcinoma in relation to radioiodine treatment. Clinical nuclear medicine 2011. p. 277-82.PMID: 21368600. KQ5e3a21368600
139 Farkas EA, King TA, Bolton JS and Fuhrman GM. A comparison of total thyroidectomy and lobectomy in the treatment of dominant thyroid nodules. American surgeon 2002. p. 678-82; discussion 682-3.PMID: 12206601. KQ4E1012206601
140 Farrar WB, Cooperman M and James AG. Surgical management of papillary and follicular carcinoma of the thyroid. Annals of surgery 1980. p. 701-4.PMID: 7447520. KQ4E2B, KQ5E6G7447520
141 Favus MJ, Schneider AB, Stachura ME, Arnold JE, Ryo UY, Pinsky SM, Colman M, Arnold MJ and Frohman LA. Thyroid cancer occurring as a late consequence of head-and-neck irradiation. Evaluation of 1056 patients. New England journal of medicine 1976. p. 1019-25.PMID: 1256510. KQ2E4D, KQ3E51256510
142 Fayek IS, Kamel AA and Sidhom NF. Safety and Prognostic Impact of Prophylactic Level VII Lymph Node Dissection for Papillary Thyroid Carcinoma. Asian Pacific Journal of Cancer Prevention: Apjcp 2015. p. 8425-30.PMID: 26745096. KQ5E3A26745096
143 Filho JG and Kowalski LP. Postoperative complications of thyroidectomy for differentiated thyroid carcinoma. American journal of otolaryngology 2004. p. 225-30.PMID: 15239027. KQ5e3a15239027
144 Fink A, Tomlinson G, Freeman JL, Rosen IB and Asa SL. Occult micropapillary carcinoma associated with benign follicular thyroid disease and unrelated thyroid neoplasms. Modern Pathology 1996. p. 816-20.PMID: 8871922. KQ5E58871922
145 Florentine BD, Staymates B, Rabadi M, Barstis J, Black A and Cancer Committee of the Henry Mayo Newhall Memorial H. The reliability of fine-needle aspiration biopsy as the initial diagnostic procedure for palpable masses: a 4-year experience of 730 patients from a community hospital-based outpatient aspiration biopsy clinic. Cancer 2006. p. 406-16.PMID: 16773630. KQ3e416773630
146 Foley CS, Agcaoglu O, Siperstein AE and Berber E. Robotic transaxillary endocrine surgery: a comparison with conventional open technique. Surg Endosc 2012/02/09 ed2012. p. 2259-66.PMID: 22311302. KQ4E522311302
147 Fon LJ, Deans GT, Lioe TF, Lawson JT, Briggs K and Spence RA. An audit of thyroid surgery in a general surgical unit. Annals of the Royal College of Surgeons of England 1996. p. 192-6.PMID: 8779503. KQ4E2B, KQ5E48779503
148 Franceschi S and Vaccarella S. Thyroid cancer: An epidemic of disease or an epidemic of diagnosis? International Journal of Cancer. 2014/11/05 ed2014.PMID: 25365909. KQ3E225365909
149 Frates MC, Benson CB, Doubilet PM, Cibas ES and Marqusee E. Can color Doppler sonography aid in the prediction of malignancy of thyroid nodules? Journal of ultrasound in medicine 2003. p. 127-31; quiz 132-4.PMID: 12562117. KQ2e2c12562117
150 Fukunari N, Nagahama M, Sugino K, Mimura T, Ito K and Ito K. Clinical evaluation of color Doppler imaging for the differential diagnosis of thyroid follicular lesions. World journal of surgery 2004. p. 1261-5.PMID: 15517496. KQ2e2c15517496
151 Gasperi M, Fugazzola L, Ceccarelli C, Lippi F, Centoni R, Martino E and Pinchera A. Testicular function in patients with differentiated thyroid carcinoma treated with radioiodine. Journal of nuclear medicine 1994. p. 1418-22.PMID: 8071685. KQ5E6G8071685
152 Gazdag A, Nagy EV, Erdei A, Bodor M, Berta E, Szabo Z and Jenei Z. Aortic stiffness and left ventricular function in patients with differentiated thyroid cancer. J Endocrinol Invest 2014/09/10 ed2014.PMID: 25194423. KQ5E625194423
153 Gemsenjager E, Perren A, Seifert B, Schuler G, Schweizer I and Heitz PU. Lymph node surgery in papillary thyroid carcinoma. Journal of the American College of Surgeons 2003. p. 182-90.PMID: 12892795. KQ5e6h12892795
154 Gharib H, Suman VJ and Goellner JR. “Suspicious” thyroid cytologic findings: outcome in patients without immediate surgical treatment. Mayo Clinic proceedings 1993. p. 343-8.PMID: 8455392. KQ3E48455392
155 Ghori FY, Gutterman-Litofsky DR, Jamal A, Yeung SC, Arem R and Sherman SI. Socioeconomic factors and the presentation, management, and outcome of patients with differentiated thyroid carcinoma. Thyroid 2002. p. 1009-16.PMID: 12490079. KQ3e112490079
156 Ghossein R, Ganly I, Biagini A, Robenshtok E, Rivera M and Tuttle RM. Prognostic factors in papillary microcarcinoma with emphasis on histologic subtyping: a clinicopathologic study of 148 cases. Thyroid 2014. p. 245-53.PMID: 23745671. KQ5e523745671
157 Giani C, Fierabracci P, Bonacci R, Gigliotti A, Campani D, De Negri F, Cecchetti D, Martino E and Pinchera A. Relationship between breast cancer and thyroid disease: relevance of autoimmune thyroid disorders in breast malignancy. Journal of Clinical Endocrinology & Metabolism 1996. p. 990-4.PMID: 8772562. KQ2E5, KQ3E58772562
158 Giddings AE. Solitary thyroid nodule: audit shows improved care requires cytological diagnosis. Annals of the Royal College of Surgeons of England 1989. p. 316-9.PMID: 2802479. KQ5E4D2802479
159 Gimm O and Dralle H. Surgical strategies in papillary thyroid carcinoma. Current Topics in Pathology 1997. p. 51-64.PMID: 9018916. KQ5E59018916
160 Goffredo P, Cheung K, Roman SA and Sosa JA. Can minimally invasive follicular thyroid cancer be approached as a benign lesion?: a population-level analysis of survival among 1,200 patients. Annals of surgical oncology 2013. p. 767-72.PMID: 23111705. KQ4E5, KQ5e623111705
161 Goffredo P, Thomas SM, Dinan MA, Perkins JM, Roman SA and Sosa JA. Patterns of Use and Cost for Inappropriate Radioactive Iodine Treatment for Thyroid Cancer in the United States: Use and Misuse. JAMA Internal Medicine 2015/02/17 ed2015.PMID: 25686394. KQ5E525686394
162 Goldfarb M, Gondek S, Solorzano C and Lew JI. Surgeon-performed ultrasound can predict benignity in thyroid nodules. Surgery 2011. p. 436-41.PMID: 21878228. KQ2e2c21878228
163 Golia F, Bruno-Bossio G, Vignali E and Pinchera A. Carefully monitored levothyroxine suppressive therapy is not associated with bone loss in premenopausal women. Journal of Clinical Endocrinology & Metabolism 1994. p. 818-23.PMID: 8157704. KQ5E48157704
164 Goncalves Filho J and Kowalski LP. Surgical complications after thyroid surgery performed in a cancer hospital. Otolaryngology - Head & Neck Surgery 2005. p. 490-4.PMID: 15746868. KQ5e3a15746868
165 Gourin CG, Tufano RP, Forastiere AA, Koch WM, Pawlik TM and Bristow RE. Volume-based trends in thyroid surgery. Archives of Otolaryngology–Head & Neck Surgery 2010. p. 1191-1198KQ5E4D21173367
166 Govednik C, Snyder S, Quinn C, Saxena S and Jupiter D. Minimally invasive, nonendoscopic thyroidectomy: A cosmetic alternative to robotic-assisted thyroidectomy. Surgery (United States) 2014. p. 1030-8.PMID: CN-01079446. KQ5E6H
167 Grant CS, van Heerden JA, Goellner JR, Ebersold JR and Bergstralh EJ. Papillary thyroid microcarcinoma: a study of 535 cases observed in a 50-year period. Surgery 1992. p. 1139-46; discussion 1146-7.PMID: 1455316. KQ5E21455316
168 Grauer A, Raue F and Gagel RF. Changing concepts in the management of hereditary and sporadic medullary thyroid carcinoma. Endocrinol Metab Clin North Am 1990/09/01 ed1990. p. 613-35.PMID: 1979773. KQALLE11979773
169 Grover G, Sadler GP and Mihai R. Morbidity after thyroid surgery: patient perspective. Laryngoscope 2013. p. 2319-23.PMID: 23824630. KQ5e223824630
170 Guasti L, Marino F, Cosentino M, Cimpanelli M, Rasini E, Piantanida E, Vanoli P, De Palma D, Crespi C, Klersy C, Maroni L, Loraschi A, Colombo C, Simoni C, Bartalena L, Lecchini S, Grandi AM and Venco A. Pain perception, blood pressure levels, and peripheral benzodiazepine receptors in patients followed for differentiated thyroid carcinoma: a longitudinal study in hypothyroidism and during hormone treatment. Clinical Journal of Pain 2007. p. 518-23.PMID: 17575492. KQ4e6, KQ5e617575492
171 Gul K, Ersoy R, Dirikoc A, Korukluoglu B, Ersoy PE, Aydin R, Ugras SN, Belenli OK and Cakir B. Ultrasonographic evaluation of thyroid nodules: comparison of ultrasonographic, cytological, and histopathological findings. Endocrine 2009. p. 464-72.PMID: 19859839. KQ2e2c, KQ3e2c19859839
172 Gulcelik MA, Kuru B, Dincer H, Camlibel M, Yuksel UM, Yenidogan E and Reis E. Complications of completion versus total thyroidectomy. Asian Pacific Journal of Cancer Prevention: Apjcp 2012. p. 5225-8.PMID: 23244139. KQ4e3a, KQ5e3a23244139
173 Guo Z, Hu Y and Liu Q. [Clinical analysis of hoarseness after thyroidectomy]. Lin Chuang Er Bi Yan Hou Ke Za Zhi. 2001/03/27 ed1998. p. 362-3, 373.PMID: 11263159. KQ5E911263159
174 Gutierrez S, Carbonell E, Galofrea P, Xamena N, Creus A and Marcos R. A cytogenetic follow-up study of thyroid cancer patients treated with 131I. Cancer Letters 1995. p. 199-204.PMID: 7767910. KQ5E57767910
175 Gyory F, Lukacs G, Balazs G, Szakall S, Miltenyi L and Kiss A. Interdisciplinary treatment of the malignant lymphoma of the thyroid. Acta Chirurgica Hungarica 1997. p. 110-2.PMID: 9408307. KQ5E6G9408307
176 Gyory F, Lukacs G, Juhasz F, Mezosi E, Szakall S, Vegh T, Math J and Balazs G. Surgically treated Hashimoto's thyroiditis. Acta Chirurgica Hungarica 1999. p. 243-7.PMID: 10935132. KQ5E410935132
177 Haber RS. Role of ultrasonography in the diagnosis and management of thyroid cancer. Endocrine practice 2000. p. 396-400.PMID: 11141593. KQ2E2C, KQ3E2C11141593
178 Hadjisavva IS, Dina R, Talias MA and Economides PA. Prevalence of Cancer in Patients with Thyroid Nodules in the Island of Cyprus: Predictive Value of Ultrasound Features and Thyroid Autoimmune Status. European Thyroid Journal 2015. p. 123-8.PMID: 26279998. KQ2E2C26279998
179 Haghpanah V, Abbas SI, Mahmoodzadeh H, Shojaei A, Soleimani A, Larijani B and Tavangar SM. Paraplegia as initial presentation of follicular thyroid carcinoma. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan 2006. p. 233-4.PMID: 16542610. KQ3e216542610
180 Hakala T, Kellokumpu-Lehtinen P, Kholova I, Holli K, Huhtala H and Sand J. Rising incidence of small size papillary thyroid cancers with no change in disease-specific survival in Finnish thyroid cancer patients. Scandinavian Journal of Surgery: SJS 2012. p. 301-6.PMID: 23238509. KQ3e223238509
181 Hall P, Holm L, Lundell G, Bjelkengren G, Larsson L, Lindberg S, Tennvall J, Wicklund H and Boice Jr J. Cancer risks in thyroid cancer patients. British Journal of Cancer 1991. p. 159KQ5E6G
182 Hall P, Holm LE and Lundell G. Second primary tumors following thyroid cancer. A Swedish record-linkage study. Acta Oncologica. 1990/01/01 ed1990. p. 869-73.PMID: 2261200. KQ5E62261200
183 Hamilton TE, van Belle G and LoGerfo JP. Thyroid neoplasia in Marshall Islanders exposed to nuclear fallout. Jama 1987. p. 629-35.PMID: 3612986. KQ2E3A, KQ3E3A3612986
184 Han MA, Choi KS, Lee HY, Kim Y, Jun JK and Park EC. Current status of thyroid cancer screening in Korea: results from a nationwide interview survey. Asian Pacific Journal of Cancer Prevention: Apjcp 2011. p. 1657-63.PMID: 22126540. KQ2E522126540
185 Handelsman DJ and Turtle JR. Testicular damage after radioactive iodine (I-131) therapy for thyroid cancer. Clinical endocrinology 1983. p. 465-72.PMID: 6409459. KQ5E6G6409459
186 Harach HR, Franssila KO and Wasenius VM. Occult papillary carcinoma of the thyroid. A “normal” finding in Finland. A systematic autopsy study. Cancer. 1985/08/01 ed1985. p. 531-8.PMID: 2408737. KQALLE12408737
187 Harada T, Fukunaga M, Furukawa J, Yamane Y, Yasuda K, Yanagimoto S, Tomomitsu T, Otsuka N and Morita R. New perspectives for diagnosis of nodular goiter by technetium-thallium subtraction scanning. Clinical nuclear medicine 1989. p. 897-902.PMID: 2557998. KQ2E2C, KQ3E52557998
188 Hauch A, Al-Qurayshi Z, Randolph G and Kandil E. Total thyroidectomy is associated with increased risk of complications for low- and high-volume surgeons. Annals of surgical oncology 2014. p. 3844-52.PMID: 24943236. KQ5E4D24943236
189 Hay D. Local recurrence of papillary thyroid carcinoma after unilateral or bilateral thyroidectomy. Wiener klinische Wochenschrift 1988. p. 342-6.PMID: 3407192. KQ5E6G3407192
190 Hay ID, Goellner JR, Ryan JJ and McConahey WM. Mortality from papillary thyroid carcinoma. A case-control study of 56 lethal cases. Cancer 1988. p. 1381-8.PMID: 3416277. KQ5E6G3416277
191 Henry JF, Gramatica L, Denizot A, Kvachenyuk A, Puccini M and Defechereux T. Morbidity of prophylactic lymph node dissection in the central neck area in patients with papillary thyroid carcinoma. Langenbecks Archives of Surgery 1998. p. 167-9.PMID: 9641892. KQ5E109641892
192 Hesselink EN, Lefrandt JD, Schuurmans EP, Burgerhof JG, Groen B, Gansevoort RT, van der Horst-Schrivers AN, Dullaart RP, Van Gelder IC, Brouwers AH, Rienstra M and Links TP. Increased Risk of Atrial Fibrillation After Treatment for Differentiated Thyroid Carcinoma. Journal of Clinical Endocrinology & Metabolism 2015. p. 4563-9.PMID: 26480284. KQ5E526480284
193 Hirsch D, Ginat M, Levy S, Benbassat C, Weinstein R, Tsvetov G, Singer J, Shraga-Slutzky I, Grozinski-Glasberg S, Mansiterski Y, Shimon I and Reicher-Atir R. Illness perception in patients with differentiated epithelial cell thyroid cancer. Thyroid 2009. p. 459-65.PMID: 19415995. KQ4e419415995
194 Ho AS, Davies L, Nixon IJ, Palmer FL, Wang LY, Patel SG, Ganly I, Wong RJ, Tuttle RM and Morris LG. Increasing diagnosis of subclinical thyroid cancers leads to spurious improvements in survival rates. Cancer 2015/02/26 ed2015.PMID: 25712809. KQ3E225712809
195 Hoelzer S, Steiner D, Bauer R, Reiners C, Farahati J, Hundahl SA and Dudeck J. Current practice of radioiodine treatment in the management of differentiated thyroid cancer in Germany. European journal of nuclear medicine 2000. p. 1465-72.PMID: 11083534. KQ4E2B, KQ5E511083534
196 Holm LE. Cancer risks after diagnostic doses of 131I with special reference to thyroid cancer. Cancer Detect Prev 1991. p. 27-30.PMID: 2044071. KQ5E22044071
197 Holm LE, Dahlqvist I, Israelsson A and Lundell G. Malignant thyroid tumors after iodine-131 therapy: a retrospective cohort study. New England journal of medicine 1980. p. 188-91.PMID: 7383089. KQ5E4D7383089
198 Howard JE, Vaswani A and Heotis P. Thyroid disease among the Rongelap and Utirik population--an update. Health Phys 1997/07/01 ed1997. p. 190-8.PMID: 9199229. KQALLE49199229
199 Hrafnkelsson J, Tulinius H, Jonasson JG, Olafsdottir G and Sigvaldason H. Papillary thyroid carcinoma in Iceland. A study of the occurrence in families and the coexistence of other primary tumours. Acta Oncologica. 1989/01/01 ed1989. p. 785-8.PMID: 2611030. KQ2E4C2611030
200 Hryhorczuk AL, Stephens T, Bude RO, Rubin JM, Bailey JE, Higgins EJ, Fox GA and Klein KA. Prevalence of malignancy in thyroid nodules with an initial nondiagnostic result after ultrasound guided fine needle aspiration. Ultrasound in medicine & biology 2012. p. 561-7.PMID: 22341051. KQ3e622341051
201 Hsiao YL and Chang TC. Ultrasound evaluation of thyroid abnormalities and volume in Chinese adults without palpable thyroid glands. Journal of the Formosan Medical Association 1994/02/01 ed1994. p. 140-4.PMID: 7912585. KQALLE47912585
202 Hu G, Zhu W, Yang W, Wang H, Shen L and Zhang H. The Effectiveness of Radioactive Iodine Remnant Ablation for Papillary Thyroid Microcarcinoma: A Systematic Review and Meta-analysis. World journal of surgery 2016. p. 100-9.PMID: 26578322. KQ4E2B26578322
203 Huang X, Guo LH, Xu HX, Gong XH, Liu BJ, Xu JM, Zhang YF, Li XL, Li DD, Qu S and Fang L. Acoustic radiation force impulse induced strain elastography and point shear wave elastography for evaluation of thyroid nodules. International journal of clinical and experimental medicine 2015. p. 10956-63.PMID: 26379890. KQ2E2C26379890
204 Hughes DT, Haymart MR, Miller BS, Gauger PG and Doherty GM. The most commonly occurring papillary thyroid cancer in the United States is now a microcarcinoma in a patient older than 45 years. Thyroid 2011/01/28 ed2011. p. 231-6.PMID: 21268762. KQALLE121268762
205 Hundahl SA, Fleming ID, Fremgen AM and Menck HR. A National Cancer Data Base report on 53,856 cases of thyroid carcinoma treated in the U.S., 1985-1995 [see commetns]. Cancer 1998. p. 2638-48.PMID: 9874472. KQ4E2B9874472
206 Hussain F, Iqbal S, Mehmood A, Bazarbashi S, ElHassan T and Chaudhri N. Incidence of thyroid cancer in the Kingdom of Saudi Arabia, 2000-2010. Hematology/oncology & stem cell therapy 2013. p. 58-64.PMID: 23756719. KQ3e223756719
207 Hwang S, Shin DY, Kim EK, Yang WI, Byun JW, Lee SJ, Kim G, Im SJ and Lee EJ Focal Lymphocytic Thyroiditis Nodules Share the Features of Papillary Thyroid Cancer on Ultrasound. Yonsei medical journal 2015. p. 1338-44.PMID: 26256977. KQ2E2C26256977
208 Hyer S, Vini L, O'Connell M, Pratt B and Harmer C Testicular dose and fertility in men following I(131) therapy for thyroid cancer. Clinical endocrinology 2002. p. 755-8.PMID: 12072044. KQ5e6g12072044
209 Hyer SL, Dandekar P, Newbold K, Haq M, Wechalakar K, Thway K and Harmer C Thyroid cancer causing obstruction of the great veins in the neck.[Erratum appears in World J Surg Oncol. 2008;6:40 Note: Thway, Khin [added]]. World journal of surgical oncology 2008. p. 36.PMID: 18387194. KQ4e1, KQ5e118387194
210 Ikeda Y, Takami H, Niimi M, Kan S, Sasaki Y and Takayama J Endoscopic thyroidectomy and parathyroidectomy by the axillary approach. A preliminary report. Surgical endoscopy 2002. p. 92-5.PMID: 11961613. KQ5E611961613
211 Illouz F, Rodien P, Saint-Andre JP, Triau S, Laboureau-Soares S, Dubois S, Vielle B, Hamy A and Rohmer V. Usefulness of repeated fine-needle cytology in the follow-up of non-operated thyroid nodules.[Erratum appears in Eur J Endocrinol. 2007 Jun;156(6):705 Note: Antoine, Hamy [corrected to Hamy, Antoine]]. European Journal of Endocrinology 2007. p. 303-8.PMID: 17322489. KQ3e517322489
212 Imaizumi M, Usa T, Tominaga T, Akahoshi M, Ashizawa K, Ichimaru S, Nakashima E, Ishii R, Ejima E, Hida A, Soda M, Maeda R, Nagataki S and Eguchi K Long-term prognosis of thyroid nodule cases compared with nodule-free controls in atomic bomb survivors. Journal of Clinical Endocrinology & Metabolism 2005. p. 5009-14.PMID: 15941865. KQ2e3b15941865
213 Isaac A, Jeffery CC, Seikaly H, Al-Marzouki H, Harris JR and DA OC Predictors of non-diagnostic cytology in surgeon-performed ultrasound guided fine needle aspiration of thyroid nodules. Journal of Otolaryngology: Head and Neck Surgery. 2014/12/04 ed2014. p. 48.PMID: 25466726. KQ3E525466726
214 Ishigaki S, Shimamoto K, Satake H, Sawaki A, Itoh S, Ikeda M, Ishigaki T and Imai T Multi-slice CT of thyroid nodules: comparison with ultrasonography. Radiation Medicine 2004. p. 346-53.PMID: 15553016. KQ2e2c15553016
215 Ishihara T, Yamazaki S, Kobayashi K, Inoue H, Fukai S, Ito K and Mimura T Resection of the trachea infiltrated by thyroid carcinoma. Annals of surgery 1982. p. 496-500.PMID: 7065753. KQ4E4B, KQ5E4B7065753
216 Ishikawa K, Noguchi S, Tanaka K, Fukuda A and Hirohata T Second primary neoplasms in thyroid cancer patients. Japanese Journal of Cancer Research 1996/03/01 ed1996. p. 232-9.PMID: 8613424. KQ5E6G8613424
217 Ito Y, Amino N, Yokozawa T, Ota H, Ohshita M, Murata N, Morita S, Kobayashi K and Miyauchi A Ultrasonographic evaluation of thyroid nodules in 900 patients: comparison among ultrasonographic, cytological, and histological findings. Thyroid 2007. p. 1269-76.PMID: 17988196. KQ2E2C17988196
218 Ito Y, Higashiyama T, Takamura Y, Miya A, Kobayashi K, Matsuzuka F, Kuma K and Miyauchi A Long-term follow-up for patients with papillary thyroid carcinoma treated as benign nodules. Anticancer Research 2007. p. 1039-43.PMID: 17465240. KQ4e2b, KQ5e517465240
219 Ivanac G, Brkljacic B, Ivanac K, Huzjan R, Skreb F and Cikara I Vascularisation of benign and malignant thyroid nodules: CD US evaluation. Ultraschall in der Medizin 2007. p. 502-6.PMID: 17492574. KQ2e2c, KQ3e517492574
220 J R, B L, LL Z, HY L, F Z, S L and LR Z. A taller-than-wide shape is a good predictor of papillary thyroid carcinoma in small solid nodules. Journal of ultrasound in medicine 2015. p. 19-26.PMID: 25542935. KQ3E1A25542935
221 J T, Goldberg AS, Jones J, Zhang J, Lowe J, Ezzat S, Gilbert J, Zahedi A, Segal P and Sawka AM. A systematic review of randomized controlled trials for management of persistent post-treatment fatigue in thyroid cancer survivors. Thyroid 2015. p. 198-210.PMID: 25382050. KQ4e4, KQ5e625382050
222 Jacob P, Kenigsberg Y, Goulko G, Buglova E, Gering F, Golovneva A, Kruk J and Demidchik EP Thyroid cancer risk in Belarus after the Chernobyl accident: comparison with external exposures. Radiation & Environmental Biophysics 2000. p. 25-31.PMID: 10789892. KQ1,2,3,4,5E3B10789892
223 Jamski J, Jamska A, Graca M, Barczynski M and Wlodyka J. [Recurrent laryngeal nerve injury following thyroid surgery]. Przegl Lek. 2004/07/03 ed2004. p. 13-6.PMID: 15230099. KQ5E915230099
224 Jatzko GR, Lisborg PH, Muller MG and Wette VM Recurrent nerve palsy after thyroid operations--principal nerve identification and a literature review. Surgery 1994. p. 139-44.PMID: 8310401. KQALLE28310401
225 Jeannon JP, Orabi AA, Bruch GA, Abdalsalam HA and Simo R Diagnosis of recurrent laryngeal nerve palsy after thyroidectomy: a systematic review. International journal of clinical practice 2009. p. 624-9.PMID: 19335706. KQ4e2b, KQ5e819335706
226 Jeong HS, Baek CH, Son YI, Choi JY, Kim HJ, Ko YH, Chung JH and Baek HJ. Integrated 18F-FDG PET/CT for the initial evaluation of cervical node level of patients with papillary thyroid carcinoma: comparison with ultrasound and contrast-enhanced CT. Clinical endocrinology 2006. p. 402-7.PMID: 16918964. KQ2e516918964
227 Jeong SP, Ki KO, Kim EK, Chang HS and Soon WH Sonographic screening for thyroid cancer in females undergoing breast sonography. AJR. American Journal of Roentgenology 2006. p. 1025-8.PMID: CN-00735838. KQ3E2B16554573
228 Jhiang SM Long-term impact of initial surgical and medical therapy on papillary and follicular thyroid cancer.[Erratum appears in Am J Med 1995 Feb;98(2):215]. American Journal of Medicine 1994. p. 418-28.PMID: 7977430. KQ4E6G7977430
229 Jog VB, Baluja CA and Damle SR Risk of hypoparathyroidism after surgery for carcinoma of the thyroid. Head & neck 1990. p. 321-5.PMID: 2361862. KQ5E32361862
230 Johns ME, Shikhani AH, Kashima HK and Matanoski GM Multiple primary neoplasms in patients with salivary gland or thyroid gland tumors. Laryngoscope 1986/07/01 ed1986. p. 718-21.PMID: 3724320. KQALLE43724320
231 Jonklaas J Nasal symptoms after radioiodine therapy: a rarely described side effect with similar frequency to lacrimal dysfunction. Thyroid 2014. p. 1806-14.PMID: 25090584. KQ5E725090584
232 Joseph KR, Edirimanne S and Eslick GD. The association between breast cancer and thyroid cancer: a meta-analysis. Breast Cancer Research & Treatment 2015. p. 173-81.PMID: 26058757. KQ5E126058757
233 JR B, HF S, DC B and JN P. Surgical therapy for thyroid carcinoma: a review of 1249 solitary thyroid nodules. Surgery 1988. p. 940-6.PMID: 3194845. KQ5E6G3194845
234 Jung H and Schlager B. [Recurrent laryngeal nerve paralysis after thyroidectomy]. Laryngorhinootologie. 2000/07/27 ed2000. p. 297-303.PMID: 10911606. KQ5E910911606
235 Kacar Guveli T, Ozkan S, Oner Tamam M, Uyanik E, Ediz N, Mulazimoglu M and Ozpacaci T The Effect of High Dose Radioiodine Therapy on Formation of Radiation Retinopathy During Thyroid Cancer Treatment. Molecular Imaging and Radionuclide Therapy 2014/12/30 ed2014. p. 84-88.PMID: 25541931. KQ5E3A25541931
236 Kahn C, Simonella L, Sywak M, Boyages S, Ung O and O'Connell D Post-surgical pathology reporting of thyroid cancer in New South Wales, Australia. Thyroid 2012/02/16 ed2012.PMID: 22332763. KQ4E5
237 Kandil E, Noureldine SI and Tufano RP Thyroidectomy vs Active Surveillance for Subcentimeter Papillary Thyroid Cancers-The Cost Conundrum. JAMA Otolaryngology-- Head & Neck Surgery. 2015/12/15 ed2015. p. 1-2.PMID: 26661274. KQ5E526661274
238 Kang SW, Lee SH, Park JH, Jeong JS, Park S, Lee CR, Jeong JJ, Nam KH, Chung WY and Park CS A comparative study of the surgical outcomes of robotic and conventional open modified radical neck dissection for papillary thyroid carcinoma with lateral neck node metastasis. Surgical endoscopy 2012. p. 3251-7.PMID: 22648105. KQ4e2b, KQ5e422648105
239 Kaplan EL, McCormick M and Straus FH Natural history, treatment, and course of papillary thyroid carcinoma. Journal of Clinical Endocrinology & Metabolism 1990. p. 414-24.PMID: 2380337. KQ5E62380337
240 Kaplan EL, Straus FH and Shukla MS Does the method of management of papillary thyroid carcinoma make a difference in outcome? World journal of surgery 1994. p. 123-30.PMID: 8197768. KQ4E2, KQ5E28197768
241 Karapanou O, Papadopoulos A, Vlassopoulou B, Vassilopoulos C, Pappa E, Tsagarakis S and Niakas D Health status of Greek thyroid cancer patients after radioiodine administration compared to a demographically matched general population sample. Hellenic journal of nuclear medicine 2012. p. 98-102.PMID: 22741146. KQ4e2b, KQ5e222741146
242 Kawai T, Nishihara E, Kudo T, Ota H, Morita S, Kobayashi K, Ito M, Kubota S, Amino N and Miyauchi A Histopathological diagnoses of “accessory” thyroid nodules diagnosed as benign by fine-needle aspiration cytology and ultrasonography. Thyroid 2012. p. 299-303.PMID: 22300250. KQ2e2c22300250
243 Kazaure HS, Roman SA and Sosa JA Aggressive variants of papillary thyroid cancer: incidence, characteristics and predictors of survival among 43,738 patients. Annals of surgical oncology 2012. p. 1874-80.PMID: 22065195. KQ4e622065195
244 Kerber RA, Till JE, Simon SL, Lyon JL, Thomas DC, Preston-Martin S, Rallison ML, Lloyd RD and Stevens W A cohort study of thyroid disease in relation to fallout from nuclear weapons testing. Jama 1993/11/03 ed1993. p. 2076-82.PMID: 8411574. KQALLE48411574
245 Kern KA Comparative analysis of complications from I-131 radioablation for well-differentiated thyroid cancer. Surgery 1994. p. 1024-30.PMID: 7985082. KQ5E27985082
246 Kessler A, Gavriel H, Zahav S, Vaiman M, Shlamkovitch N, Segal S and Eviatar E Accuracy and consistency of fine-needle aspiration biopsy in the diagnosis and management of solitary thyroid nodules. Israel Medical Association Journal: Imaj 2005. p. 371-3.PMID: 15984379. KQ3e615984379
247 Keyhani-Rofagha S, Cunningham JJ and Mazzaferri EL Cystic thyroid nodules. The dilemma of malignant lesions. Archives of Internal Medicine 1990. p. 1422-7.PMID: 2196027. KQ2E2C, KQ3E52196027
248 Khang AR, Cho SW, Choi HS, Ahn HY, Yoo WS, Kim KW, Kang KW, Yi KH, Park do J, Lee DS, Chung JK, Cho BY and Park YJ. The risk of second primary malignancy is increased in differentiated thyroid cancer patients with a cumulative I dose over 37 GBq. Clin Endocrinol (Oxf). 2014/08/15 ed2014.PMID: 25115234. KQ5E525115234
249 Kiernan CM, Parikh AA, Parks LL and Solorzano CC. Use of Radioiodine after Thyroid Lobectomy in Patients with Differentiated Thyroid Cancer: Does It Change Outcomes? Journal of the American College of Surgeons. 2015/02/11 ed2014.PMID: 25667136. KQ4E2B25667136
250 Kiernan CM, Parikh AA, Parks LL and Solorzano CC. Use of radioiodine after thyroid lobectomy in patients with differentiated thyroid cancer: does it change outcomes? Journal of the American College of Surgeons 2015. p. 617-25.PMID: 25667136. KQ5E2B25667136
251 Kikuchi S, Perrier ND, Cheah WK, Siperstein AE, Duh QY and Clark OH. Complication of thyroidectomy in patients with radiation-induced thyroid neoplasms. Archives of Surgery 2004. p. 1185-8.PMID: 15545564. KQ5e515545564
252 Kilfoy BA, Zheng T, Holford TR, Han X, Ward MH, Sjodin A, Zhang Y, Bai Y, Zhu C, Guo GL, Rothman N and Zhang Y. International patterns and trends in thyroid cancer incidence, 1973-2002. Cancer Causes & Control. 2008/11/20 ed2009. p. 525-31.PMID: 19016336. KQALLE219016336
253 Kim BM, Kim MJ, Kim EK, Kwak JY, Hong SW, Son EJ and Kim KH. Sonographic differentiation of thyroid nodules with eggshell calcifications. Journal of ultrasound in medicine 2008. p. 1425-30.PMID: 18809952. KQ2e518809952
254 Kim C, Bi X, Pan D, Chen Y, Carling T, Ma S, Udelsman R and Zhang Y. The risk of second cancers after diagnosis of primary thyroid cancer is elevated in thyroid microcarcinomas. Thyroid 2013. p. 575-82.PMID: 23237308. KQ5e6h23237308
255 Kim DL, Song KH and Kim SK. High prevalence of carcinoma in ultrasonography-guided fine needle aspiration cytology of thyroid nodules. Endocrine journal 2008. p. 135-42.PMID: 18219180. KQ3E118219180
256 Kim DW. Ultrasonographic Features of the Major Salivary Glands after Radioactive Iodine Ablation in Patients with Papillary Thyroid Carcinoma. Ultrasound in medicine & biology 2015. p. 2640-5.PMID: 26215493. KQ5E526215493
257 Kim DW, Lee EJ, In HS and Kim SJ. Sonographic differentiation of partially cystic thyroid nodules: a prospective study. Ajnr: American Journal of Neuroradiology 2010. p. 1961-6.PMID: 20634308. KQ2e2c20634308
258 Kim DW, Lee EJ, Kim SH, Kim TH, Lee SH, Kim DH and Rho MH. Ultrasound-guided fine-needle aspiration biopsy of thyroid nodules: comparison in efficacy according to nodule size. Thyroid 2009. p. 27-31.PMID: 19021460. KQ2e4a19021460
259 Kim DW, Lee EJ and Lee JH. Role of ultrasound diagnosis in assessing and managing thyroid nodules with inadequate cytology. AJR. American Journal of Roentgenology 2011. p. 1213-9.PMID: 22021517. KQ2e2c22021517
260 Kim HJ, Kim NK, Choi JH, Kim SW, Jin SM, Suh S, Bae JC, Min YK, Chung JH and Kim SW. Radioactive iodine ablation does not prevent recurrences in patients with papillary thyroid microcarcinoma. Clinical endocrinology 2013. p. 614-20.PMID: 22957654. KQ4e2b, KQ5e522957654
261 Kim JA, Kim JS, Chang MS, Yoo YK and Kim DK. Influence of carbon dioxide insufflation of the neck on intraocular pressure during robot-assisted endoscopic thyroidectomy: a comparison with open thyroidectomy. Surg Endosc 2012/10/18 ed2013. p. 1587-93.PMID: 23073689. KQ5E523073689
262 Kim KM, Park JB, Kang SJ and Bae KS. Ultrasonographic guideline for thyroid nodules cytology: single institute experience. Journal of The Korean Surgical Society 2013. p. 73-9.PMID: 23396617. KQ2e2c23396617
263 Kim SK, Kang SY, Youn HJ and Jung SH. Comparison of conventional thyroidectomy and endoscopic thyroidectomy via axillo-bilateral breast approach in papillary thyroid carcinoma patients. Surg Endosc 2015/10/30 ed2015.PMID: 26511120. KQ5E6H26511120
264 Kita T, Yokoyama K, Higuchi T, Kinuya S, Taki J, Nakajima K, Michigishi T and Tonami N. Multifactorial analysis on the short-term side effects occurring within 96 hours after radioiodine-131 therapy for differentiated thyroid carcinoma. Annals of nuclear medicine 2004. p. 345-9.PMID: 15359929. KQ5e515359929
265 Knudsen N, Perrild H, Christiansen E, Rasmussen S, Dige-Petersen H and Jorgensen T. Thyroid structure and size and two-year follow-up of solitary cold thyroid nodules in an unselected population with borderline iodine deficiency. European Journal of Endocrinology 2000. p. 224-30.PMID: 10700715. KQ2E5, KQ3E510700715
266 Ko KY, Kao CH, Lin CL, Huang WS and Yen RF. (131)I treatment for thyroid cancer and the risk of developing salivary and lacrimal gland dysfunction and a second primary malignancy: a nationwide population-based cohort study. European Journal of Nuclear Medicine & Molecular Imaging 2015. p. 1172-8.PMID: 25900274. KQ5E3B25900274
267 Ko SY, Kim EK, Moon HJ, Yoon JH, Kim HY and Kwak JY. Application of Thyroid Imaging Reporting and Data System in the Ultrasound Assessment of Thyroid Nodules According to Physician Experience. Ultrasound Quarterly 2015/08/19 ed2015.PMID: 26280583. KQ2E2C26280583
268 Koh J, Moon HJ, Park JS, Kim SJ, Kim HY, Kim EK and Kwak JY. Variability in Interpretation of Ultrasound Elastography and Gray-Scale Ultrasound in Assessing Thyroid Nodules. Ultrasound in medicine & biology 2016. p. 51-9.PMID: 26386478. KQ2E2C26386478
269 Koike E, Noguchi S, Yamashita H, Murakami T, Ohshima A, Kawamoto H and Yamashita H. Ultrasonographic characteristics of thyroid nodules: prediction of malignancy. Archives of Surgery 2001. p. 334-7.PMID: 11231857. KQ2E2C11231857
270 Koike E, Yamashita H, Noguchi S, Murakami T, Ohshima A, Maruta J, Kawamoto H and Yamashita H. Effect of combining ultrasonography and ultrasound-guided fine-needle aspiration biopsy findings for the diagnosis of thyroid nodules. European Journal of Surgery 2001. p. 656-61.PMID: 11759733. KQ2E2C11759733
271 Kountakis SE, Skoulas IG and Maillard AAJ. The radiologic work-up in thyroid surgery: fine-needle biopsy versus scintigraphy and ultrasound. Ear, Nose, & Throat Journal 2002. p. 151-4.PMID: 11913059. kq2e2c11913059
272 Kouvaraki MA, Lee JE, Shapiro SE, Sherman SI and Evans DB. Preventable reoperations for persistent and recurrent papillary thyroid carcinoma. Surgery 2004. p. 1183-91.PMID: 15657574. KQ5e615657574
273 Kovacevic DO and Skurla MS. Sonographic diagnosis of thyroid nodules: correlation with the results of sonographically guided fine-needle aspiration biopsy.[Erratum appears in J Clin Ultrasound. 2007 Jun;35(5):293 Note: Kovacevic, Obad [corrected to Kovacevic, Dragica Obad]]. Journal of Clinical Ultrasound 2007. p. 63-7.PMID: 17206727. KQ2E217206727
274 Krishnamurthy GT and Blahd WH. Radioiodine I-31 therapy in the management of thyroid cancer. A prospective study. Cancer 1977. p. 195-202.PMID: 880551. KQ4E2B, KQ5E6G880551
275 Kube R, Horschig P, Marusch F, Horntrich J and Gastinger I. [Postoperative recurrent nerve paralysis after initial interventions for benign goiter]. Zentralbl Chir. 1998/05/23 ed1998. p. 11-6.PMID: 9542022. KQ5E99542022
276 Kucuk NO, Tari P, Tokmak E and Aras G. Treatment for microcarcinoma of the thyroid--clinical experience. Clinical nuclear medicine 2007. p. 279-81.PMID: 17413573. KQ5E3A17413573
277 Kuhn MA, Bloom G and Myssiorek D. Patient perspectives on dysphonia after thyroidectomy for thyroid cancer. Journal of Voice 2013. p. 111-4.PMID: 22925427. KQ5e222925427
278 Kuo JH, Chabot JA and Lee JA. Breast cancer in thyroid cancer survivors: An analysis of the Surveillance, Epidemiology, and End Results-9 database. Surgery 2016. p. 23-30.PMID: 26522696. KQ5E226522696
279 Kupferman ME, Patterson DM, Mandel SJ, LiVolsi V and Weber RS. Safety of modified radical neck dissection for differentiated thyroid carcinoma. Laryngoscope 2004. p. 403-6.PMID: 15091209. KQ5E6H15091209
280 Kupferman ME, Patterson M, Mandel SJ, LiVolsi V and Weber RS. Patterns of lateral neck metastasis in papillary thyroid carcinoma. Archives of Otolaryngology -- Head & Neck Surgery 2004. p. 857-60.PMID: 15262763. KQ5e515262763
281 Kurukahvecioglu O, Taneri F, Yuksel O, Aydin A, Tezel E and Onuk E. Total thyroidectomy for the treatment of Hashimoto's thyroiditis coexisting with papillary thyroid carcinoma. Advances in Therapy 2007. p. 510-6.PMID: 17660159. KQ5e3a17660159
282 Kwak H, Kim H, Lee H, Jung S, Son G, Lee J and Bae J. Assessment of vocal function with intraoperative neuromonitoring (IONM) during robotic thyroidectomy: A randomized clinical trial. Thyroid 2014. p. A57. CN-01077843. KQALLE7 (only abstract available)
283 Kwak JY, Kim EK, Kim MJ and Son EJ. Significance of sonographic characterization for managing subcentimeter thyroid nodules. Acta Radiologica 2009. p. 917-23.PMID: 19636989. kq3e2c19636989
284 Kwon JH, Kim EK, Lee HS, Moon HJ and Kwak JY. Neck ultrasonography as preoperative localization of primary hyperparathyroidism with an additional role of detecting thyroid malignancy. European journal of radiology 2013. p. e17-21.PMID: 22921682. KQ2e222921682
285 La Vecchia C, Malvezzi M, Bosetti C, Garavello W, Bertuccio P, Levi F and Negri E. Thyroid cancer mortality and incidence: a global overview. International Journal of Cancer. 2014/10/07 ed2015. p. 2187-95.PMID: 25284703. KQALLE125284703
286 Lang BH, Ng SH, Lau LL, Cowling BJ, Wong KP and Wan KY. A systematic review and meta-analysis of prophylactic central neck dissection on short-term locoregional recurrence in papillary thyroid carcinoma after total thyroidectomy. Thyroid 2013. p. 1087-98.PMID: 23402640. KQ5e223402640
287 Lang BH, Wong CK, Tsang JS and Wong KP. A systematic review and meta-analysis comparing outcomes between robotic-assisted thyroidectomy and non-robotic endoscopic thyroidectomy. Journal of surgical research 2014. p. 389-98.PMID: 24814766. KQ4e2b, KQ5e824814766
288 Lasithiotakis K, Grisbolaki E, Koutsomanolis D, Venianaki M, Petrakis I, Vrachassotakis N, Chrysos E, Zoras O and Chalkiadakis G. Indications for surgery and significance of unrecognized cancer in endemic multinodular goiter. World journal of surgery 2012. p. 1286-92.PMID: 22395348. KQ2e4d, KQ3e4d, KQ5e4d22395348
289 Leblanc BJ, Ryan S, Martin E, Milligan E and Nathan CA. Thyroid Nodules in a Veterans Affairs Population. Otolaryngology - Head & Neck Surgery. 2012/08/01 ed2012. p. P184-P185.PMID: 25718654. KQ4E5
290 Lee D, Oh K, Cho J-G, Kwon S-Y, Woo J-S, Baek S-K and Jung K-Y. The Benefits and Risks of Prophylactic Central Neck Dissection for Papillary Thyroid Carcinoma: Prospective Cohort Study. International journal of endocrinology 2015.PMID: CN-01103105. KQ5E6H
291 Lee HN, An JY, Lee KM, Kim EJ, Choi WS and Kim DY. Salivary gland dysfunction after radioactive iodine (I-131) therapy in patients following total thyroidectomy: emphasis on radioactive iodine therapy dose. Clinical imaging 2015. p. 396-400.PMID: 25630229. KQ5E725630229
292 Lee HS, Park HS, Kim SW, Choi G, Park HS, Hong JC, Lee SG, Baek SM and Lee KD. Clinical characteristics of papillary thyroid microcarcinoma less than or equal to 5 mm on ultrasonography. European archives of oto-rhino-laryngology 2013. p. 2969-74.PMID: 23873032. KQ5E223873032
293 Lee J, Kwon IS, Bae EH and Chung WY. Comparative analysis of oncological outcomes and quality of life after robotic versus conventional open thyroidectomy with modified radical neck dissection in patients with papillary thyroid carcinoma and lateral neck node metastases. Journal of clinical endocrinology and metabolism 2013. p. 2701-8.PMID: CN-00867252. KQ5E623678034
294 Lee J, Nah KY, Kim RM, Ahn YH, Soh EY and Chung WY. Differences in postoperative outcomes, function, and cosmesis: open versus robotic thyroidectomy. Surg Endosc 2010/05/22 ed2010. p. 3186-94.PMID: 20490558. KQ5E6H20490558
295 Lee JC and Siow JK. Thyroid surgery--the Tan Tock Seng Hospital otolaryngology experience. Annals of the Academy of Medicine, Singapore 2002. p. 158-64.PMID: 11957551. KQ4E10, KQ5E1011957551
296 Lee KE, Koo do H, Im HJ, Park SK, Choi JY, Paeng JC, Chung JK, Oh SK and Youn YK. Surgical completeness of bilateral axillo-breast approach robotic thyroidectomy: comparison with conventional open thyroidectomy after propensity score matching. Surgery 2011. p. 1266-74.PMID: 22136850. KQ5E522136850
297 Lee MJ, Hong SW, Chung WY, Kwak JY, Kim MJ and Kim EK. Cytological results of ultrasound-guided fine-needle aspiration cytology for thyroid nodules: emphasis on correlation with sonographic findings. Yonsei medical journal 2011. p. 838-44.PMID: 21786450. KQ2e2c21786450
298 Lee NJ, Blakey JD, Bhuta S and Calcaterra TC. Unintentional parathyroidectomy during thyroidectomy. Laryngoscope 1999. p. 1238-40.PMID: 10443826. KQ4E2B, KQ5E410443826
299 Lee S, Lee YY, Yoon HJ, Choi E, Suh M, Park B, Jun JK, Kim Y and Choi KS. Responses to Overdiagnosis in Thyroid Cancer Screening Among Korean Women. Cancer Res Treat 2016/01/05 ed2015.PMID: 26727718. KQ3E526727718
300 Lee S, Ryu HR, Park JH, Kim KH, Kang SW, Jeong JJ, Nam KH, Chung WY and Park CS. Early surgical outcomes comparison between robotic and conventional open thyroid surgery for papillary thyroid microcarcinoma. Surgery 2012. p. 724-30.PMID: 22284763. KQ5E6h22284763
301 Lee YH, Kim DW, In HS, Park JS, Kim SH, Eom JW, Kim B, Lee EJ and Rho MH. Differentiation between benign and malignant solid thyroid nodules using an US classification system. Korean Journal of Radiology 2011. p. 559-67.PMID: 21927557. KQ2e2c21927557
302 Leenhardt L, Grosclaude P, Cherie-Challine L and Thyroid Cancer C. Increased incidence of thyroid carcinoma in france: a true epidemic or thyroid nodule management effects? Report from the French Thyroid Cancer Committee. Thyroid 2005/01/15 ed2004. p. 1056-60.PMID: 15650358. KQALLE115650358
303 Leenhardt L, Menegaux F, Franc B, Delbot T, Mansour G, Hoang C, Guillausseau C, Aurengo H, Le Guillouzic D, Turpin G, Aurengo A, Chigot JP and Hejblum G. Selection of patients with solitary thyroid nodules for operation. European Journal of Surgery 2002. p. 236-41.PMID: 12440762. KQ2e2c12440762
304 Levine RA. Value of Doppler ultrasonography in management of patients with follicular thyroid biopsy specimens. Endocrine practice 2006. p. 270-4.PMID: 16772198. KQ2E2, KQ3E216772198
305 Li C, Tao Z, Qu J, Zhou T and Xia F. A voice acoustic analysis of thyroid adenoma patients after a unilateral thyroid lobectomy. Journal of Voice 2012. p. e23-6.PMID: 21530164. KQ5e4d21530164
306 Li F, Zhang J, Wang Y and Liu L. Clinical value of elasticity imaging and contrast-enhanced ultrasound in the diagnosis of papillary thyroid microcarcinoma. Oncol Lett 2015/12/02 ed2015. p. 1371-1377.PMID: 26622676. KQ3E3A26622676
307 Li Y, Jian WH, Guo ZM, Li QL, Lin SJ and Huang HY. A Meta-analysis of Carbon Nanoparticles for Identifying Lymph Nodes and Protecting Parathyroid Glands during Surgery. Otolaryngology - Head & Neck Surgery 2015. p. 1007-16.PMID: 25897006. KQ5E3A25897006
308 Li YJ, Wang YZ, Yi ZB, Chen LL and Zhou XD. Comparison of Completion Thyroidectomy and Primary Total Surgery for Differentiated Thyroid Cancer: A Meta-Analysis. Oncology Research and Treatment 2015. p. 528-31.PMID: 26451702. KQ5E3A26451702
309 Liehn JC, Maes B and Delisle MJ. Multivariate analysis in solitary cold thyroid nodules for the diagnosis of malignancy. European Journal of Cancer & Clinical Oncology 1988. p. 881-8.PMID: 3169093. KQ2E2C3169093
310 Lin JD, Chao TC, Huang BY, Chen ST, Chang HY and Hsueh C. Thyroid cancer in the thyroid nodules evaluated by ultrasonography and fine-needle aspiration cytology. Thyroid 2005. p. 708-17.PMID: 16053388. KQ2e2c, KQ2e216053388
311 Lin JD, Chao TC, Sun JH, Ho C and Weng HF. Trends in the clinical characteristics of patients with papillary thyroid carcinoma in Taiwan. Oncology 2000. p. 280-5.PMID: 10838492. KQ4E2B10838492
312 Lin JD, Hsueh C and Chao TC. Long-Term Follow-Up of the Therapeutic Outcomes for Papillary Thyroid Carcinoma With Distant Metastasis. Medicine 2015. p. e1063.PMID: 26131826. KQ4E2B26131826
313 Lin JD, Hsueh C, Chao TC, Weng HF and Huang BY. Thyroid follicular neoplasms diagnosed by high-resolution ultrasonography with fine needle aspiration cytology. Acta cytologica 1997. p. 687-91.PMID: 9167684. KQ2E2C, KQ3E49167684
314 Lin JK, Lee CH, Lui WY and P'Eng FK. The result of the treatment of thyroid cancer. A retrospective study. Taiwan i Hsueh Hui Tsa Chih - Journal of the Formosan Medical Association 1985. p. 482-93.PMID: 3860620. KQ5E6G3860620
315 Lin WY, Shen YY and Wang SJ. Short-term hazards of low-dose radioiodine ablation therapy in postsurgical thyroid cancer patients. Clinical nuclear medicine 1996. p. 780-2.PMID: 8896926. KQ5E58896926
316 Lindahl F. Papillary thyroid carcinoma in Denmark 1943-68. II. Treatment and survival. Acta Chirurgica Scandinavica 1975. p. 504-13.PMID: 52963. KQ5E6G52963
317 Lindahl F. Papillary thyroid carcinoma in Denmark, 1943--1968. Cancer 1975. p. 540-52.PMID: 1157017. KQ5E6G1157017
318 Lips CJ, Landsvater RM, Hoppener JW, Geerdink RA, Blijham G, van Veen JM, van Gils AP, de Wit MJ, Zewald RA, Berends MJ and . Clinical screening as compared with DNA analysis in families with multiple endocrine neoplasia type 2A. N Engl J Med 1994/09/29 ed1994. p. 828-35.PMID: 7915822. KQALLE57915822
319 Liu Q, Djuricin G and Prinz RA. Total thyroidectomy for benign thyroid disease. Surgery 1998. p. 2-7.PMID: 9457216. KQ5E4D9457216
320 Liu S, Semenciw R, Ugnat AM and Mao Y. Increasing thyroid cancer incidence in Canada, 1970-1996: time trends and age-period-cohort effects. British Journal of Cancer. 2001/11/27 ed2001. p. 1335-9.PMID: 11720471. KQALLE111720471
321 Lo CY, Kwok KF and Yuen PW. A prospective evaluation of recurrent laryngeal nerve paralysis during thyroidectomy. Archives of Surgery 2000/02/11 ed2000. p. 204-7.PMID: 10668882. KQ5E4D10668882
322 Lodewijk L, Vriens MR, Vorselaars WM, van der Meij NT, Kist JW, Barentsz MW, Verkooijen HM, Rinkes IH and Valk GD. SAME-DAY FINE NEEDLE ASPIRATION CYTOLOGY DIAGNOSIS FOR THYROID NODULES ACHIEVES RAPID ANXIETY DECREASE AND HIGH DIAGNOSTIC ACCURACY. Endocr Pract. 2016/01/01 ed2015.PMID: 26720251. KQ3E426720251
323 Lombardi CP, Raffaelli M, D'Alatri L, Crea C, Marchese MR, Maccora D, Paludetti G and Bellantone R. Video-assisted thyroidectomy significantly reduces the risk of early postthyroidectomy voice and swallowing symptoms. World journal of surgery 2008. p. 693-700.PMID: CN-00647649. KQ5e518259807
324 Lombardi CP, Raffaelli M, de Crea C, Princi P, Castaldi P, Spaventa A, Salvatori M and Bellantone R. Report on 8 years of experience with video-assisted thyroidectomy for papillary thyroid carcinoma. Surgery 2007. p. 944-51; discussion 944-51.PMID: 18063080. KQ5e618063080
325 Lombardi CP, Raffaelli M, De Crea C, Sessa L and Bellantone R. Morbidity of central neck dissection: primary surgery vs reoperation. Results of a case-control study. Langenbecks Archives of Surgery 2014. p. 747-53.PMID: 24781962. KQ5E724781962
326 Londero SC, Krogdahl A, Bastholt L, Overgaard J, Pedersen HB, Frisch T, Bentzen J, Pedersen PU, Christiansen P and Godballe C. Papillary thyroid carcinoma in Denmark 1996-2008: an investigation of changes in incidence. Cancer Epidemiology 2013. p. e1-6.PMID: 23182499. KQ3E5, KQ4E523182499
327 Lopez-Bru D, Palazon-Bru A, Folgado-de la Rosa DM and Gil-Guillen VF. Scoring System for Mortality in Patients Diagnosed with and Treated Surgically for Differentiated Thyroid Carcinoma with a 20-Year Follow-Up. PLoS ONE [Electronic Resource]2015. p. e0128620.PMID: 26115328. KQ5E526115328
328 Lorente-Poch L, Sancho JJ, Ruiz S and Sitges-Serra A. Importance of in situ preservation of parathyroid glands during total thyroidectomy. British journal of surgery 2015. p. 359-67.PMID: 25605285. KQ5E425605285
329 Loyo M, Tufano RP and Gourin CG. National trends in thyroid surgery and the effect of volume on short-term outcomes. The Laryngoscope 2013. p. 2056-2063KQ5E4D23737403
330 Lu CH, Lee KD, Chen PT, Chen CC, Kuan FC, Huang CE, Chen MF and Chen MC. Second primary malignancies following thyroid cancer: a population-based study in Taiwan. Eur J Endocrinol 2013/08/14 ed2013. p. 577-85.PMID: 23939917. KQ5E223939917
331 Lu X, Huang XM, Sun W, Liang WW and Cai Q. [Comparison of the surgical stress between endoscopic thyroidectomy via anterior chest approach and conventional thyroidectomy]. Zhonghua er bi yan hou tou jing wai ke za zhi [Chinese journal of otorhinolaryngology head and neck surgery] 2010. p. 895-8.PMID: CN-00802001. KQ5e221215201
332 Lundgren CI, Stalberg P, Grodski S, Sidhu S, Sywak M and Delbridge L. Minimally invasive thyroid surgery for diagnostic excision of solitary thyroid nodules. Asian Journal of Surgery 2007. p. 250-4.PMID: 17962127. KQ5e4d17962127
333 Lushbaugh CC and Casarett GW. The effects of gonadal irradiation in clinical radiation therapy: a review. Cancer 1976/02/01 ed1976. p. 1111-25.PMID: 766956. KQ5E6G766956
334 LY W, IJ N, FL P, D T, RM T, AR S, SG P, JP S and I G. Comparable outcomes for patients with pT1a and pT1b differentiated thyroid cancer: Is there a need for change in the AJCC classification system? Surgery 2014. p. 1484-9; discussion 1489-90.PMID: 25456937. KQ5e525456937
335 Lyle MA and Dean DS. Ultrasound-Guided Fine-Needle Aspiration Biopsy of Thyroid Nodules in Patients Taking Novel Oral Anticoagulants. Thyroid 2015/01/15 ed2015.PMID: 25584817. KQ3E525584817
336 Lyons KJ, Tarter JW and Ragsdale TL. Local complications after surgical resection for thyroid carcinoma. American journal of surgery 1994. p. 404-7.PMID: 7977960. KQ5E6G7977960
337 M B, JA S, RC N, HA H, NM W and JK H. Thyroid cancers incidentally detected at imaging in a 10-year period: how many cancers would be missed with use of the recommendations from the Society of Radiologists in Ultrasound? Radiology 2014. p. 888-94.PMID: 24475865. KQ3e424475865
338 Ma SH, Liu QJ, Zhang YC and Yang R. Alternative surgical strategies in patients with sporadic medullary thyroid carcinoma: Long-term follow-up. Oncol Lett 2012/08/07 ed2011. p. 975-980.PMID: 22866159. KQ4E5, KQ5E522783375
339 Ma X, Zhang B, Ling W, Liu R, Jia H, Zhu F, Wang M, Liu H, Huang J and Liu L. Contrast-enhanced sonography for the identification of benign and malignant thyroid nodules: Systematic review and meta-analysis. Journal of Clinical Ultrasound 2015/09/25 ed2015.PMID: 26402325. KQ2E626402325
340 Machens A, Hinze R, Thomusch O and Dralle H. Pattern of nodal metastasis for primary and reoperative thyroid cancer. World journal of surgery 2002. p. 22-8.PMID: 11898029. KQ4E5, KQ5E511898029
341 Mäenpää HO, Heikkonen J, Vaalavirta L, Tenhunen M and Joensuu H. Low vs. high radioiodine activity to ablate the thyroid after thyroidectomy for cancer: a randomized study. PloS one 2008. p. e1885.PMID: CN-00638670. KQ5E2B18382668
342 Magri F, Chytiris S, Zerbini F, Capelli V, Gaiti M, Carbone A, Fonte R, Malovini A, Rotondi M, Bellazzi R and Chiovato L. Maximal stiffness evaluation by real-time ultrasound elastography, an improved tool for the differential diagnosis of thyroid nodules. Endocrine practice 2015. p. 474-81.PMID: 25667375. KQ2E2C25667375
343 Maier TM, Schober O, Gers J, Gorlich D, Wenning C, Schaefers M, Riemann B and Vrachimis A. Differentiated thyroid cancer patients more than 60 years old paradoxically show an increased life expectancy. Journal of nuclear medicine 2015. p. 190-5.PMID: 25613533. KQ4E5, KQ5E525613533
344 Makay O, Unalp O, Icoz G, Akyildiz M and Yetkin E. Completion thyroidectomy for thyroid cancer. Acta Chirurgica Belgica 2006. p. 528-31.PMID: 17168263. KQ5e617168263
345 Mallick U, Harmer C, Hackshaw A and Moss L. Iodine or Not (IoN) for Low-risk Differentiated Thyroid Cancer: The Next UK National Cancer Research Network Randomised Trial following HiLo. Clinical oncology 2012. p. 159-61.PMID: CN-00897194. KQ4e222316618
346 Marchegiani C, Lucci S, De Antoni E, Catania A, Grilli P, Pierro A and Di Matteo G. Thyroid cancer: surgical experience with 322 cases. International surgery 1985. p. 121-4.PMID: 4055275. KQ5E6G4055275
347 Marchetta FC and Sako K. The diagnosis of thyroid carcinoma during the postoperative period after less than total thyroidectomy. American journal of surgery 1978. p. 455-6.PMID: 707724. KQ4E2B, KQ5E6G707724
348 Marti JL, Jain KS and Morris LG. Increased risk of second primary malignancy in pediatric and young adult patients treated with radioactive iodine for differentiated thyroid cancer. Thyroid 2015. p. 681-7.PMID: 25851829. KQ5E425851829
349 Martins AS, Melo GM, Valerio JB, Langner E, Lage HT and Tincani AJ. Treatment of locally aggressive well-differentiated thyroid cancer. International surgery 2001. p. 213-9.PMID: 12056464. KQ5E6H12056464
350 Martins RG, Caplan RH, Lambert PJ, Rooney B and Kisken WA. Management of thyroid cancer of follicular cell origin: Gundersen/Lutheran Medical Center, 1969-1995. Journal of the American College of Surgeons 1997. p. 388-97.PMID: 9328388. KQ5E6G9328388
351 Matesa N, Tabain I, Dabelic N, Petric V and Kusic Z. Diagnostic relevance of fine needle aspiration cytology for follicular lesions of the thyroid: retrospective study. Croatian Medical Journal 2002. p. 606-9.PMID: 12402405. KQ3E512402405
352 Matsuyama H, Sugitani I, Fujimoto Y and Kawabata K. Indications for thyroid cancer surgery in elderly patients. Surgery today 2009. p. 652-7.PMID: 19639430. KQ4e719639430
353 Matsuzu K, Sugino K, Masudo K, Nagahama M, Kitagawa W, Shibuya H, Ohkuwa K, Uruno T, Suzuki A, Magoshi S, Akaishi J, Masaki C, Kawano M, Suganuma N, Rino Y, Masuda M, Kameyama K, Takami H and Ito K. Thyroid lobectomy for papillary thyroid cancer: long-term follow-up study of 1,088 cases. World journal of surgery 2014. p. 68-79.PMID: 24081532. KQ4e2b, KQ5e524081532
354 Matsuzuka F, Kobayashi A, Hirai K, Morita S, Miyauchi A, Katayama S and Sugawara M. Outcome of long standing solitary thyroid nodules. World journal of surgery 1992. p. 583-7; discussion 587-8.PMID: 1413828. KQ3E21413828
355 Matsuzuka F, Yokozawa T, Miyauchi A and Sugawara M. Fate of untreated benign thyroid nodules: results of long-term follow-up. World journal of surgery 1994. p. 495-8; discussion 499.PMID: 7725734. kq2e2, KQ3E5, KQ5E57725734
356 McConnell RJ, Brenner AV, Oliynyk VA, Robbins J, Terekhova GM, Fink DJ, Epshtein OV, Hatch M, Shpak VM, Brill AB, Shelkovoy YA, Zablotska LB, Masnyk IJ, Howe GR and Tronko MD. Factors associated with elevated serum concentrations of anti-TPO antibodies in subjects with and without diffuse goitre. Results from the Ukrainian-American Cohort Study of thyroid cancer and other thyroid diseases following the Chornobyl accident. Clinical endocrinology 2007. p. 879-90.PMID: 18052943. KQ2e3b, KQ5e518052943
357 McGuire ST and English JC, 3rd. Papillary thyroid cancer: an indication for thyroid palpation by the dermatologist. Archives of Dermatology 2010. p. 1056-7.PMID: 20855721. KQ2e2a20855721
358 Mehrvarz S, Mohebbi HA, Kalantar Motamedi MH, Khatami SM, Rezaie R and Rasouli HR. Parathyroid hormone measurement in prediction of hypocalcaemia following thyroidectomy. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan 2014. p. 82-7.PMID: 24490999. KQ5e3a24490999
359 Meijer JA, Bakker LE, Valk GD, Herder WW, Wilt JH, Netea-Maier RT, Schaper N, Fliers E, Lips P, Plukker JT, Links TP and Smit JA. Radioactive iodine in the treatment of medullary thyroid carcinoma: a controlled multicenter study. European journal of endocrinology / European Federation of Endocrine Societies 2013. p. 779-86.PMID: CN-00965040. KQ4E2B
360 Merchant WJ, Thomas SM, Coppen MJ and Prentice MG. The role of thyroid fine needle aspiration (FNA) cytology in a District General Hospital setting. Cytopathology 1995/12/01 ed1995. p. 409-18.PMID: 8770542. KQALLE18770542
361 Merchavy S, Marom T, Forest V-I, Hier M, Mlynarek A, McHugh T and Payne R. Comparison of the incidence of postoperative hypocalcemia following total thyroidectomy vs completion thyroidectomy. Otolaryngology--head and neck surgery 2014. p. 0194599814556250KQ5E6H
362 Mettler FA, Jr., Williamson MR, Royal HD, Hurley JR, Khafagi F, Sheppard MC, Beral V, Reeves G, Saenger EL, Yokoyama N and . Thyroid nodules in the population living around Chernobyl. Jama 1992/08/15 ed1992. p. 616-9.PMID: 1629989. KQALLE41629989
363 Miccoli P, Minuto MN, Galleri D, D'Agostino J, Basolo F, Antonangeli L, Aghini-Lombardi F and Berti P. Incidental thyroid carcinoma in a large series of consecutive patients operated on for benign thyroid disease. ANZ Journal of Surgery 2006. p. 123-6.PMID: 16626346. KQ3e4d16626346
364 Mihailescu DV and Schneider AB. Size, number, and distribution of thyroid nodules and the risk of malignancy in radiation-exposed patients who underwent surgery. Journal of Clinical Endocrinology & Metabolism 2008. p. 2188-93.PMID: 18381575. KQ3e4d18381575
365 Miki H, Oshimo K, Inoue H, Kawano M, Tanaka K, Komaki K, Uyama T, Morimoto T and Monden Y. Incidence of ultrasonographically-detected thyroid nodules in healthy adults. Tokushima J Exp Med 1993/06/01 ed1993. p. 43-6.PMID: 8211979. KQALLE28211979
366 Mikosch P, Wartner U, Kresnik E, Gallowitsch HJ, Heinisch M, Dinges HP and Lind P. Results of preoperative ultrasound guided fine needle aspiration biopsy of solitary thyroid nodules as compared with the histology. A retrospective analysis of 538 patients. Nuclear-Medizin 2001. p. 148-54.PMID: 11727627. KQ2E2C, KQ3E2C11727627
367 Miller W, Butters M, Leibl B and Bittner R. [Quality assurance in goiter surgery by rate of recurrent nerve paralysis]. Chirurg. 1995/12/01 ed1995. p. 1210-4.PMID: 8582164. KQ5E98582164
368 Mishra A and Mishra SK. Total thyroidectomy for differentiated thyroid cancer: primary compared with completion thyroidectomy. European Journal of Surgery 2002/10/12 ed2002. p. 283-7.PMID: 12375610. KQ5E3A12375610
369 Misiakos EP, Liakakos T, Macheras A, Zachaki A, Kakaviatos N and Karatzas G. Total thyroidectomy for the treatment of thyroid diseases in an endemic area. Southern Medical Journal 2006. p. 1224-9.PMID: 17195417. KQ5e4d17195417
370 Misiolek M, Waler J, Namyslowski G, Kucharzewski M, Podwinski A and Czecior E. Recurrent laryngeal nerve palsy after thyroid cancer surgery: a laryngological and surgical problem. Eur Arch Otorhinolaryngol 2002/01/05 ed2001. p. 460-2.PMID: 11769992. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E111769992
371 Mitov F, Dimov R, Outchikov P, Manchev I, Mourdjev K and Todorov A. A comparative analysis of the postoperative complications of thyroid cancer surgery related to surgical approach. Folia Medica (Plovdiv) 1999. p. 34-9.PMID: 10658364. KQ5E6H10658364
372 Mitra I, Nichani JR, Yap B and Homer JJ. Effect of central compartment neck dissection on hypocalcaemia incidence after total thyroidectomy for carcinoma. Journal of Laryngology & Otology 2011. p. 497-501.PMID: 21106140. KQ5e6h21106140
373 Miyauchi A. Clinical Trials of Active Surveillance of Papillary Microcarcinoma of the Thyroid. World J Surg 2016/01/09 ed2016KQ4E1, KQ5E1
374 M'Kacher R, Legal JD, Schlumberger M, Aubert B, Beron-Gaillard N, Gaussen A and Parmentier C. Sequential biological dosimetry after a single treatment with iodine-131 for differentiated thyroid carcinoma. Journal of nuclear medicine 1997. p. 377-80.PMID: 9074522. KQ5E59074522
375 Monsieurs M, Thierens H, Dierckx RA, Casier K, De Baere E, De Ridder L, De Saedeleer C, De Winter H, Lippens M, van Imschoot S, Wulfrank D and Simons M. Real-life radiation burden to relatives of patients treated with iodine-131: a study in eight centres in Flanders (Belgium). European journal of nuclear medicine 1998. p. 1368-76.PMID: 9818275. KQ5E59818275
376 Monzen S, Mariya Y, Wojcik A, Kawamura C, Nakamura A, Chiba M, Hosoda M and Takai Y. Predictive factors of cytotoxic damage in radioactive iodine treatment of differentiated thyroid cancer patients. Mol Clin Oncol 2015/07/03 ed2015. p. 692-698.PMID: 26137289. KQ5E2B26137289
377 Moon HJ, Lee HS, Kim EK, Ko SY, Seo JY, Park WJ, Park HY and Kwak JY. Thyroid nodules < 5 mm on ultrasonography: are they “leave me alone” lesions? Endocrine 2015. p. 735-44.PMID: 25600483. KQ1E2, KQ2E2C, KQ3E2, KQ4E7, KQ5E525600483
378 Moon WJ, Jung SL, Lee JH, Na DG, Baek JH, Lee YH, Kim J, Kim HS, Byun JS, Lee DH, Thyroid Study Group KSoN, Head and Neck R. Benign and malignant thyroid nodules: US differentiation--multicenter retrospective study. Radiology 2008/04/12 ed2008. p. 762-70.PMID: 18403624. KQ2E2C18403624
379 Mori I, Miyauchi A, Kuma S, Tang W and Kakudo K. Thyroid nodular lesion: analysis of cancer risk based on Kuma Hospital experience. Pathology International 2003. p. 579-83.PMID: 14507313. KQ3e514507313
380 Moritani S. Impact of lymph node metastases with recurrent laryngeal nerve invasion on patients with papillary thyroid carcinoma. Thyroid 2015. p. 107-11.PMID: 25317601. KQ5E425317601
381 Morris LF, Ragavendra N and Yeh MW. Evidence-based assessment of the role of ultrasonography in the management of benign thyroid nodules. World journal of surgery 2008. p. 1253-63.PMID: 18311500. KQ2e818311500
382 Morris LG and Myssiorek D. Improved detection does not fully explain the rising incidence of well-differentiated thyroid cancer: a population-based analysis. Am J Surg 2010/06/22 ed2010. p. 454-61.PMID: 20561605. KQ2E5, KQ3E5, KQ4E520561605
383 Morris LG, Sikora AG, Tosteson TD and Davies L. The increasing incidence of thyroid cancer: the influence of access to care. Thyroid 2013. p. 885-91.PMID: 23517343. KQ3e523517343
384 Morrissey AT, Chau J, Yunker WK, Mechor B, Seikaly H and Harris JR. Comparison of drain versus no drain thyroidectomy: randomized prospective clinical trial. Le Journal d'oto-rhino-laryngologie et de chirurgie cervico-faciale [Journal of otolaryngology - head & neck surgery]2008. p. 43-7.PMID: CN-00639625. KQ5e6
385 Mortensen JD, Woolner LB and Bennett WA. Gross and microscopic findings in clinically normal thyroid glands. J Clin Endocrinol Metab 1955/10/01 ed1955. p. 1270-80.PMID: 13263417. KQ2E213263417
386 Moulton-Barrett R, Crumley R, Jalilie S, Segina D, Allison G, Marshak D and Chan E. Complications of thyroid surgery. Int Surg 1997/01/01 ed1997. p. 63-6.PMID: 9189806. KQ5E109189806
387 Mulaudzi TV, Ramdial PK, Madiba TE and Callaghan RA. Thyroid carcinoma at King Edward VIII Hospital, Durban, South Africa. East African Medical Journal 2001. p. 242-5.PMID: 12002083. KQ5E6H12002083
388 Muruganandham K, Sistla SC, Elangovan S and Verma SK. Routine ultrasound-guided aspiration cytology for evaluation of palpable thyroid nodules in an endemic area: is it justified? Le Journal d'oto-rhino-laryngologie et de chirurgie cervico-faciale [Journal of otolaryngology - head & neck surgery] 2009. p. 222-6.PMID: CN-00721469. KQ2e3A
389 Musacchio MJ, Kim AW, Vijungco JD and Prinz RA. Greater local recurrence occurs with “berry picking” than neck dissection in thyroid cancer. American surgeon 2003. p. 191-6; discussion 196-7.PMID: 12678473. KQ5E212678473
390 Musella M, Innaro N, Castaldo P, Carrano A, Cimmino G and Musella S. 10-year experience of total thyroidectomy with special reference to 85 thyroid cancers in one Italian centre. European journal of surgical oncology 1997. p. 211-4.PMID: 9236893. KQ5E6H9236893
391 Nagataki S, Shibata Y, Inoue S, Yokoyama N, Izumi M and Shimaoka K. Thyroid diseases among atomic bomb survivors in Nagasaki. JAMA 1994/08/03 ed1994. p. 364-70.PMID: 8028167. KQALLE58028167
392 Nam KH, Yoon JH, Chang HS and Park CS. Optimal timing of surgery in well-differentiated thyroid carcinoma detected during pregnancy. Journal of surgical oncology 2005. p. 199-203.PMID: 16118775. KQ5E716118775
393 Nam-Goong IS, Kim HY, Gong G, Lee HK, Hong SJ, Kim WB and Shong YK. Ultrasonography-guided fine-needle aspiration of thyroid incidentaloma: correlation with pathological findings. Clinical endocrinology 2004. p. 21-8.PMID: 14678283. KQ3e214678283
394 Narendra H and Vamsi R. Prophylactic central node dissection in well differentiated thyroid cancers: Does this increase morbidity? European journal of cancer 2014. p. e13.PMID: CN-01059262. KQ5E3a
395 Negro R, Gharib H, Savoldi L, Barbieri V and Valcavi R. A longitudinal study of thyroidectomized patients in a region of northern Italy: benign versus malignant disease. Endocrine practice 2013. p. 259-62.PMID: 23512384. KQ5e523512384
396 Nielsen TR, Andreassen UK, Brown CL, Balle VH and Thomsen J. Microsurgical technique in thyroid surgery--a 10-year experience. Journal of Laryngology & Otology 1998. p. 556-60.PMID: 9764296. KQ4E2B, KQ5E49764296
397 Nilubol N and Kebebew E. Should small papillary thyroid cancer be observed? A population-based study. Cancer 2015. p. 1017-24.PMID: 25425528. KQ5E525425528
398 Nishiyama RLG, Thompson NW The prevalence of small papillary thyroid carcinomas in 100 consecutive necropsies in an American population. In: L. DeGroot, editor. New York: Grune & Stratton; 1977. p. 123-125KQ2E5
399 Nixon IJ, Ganly I, Patel S, Palmer FL, Whitcher MM, Tuttle RM, Shaha AR and Shah JP. The impact of microscopic extrathyroid extension on outcome in patients with clinical T1 and T2 well-differentiated thyroid cancer. Surgery 2011. p. 1242-9.PMID: 22136847. KQ4e2b, KQ5e522136847
400 Nixon IJ, Wang LY, Ganly I, Patel SG, Morris LG, Migliacci JC, Tuttle RM, Shah JP and Shaha AR. Outcomes for patients with papillary thyroid cancer who do not undergo prophylactic central neck dissection. Br J Surg 2015/10/30 ed2015.PMID: 26511531. KQ4E2B, KQ5E426511531
401 Njolstad PR, Akslen LA, Albrektsen G, Viste A, Soreide O and Varhaug JE. Thyroid carcinoma: results from surgical treatment in 211 consecutive patients. European Journal of Surgery 1991. p. 521-6.PMID: 1683575. KQ5E6G1683575
402 Noguchi S, Yamashita H, Murakami N, Nakayama I, Toda M and Kawamoto H. Small carcinomas of the thyroid. A long-term follow-up of 867 patients. Archives of Surgery 1996. p. 187-91.PMID: 8611077. KQ5E6G8611077
403 Noguchi S, Yamashita H, Uchino S and Watanabe S. Papillary microcarcinoma. World journal of surgery 2008. p. 747-53.PMID: 18264828. KQ3e518264828
404 Nolan NG, Koppikar MM and Kotlyarov EV. Thyroid scanning of the patient with history of childhood irradiation. Annals of Clinical & Laboratory Science 1981. p. 31-6.PMID: 7212627. KQALLE27212627
405 Noureldine SI, Abbas A, Tufano RP, Srivastav S, Slakey DP, Friedlander P and Kandil E. The impact of surgical volume on racial disparity in thyroid and parathyroid surgery. Annals of surgical oncology 2014. p. 2733-9.PMID: 24633666. KQ5E424633666
406 Noureldine SI, Genther DJ, Lopez M, Agrawal N and Tufano RP. Early predictors of hypocalcemia after total thyroidectomy: an analysis of 304 patients using a short-stay monitoring protocol. JAMA Otolaryngology-- Head & Neck Surgery 2014. p. 1006-13.PMID: 25321339. KQ4e2b, KQ5e525321339
407 Nygard B, Hegedus L, Karstrup S and Hansen JM. Observer variation in ultrasound assessment of the thyroid gland. British Journal of Radiology 1993. p. 625-7.PMID: 8374729. KQ1E2B, KQ2E2, KQ3E58374729
408 Oeda T, Terano T, Omura M, Tahara K, Nishikawa T, Tamura Y and Yoshida S. Comparative studies on fine-needle aspiration cytology with ultrasound scanning in the assessment of thyroid nodule. Japanese Journal of Medicine 1990. p. 478-80.PMID: 1708432. KQ2E2C, KQ3E51708432
409 Olbricht T, Emrich D, Benker G and Reinwein D. Long-term follow-up in patients with autonomous thyroid adenoma. Acta Endocrinologica 1993. p. 51-5.PMID: 8447194. KQ4E58447194
410 Ontai S and Straehley CJ. The surgical treatment of well-differentiated carcinoma of the thyroid. American surgeon 1985. p. 653-7.PMID: 4062059. KQ5E6G4062059
411 Orloff LA, Weymuller EA and Flaherty MJ. Papillary thyroid carcinoma mistaken for malignant melanoma: pitfalls in diagnosis. Head & neck 1995. p. 157-60.PMID: 7558815. KQ2E2, KQ3E27558815
412 Orsenigo E, Beretta E, Veronesi P, Mari G, Gini P and Di Carlo V. Total thyroidectomy in the treatment of thyroid cancer. European journal of surgical oncology 1995. p. 478-81.PMID: 7589589. KQ4E5, KQ5E6G7589589
413 Otto RA and Cochran CS. Sensitivity and specificity of intraoperative recurrent laryngeal nerve stimulation in predicting postoperative nerve paralysis. Annals of Otology, Rhinology & Laryngology. 2002/11/27 ed2002. p. 1005-7.PMID: 12450175. KQ5E512450175
414 Ozel A, Erturk SM, Ercan A, Yilmaz B, Basak T, Cantisani V, Basak M and Karpat Z. The diagnostic efficiency of ultrasound in characterization for thyroid nodules: how many criteria are required to predict malignancy? Medical Ultrasonography 2012. p. 24-8.PMID: 22396935. KQ2e2c22396935
415 Pacini F, Vorontsova T, Molinaro E, Shavrova E, Agate L, Kuchinskaya E, Elisei R, Demidchik EP and Pinchera A. Thyroid consequences of the Chernobyl nuclear accident. Acta Paediatrica Supplement 1999. p. 23-7.PMID: 10626541. KQALLE3B10626541
416 Paek SH, Lee YM, Min SY, Kim SW, Chung KW and Youn YK. Risk factors of hypoparathyroidism following total thyroidectomy for thyroid cancer. World journal of surgery 2013. p. 94-101.PMID: 23052805. KQ5e6h23052805
417 Panzarella T, Carruthers JS, Gospodarowicz MK and Sutcliffe SB. Papillary and follicular thyroid cancer: impact of treatment in 1578 patients. International Journal of Radiation Oncology, Biology, Physics 1988. p. 1063-75.PMID: 2454902. KQ4E2B, KQ5E6G2454902
418 Papini E, Guglielmi R, Bianchini A, Crescenzi A, Taccogna S, Nardi F, Panunzi C, Rinaldi R, Toscano V and Pacella CM. Risk of malignancy in nonpalpable thyroid nodules: predictive value of ultrasound and color-Doppler features. Journal of Clinical Endocrinology & Metabolism 2002. p. 1941-6.PMID: 11994321. KQ2e4, KQ3e411994321
419 Park CS, Kim SH, Jung SL, Kang BJ, Kim JY, Choi JJ, Sung MS, Yim HW and Jeong SH. Observer variability in the sonographic evaluation of thyroid nodules. Journal of Clinical Ultrasound 2010. p. 287-93.PMID: 20544863. KQ2e2c, KQ3e420544863
420 Park KN, Jung CH, Mok JO, Kwak JJ and Lee SW. Prospective comparative study of endoscopic via unilateral axillobreast approach versus open conventional total thyroidectomy in patients with papillary thyroid carcinoma. Surg Endosc 2015/12/15 ed2015.PMID: 26659230. KQ5E726659230
421 Paschke R, Lincke T, Muller SP, Kreissl MC, Dralle H and Fassnacht M. The Treatment of Well-Differentiated Thyroid Carcinoma. Deutsches Arzteblatt International 2015. p. 452-8.PMID: 26205749. KQ5E226205749
422 Passler C, Avanessian R, Kaczirek K, Prager G, Scheuba C and Niederle B. Thyroid surgery in the geriatric patient. Archives of Surgery 2002. p. 1243-8.PMID: 12413310. KQ5e512413310
423 Pathak KA, Leslie WD, Klonisch TC and Nason RW. The changing face of thyroid cancer in a population-based cohort. Cancer Medicine 2013. p. 537-44.PMID: 24156026. KQ4e2b24156026
424 Peccin S, de Castsro JA, Furlanetto TW, Furtado AP, Brasil BA and Czepielewski MA. Ultrasonography: is it useful in the diagnosis of cancer in thyroid nodules? Journal of endocrinological investigation 2002. p. 39-43.PMID: 11885575. KQ2E3A11885575
425 Peiling Yang S, Bach AM, Michael Tuttle R and Fish SA. Frequent screening with serial neck ultrasound is more likely to identify false positive abnormalities than clinically significant disease in the surveillance of intermediate risk papillary thyroid cancer patients without suspicious findings on follow-up ultrasound evaluation. Journal of Clinical Endocrinology & Metabolism. 2015/01/31 ed2015. p. jc20143651.PMID: 25632970. KQ2E5, KQ3E525632970
426 Pelizzo MR, Boschin IM, Toniato A, Piotto A, Bernante P, Pagetta C, Rampin L and Rubello D. Papillary thyroid microcarcinoma (PTMC): prognostic factors, management and outcome in 403 patients. European journal of surgical oncology 2006. p. 1144-8.PMID: 16872798. KQ5e6h16872798
427 Pellegriti G, Frasca F, Regalbuto C, Squatrito S and Vigneri R. Worldwide increasing incidence of thyroid cancer: update on epidemiology and risk factors. J Cancer Epidemiol 2013/06/06 ed2013. p. 965212.PMID: 23737785. KQALLE123737785
428 Pellegriti G, Scollo C, Lumera G, Regalbuto C, Vigneri R and Belfiore A. Clinical behavior and outcome of papillary thyroid cancers smaller than 1.5 cm in diameter: study of 299 cases. Journal of Clinical Endocrinology & Metabolism 2004. p. 3713-20.PMID: 15292295. kQ3e415292295
429 Pereira JA, Jimeno J, Miquel J, Iglesias M, Munne A, Sancho JJ and Sitges-Serra A. Nodal yield, morbidity, and recurrence after central neck dissection for papillary thyroid carcinoma. Surgery 2005. p. 1095-100, discussion 1100-1.PMID: 16360396. KQ5e6h16360396
430 Perrino M, Vannucchi G, Vicentini L, Cantoni G, Dazzi D, Colombo C, Rodari M, Chiti A, Beck-Peccoz P and Fugazzola L. Outcome predictors and impact of central node dissection and radiometabolic treatments in papillary thyroid cancers < or =2 cm. Endocrine-related cancer 2009. p. 201-10.PMID: 19106146. KQ5e2a19106146
431 Pezzullo L, Delrio P, Losito NS, Caraco C and Mozzillo N. Post-operative complications after completion thyroidectomy for differentiated thyroid cancer. European journal of surgical oncology 1997. p. 215-8.PMID: 9236894. KQ5E69236894
432 Podnos YD, Smith D, Wagman LD and Ellenhorn JD. Radioactive iodine offers survival improvement in patients with follicular carcinoma of the thyroid. Surgery 2005. p. 1072-6; discussion 1076-7.PMID: 16360393. KQ4e2b16360393
433 Polistena A, Monacelli M, Lucchini R, Triola R, Conti C, Avenia S, Barillaro I, Sanguinetti A and Avenia N. Surgical morbidity of cervical lymphadenectomy for thyroid cancer: A retrospective cohort study over 25 years. International Journal Of Surgery 2015. p. 128-34.PMID: 26253851. KQ5E6H26253851
434 Polyzos SA, Kita M, Efstathiadou Z, Goulis DG, Benos A, Flaris N, Leontsini M and Avramidis A. The use of demographic, ultrasonographic and scintigraphic data in the diagnostic approach of thyroid nodules. Experimental & Clinical Endocrinology & Diabetes 2009. p. 159-64.PMID: 19085697. KQ2e2a19085697
435 Porterfield JR, Jr., Grant CS, Dean DS, Thompson GB, Farley DR, Richards ML, Reading CC, Charboneau JW, Vollrath BK and Sebo TJ. Reliability of benign fine needle aspiration cytology of large thyroid nodules. Surgery 2008. p. 963-8; discussion 968-9.PMID: 19041004. KQ2E1, KQ3E519041004
436 Pottern LM, Kaplan MM, Larsen PR, Silva JE, Koenig RJ, Lubin JH, Stovall M and Boice JD, Jr. Thyroid nodularity after childhood irradiation for lymphoid hyperplasia: a comparison of questionnaire and clinical findings. J Clin Epidemiol 1990/01/01 ed1990. p. 449-60.PMID: 2324785. KQALLE52324785
437 Qiu ZL, Shen CT and Luo QY. Clinical management and outcomes in patients with hyperfunctioning distant metastases from differentiated thyroid cancer after total thyroidectomy and radioactive iodine therapy. Thyroid 2015. p. 229-37.PMID: 25331724. KQ5E3A25331724
438 Quan ML, Pasieka JL and Rorstad O. Bone mineral density in well-differentiated thyroid cancer patients treated with suppressive thyroxine: a systematic overview of the literature. Journal of surgical oncology 2002. p. 62-9; discussion 69-70.PMID: 11754378. KQ5E811754378
439 Rafferty MA, Goldstein DP, Rotstein L, Asa SL, Panzarella T, Gullane P, Gilbert RW, Brown DH and Irish JC. Completion thyroidectomy versus total thyroidectomy: is there a difference in complication rates? An analysis of 350 patients. Journal of the American College of Surgeons 2007. p. 602-7.PMID: 17903736. KQ5E4D17903736
440 Rapoport A, Curioni OA, Amar A and Dedivitis RA. Review of survival rates 20-years after conservative surgery for papillary thyroid carcinoma. Revista Brasileira de Otorrinolaringologia 2015. p. 389-93.PMID: 26120098. KQ5E3B26120098
441 Rassael H, Thompson LD and Heffess CS. A rationale for conservative management of microscopic papillary carcinoma of the thyroid gland: a clinicopathologic correlation of 90 cases. European archives of oto-rhino-laryngology 1998. p. 462-7.PMID: 9833215. KQ5E6G9833215
442 Reeve TS, Delbridge L, Sloan D and Crummer P. The impact of fine-needle aspiration biopsy on surgery for single thyroid nodules. Medical Journal of Australia 1986. p. 308-11.PMID: 3531785. KQ2E2, KQ3E23531785
443 Renshaw A. An estimate of risk of malignancy for a benign diagnosis in thyroid fine-needle aspirates.[Erratum appears in Cancer Cytopathol. 2010 Oct 25;118(5):303]. Cancer Cytopathology 2010. p. 190-5.PMID: 20586117. KQ3e520586117
444 Renshaw AA. Focal features of papillary carcinoma of the thyroid in fine-needle aspiration material are strongly associated with papillary carcinoma at resection. American Journal of Clinical Pathology 2002. p. 208-10.PMID: 12162679. KQ3e2a12162679
445 Roberts JW, Symmonds RE, Jr., Hendricks JC, Snyder SK, Frazee RC, Smith RW, McKenney JF and Brindley GV, Jr. Safety and efficacy of total thyroidectomy for differentiated thyroid carcinoma: a 20-year review. American surgeon 1993. p. 110-4.PMID: 8476139. KQ5E28476139
446 Robie DK, Dinauer CW, Tuttle RM, Ward DT, Parry R, McClellan D, Svec R, Adair C and Francis G. The impact of initial surgical management on outcome in young patients with differentiated thyroid cancer. Journal of Pediatric Surgery 1998. p. 1134-8; discussion 1139-40.PMID: 9694109. KQ5E4E9694109
447 Roh JL, Park JY and Park CI. Total thyroidectomy plus neck dissection in differentiated papillary thyroid carcinoma patients: pattern of nodal metastasis, morbidity, recurrence, and postoperative levels of serum parathyroid hormone. Annals of surgery 2007. p. 604-10.PMID: 17414610. KQ5E517414610
448 Roher HD, Goretzki PE, Hellmann P and Witte J. [Complications in thyroid surgery. Incidence and therapy]. Chirurg. 1999/09/29 ed1999. p. 999-1010.PMID: 10501664. KQ5E910501664
449 Ron E, Modan B, Preston D, Alfandary E, Stovall M and Boice JD, Jr. Thyroid neoplasia following low-dose radiation in childhood. Radiat Res 1989/12/01 ed1989. p. 516-31.PMID: 2594972. KQ2e22594972
450 Rosario PW, Barroso AL, Rezende LL, Padrao EL, Borges MA, Guimaraes VC and Purisch S. Testicular function after radioiodine therapy in patients with thyroid cancer. Thyroid 2006/08/08 ed2006. p. 667-70.PMID: 16889490. KQALLE3A16889490
451 Rosário PW, Pereira LF, Padrão EL, Rezende LL, Barroso ÁL and Purisch S. Comparison of completion thyroidectomy and primary surgery for thyroid carcinoma. ANZ Journal of Surgery 2007. p. 305-305KQ5E3A
452 Rosario PW, Vasconcelos FP, Cardoso LD, Lauria MW, Rezende LL, Padrao EL, Barroso AL, Guimaraes VC and Purisch S. Managing thyroid cancer without thyroxine withdrawal. Arquivos Brasileiros de Endocrinologia e Metabologia 2006. p. 91-6.PMID: 16628280. KQ5e3a16628280
453 Rosato L, Carlevato MT, De Toma G and Avenia N. Recurrent laryngeal nerve damage and phonetic modifications after total thyroidectomy: surgical malpractice only or predictable sequence? World J Surg 2005/05/17 ed2005. p. 780-4.PMID: 15895296. KQ5E6H15895296
454 Rosen IB, Wallace C, Strawbridge HG and Walfish PG. Reevaluation of needle aspiration cytology in detection of thyroid cancer. Surgery 1981. p. 747-56.PMID: 7281013. KQ5E6G7281013
455 Rosenbaum MA and McHenry CR. Central neck dissection for papillary thyroid cancer. Archives of Otolaryngology -- Head & Neck Surgery 2009. p. 1092-7.PMID: 19917920. KQ5E6H19917920
456 Rosenbluth BD, Serrano V, Happersett L, Shaha AR, Tuttle RM, Narayana A, Wolden SL, Rosenzweig KE, Chong LM and Lee NY. Intensity-modulated radiation therapy for the treatment of nonanaplastic thyroid cancer. International Journal of Radiation Oncology, Biology, Physics 2005. p. 1419-26.PMID: 16154712. KQ5e616154712
457 Rossi R, Roti E, Trasforini G, Pansini G, Cavazzini L, Zatelli MC, Pearce EN, Braverman LE and Uberti EC. Differentiated thyroid cancers 11-20 mm in diameter have clinical and histopathologic characteristics suggesting higher aggressiveness than those < or =10 mm. Thyroid 2008. p. 309-15.PMID: 18341377. KQ5e518341377
458 Rossing M, Nygaard B, Nielsen FC and Bennedbaek FN. High prevalence of papillary thyroid microcarcinoma in danish patients: a prospective study of 854 consecutive patients with a cold thyroid nodule undergoing fine-needle aspiration. European Thyroid Journal 2012. p. 110-7.PMID: 24783005. KQ2e524783005
459 Royce PC, MacKay BR and DiSabella PM. Value of postirradiation screening for thyroid nodules. A controlled study of recalled patients. Jama. 1979/12/14 ed1979. p. 2675-8.PMID: 501862. KQ2E4D501862
460 Rubino C, de Vathaire F, Dottorini ME, Hall P, Schvartz C, Couette JE, Dondon MG, Abbas MT, Langlois C and Schlumberger M. Second primary malignancies in thyroid cancer patients. British Journal of Cancer 2003. p. 1638-44.PMID: 14583762. KQ5e6g14583762
461 Ruel E, Thomas S, Dinan M, Perkins JM, Roman SA and Sosa JA. Adjuvant radioactive iodine therapy is associated with improved survival for patients with intermediate-risk papillary thyroid cancer. Journal of Clinical Endocrinology & Metabolism 2015. p. 1529-36.PMID: 25642591. KQ5E2B25642591
462 Ryu HR, Lee J, Park JH, Kang SW, Jeong JJ, Hong JY and Chung WY. A comparison of postoperative pain after conventional open thyroidectomy and transaxillary single-incision robotic thyroidectomy: a prospective study. Annals of surgical oncology 2013. p. 2279-84.PMID: CN-00964673. KQ5E6h23529779
463 Ryu J, Ryu YM, Jung YS, Kim SJ, Lee YJ, Lee EK, Kim SK, Kim TS, Kim TH, Lee CY, Park SY and Chung KW. Extent of thyroidectomy affects vocal and throat functions: a prospective observational study of lobectomy versus total thyroidectomy. Surgery 2013. p. 611-20.PMID: 23932596. KQ5E523932596
464 S C, Zanocco K, Sturgeon C, Yeh MW and Harari A. Risk-based ultrasound screening for thyroid cancer in obese patients is cost-effective. Thyroid 2014. p. 975-86.PMID: 24512476. KQ1E224512476
465 Saad MF, Guido JJ and Samaan NA. Radioactive iodine in the treatment of medullary carcinoma of the thyroid. Journal of Clinical Endocrinology & Metabolism 1983. p. 124-8.PMID: 6853671. KQ4E6G6853671
466 Sabel MS, Haque D, Velasco JM and Staren ED. Use of ultrasound-guided fine needle aspiration biopsy in the management of thyroid disease. American surgeon 1998. p. 738-41; discussion 741-2.PMID: 9697903. KQ3E59697903
467 Sadetzki S, Calderon-Margalit R, Peretz C, Novikov I, Barchana M and Papa MZ. Second primary breast and thyroid cancers (Israel). Cancer Causes & Control. 2003/07/09 ed2003. p. 367-75.PMID: 12846369. KQ5E512846369
468 Sahin SB, Ogullar S, Ural UM, Ilkkilic K, Metin Y and Ayaz T. Alterations of thyroid volume and nodular size during and after pregnancy in a severe iodine-deficient area. Clinical endocrinology 2014. p. 762-8.PMID: 24811142. KQ2E3A24811142
469 Saint-Vil D, Emran MA, Lambert R, Alos N, Turpin S and Huot C. Cumulative doses of adjunct 131I treatment depend on location of residual thyroid tissue after total thyroidectomy in differentiated thyroid cancer. Journal of Pediatric Surgery 2007. p. 853-6.PMID: 17502198. KQ5e617502198
470 Samaan NA, Maheshwari YK, Nader S, Hill CS, Jr., Schultz PN, Haynie TP, Hickey RC, Clark RL, Goepfert H, Ibanez ML and Litton CE. Impact of therapy for differentiated carcinoma of the thyroid: an analysis of 706 cases. Journal of Clinical Endocrinology & Metabolism 1983. p. 1131-8.PMID: 6841555. KQ4E2B, KQ5E6G6841555
471 Sampson RJ, Woolner LB, Bahn RC and Kurland LT. Occult thyroid carcinoma in Olmsted County, Minnesota: prevalence at autopsy compared with that in Hiroshima and Nagasaki, Japan. Cancer 1974/12/01 ed1974. p. 2072-6.PMID: 4474057. KQ2E54474057
472 Sancho JJ, Lennard TW, Paunovic I, Triponez F and Sitges-Serra A. Prophylactic central neck disection in papillary thyroid cancer: a consensus report of the European Society of Endocrine Surgeons (ESES). Langenbecks Archives of Surgery 2014. p. 155-63.PMID: 24352594. KQ5E224352594
473 Sand J, Palkola K and Salmi J. Surgical complications after total thyroidectomy and resections for differentiated thyroid carcinoma. Annales Chirurgiae et Gynaecologiae 1996. p. 305-8.PMID: 9014059. KQ4E2B, KQ5E6G9014059
474 Sandeep TC, Strachan MW, Reynolds RM, Brewster DH, Scelo G, Pukkala E, Hemminki K, Anderson A, Tracey E, Friis S, McBride ML, Kee-Seng C, Pompe-Kirn V, Kliewer EV, Tonita JM, Jonasson JG, Martos C, Boffetta P and Brennan P. Second primary cancers in thyroid cancer patients: a multinational record linkage study. Journal of Clinical Endocrinology & Metabolism 2006. p. 1819-25.PMID: 16478820. KQ5e516478820
475 Sarkar SD, Beierwaltes WH, Gill SP and Cowley BJ. Subsequent fertility and birth histories of children and adolescents treated with 131I for thyroid cancer. Journal of nuclear medicine 1976. p. 460-4.PMID: 944243. KQ5E6G944243
476 Sarlis NJ and Gourgiotis L. Unresolved issues, dilemmas and points of interest in thyroid cancer: a current perspective. Hormones 2004. p. 149-70.PMID: 16982589. KQALLE216982589
477 Sarlis NJ, Gourgiotis L and Filie AC. Misclassification of cytologic diagnoses in patients with follicular lesions or follicular neoplasms of the thyroid gland: implications for patient care and clinical research. Cancer 2002. p. 323-4.PMID: 12478678. KQ3e212478678
478 Sasson AR, Pingpank JF, Jr., Wetherington RW, Hanlon AL and Ridge JA. Incidental parathyroidectomy during thyroid surgery does not cause transient symptomatic hypocalcemia. Archives of Otolaryngology -- Head & Neck Surgery 2001. p. 304-8.PMID: 11255476. KQ2E5, KQ5E6H11255476
479 Sawka AM, Brierley JD, Tsang RW, Thabane L, Rotstein L, Gafni A, Straus S and Goldstein DP. An updated systematic review and commentary examining the effectiveness of radioactive iodine remnant ablation in well-differentiated thyroid cancer. Endocrinology & Metabolism Clinics of North America 2008. p. 457-80, x.PMID: 18502337. KQ4e2b18502337
480 Sawka AM, Lakra DC, Lea J, Alshehri B, Tsang RW, Brierley JD, Straus S, Thabane L, Gafni A, Ezzat S, George SR and Goldstein DP. A systematic review examining the effects of therapeutic radioactive iodine on ovarian function and future pregnancy in female thyroid cancer survivors. Clinical endocrinology 2008. p. 479-90.PMID: 18284643. KQ5e218284643
481 Sawka AM, Lea J, Alshehri B, Straus S, Tsang RW, Brierley JD, Thabane L, Rotstein L, Gafni A, Ezzat S and Goldstein DP. A systematic review of the gonadal effects of therapeutic radioactive iodine in male thyroid cancer survivors. Clinical endocrinology 2008. p. 610-7.PMID: 17973944. KQ5E817973944
482 Sawka AM, Thabane L, Parlea L, Ibrahim-Zada I, Tsang RW, Brierley JD, Straus S, Ezzat S and Goldstein DP. Second primary malignancy risk after radioactive iodine treatment for thyroid cancer: a systematic review and meta-analysis. Thyroid 2009. p. 451-7.PMID: 19281429. KQ5e819281429
483 Scerrino G, Attard A, Melfa GI, Raspanti C, Di Giovanni S, Attard M, Inviati A, Mazzola S, Modica G, Gulotta G and Bonventre S. Role of Prophylactic Central Neck Dissection in CN0-Papillary Thyroid Carcinoma: Results from a High-Prevalence Area. Minerva Chirurgica 2015/06/06 ed2015.PMID: 26046958. KQ4E4 KQ5E426046958
484 Scheuller MC and Ellison D. Laryngeal mask anesthesia with intraoperative laryngoscopy for identification of the recurrent laryngeal nerve during thyroidectomy. Laryngoscope 2002/09/28 ed2002. p. 1594-7.PMID: 12352669. KQ5E2A12352669
485 Schleder S, Janke M, Agha A, Schacherer D, Hornung M, Schlitt HJ, Stroszczynski C, Schreyer AG and Jung EM. Preoperative differentiation of thyroid adenomas and thyroid carcinomas using high resolution contrast-enhanced ultrasound (CEUS). Clinical Hemorheology & Microcirculation. 2014/06/06 ed2014.PMID: 24898562. KQ2E5, KQ3E524898562
486 Schleder S, Janke M, Agha A, Schacherer D, Hornung M, Schlitt HJ, Stroszczynski C, Schreyer AG and Jung EM. Preoperative differentiation of thyroid adenomas and thyroid carcinomas using high resolution contrast-enhanced ultrasound (CEUS). Clinical Hemorheology & Microcirculation 2015. p. 13-22.PMID: 24898562. KQ2E2C24898562
487 Schlumberger M, Berg G, Cohen O, Duntas L, Jamar F, Jarzab B, Limbert E, Lind P, Pacini F, Reiners C, Sanchez Franco F, Toft A and Wiersinga WM. Follow-up of low-risk patients with differentiated thyroid carcinoma: a European perspective. European Journal of Endocrinology 2004. p. 105-12.PMID: 14763906. KQ5e114763906
488 Schneider AB, Bekerman C, Leland J, Rosengarten J, Hyun H, Collins B, Shore-Freedman E and Gierlowski TC. Thyroid nodules in the follow-up of irradiated individuals: comparison of thyroid ultrasound with scanning and palpation. Journal of Clinical Endocrinology & Metabolism 1997. p. 4020-7.PMID: 9398706. KQ2E5, KQ3E59398706
489 Schneider DF, Mazeh H, Oltmann SC, Chen H and Sippel RS. Novel thyroidectomy difficulty scale correlates with operative times. World journal of surgery 2014. p. 1984-9.PMID: 24615607. KQ5E4D24615607
490 Schroder DM, Chambors A and France CJ. Operative strategy for thyroid cancer. Is total thyroidectomy worth the price? Cancer 1986. p. 2320-8.PMID: 3756777. KQ5E6G3756777
491 Schultz PN, Hickey RC, Goepfert H, Haynie TP, Johnston DA and Ordonez NG. The results of various modalities of treatment of well differentiated thyroid carcinomas: a retrospective review of 1599 patients. Journal of Clinical Endocrinology & Metabolism 1992. p. 714-20.PMID: 1517360. KQ5E51517360
492 Schvartz C, Bonnetain F, Dabakuyo S, Gauthier M, Cueff A, Fieffe S, Pochart JM, Cochet I, Crevisy E, Dalac A, Papathanassiou D and Toubeau M. Impact on overall survival of radioactive iodine in low-risk differentiated thyroid cancer patients. Journal of Clinical Endocrinology & Metabolism 2012. p. 1526-35.PMID: 22344193. KQ4E6G, KQ5E6G22344193
493 Schwerk WB, Grun R and Wahl R. Ultrasound diagnosis of C-cell carcinoma of the thyroid. Cancer 1985. p. 624-30.PMID: 2856898. KQ2E4C, KQ3E4C2856898
494 Scopa CD, Gatopoulou C, Chalmoukis A, Androulakis J and Vagenakis A. Diagnosis of thyroid cancer in southwestern Greece. Bulletin du Cancer 1991. p. 953-9.PMID: 1768941. KQ2E2, KQ3E21768941
495 Sdano MT, Falciglia M, Welge JA and Steward DL. Efficacy of thyroid hormone suppression for benign thyroid nodules: meta-analysis of randomized trials. Otolaryngology - Head & Neck Surgery 2005. p. 391-6.PMID: 16143188. KQ4e6, KQ5e616143188
496 Seiberling KA, Dutra JC and Gunn J. Ultrasound-guided fine needle aspiration biopsy of thyroid nodules performed in the office. Laryngoscope 2008. p. 228-31.PMID: 17989576. KQ1E2B, KQ2E2C, KQ3E517989576
497 Selberherr A, Scheuba C, Riss P and Niederle B. Postoperative hypoparathyroidism after thyroidectomy: efficient and cost-effective diagnosis and treatment. Surgery 2015. p. 349-53.PMID: 25532435. KQ5E4D25532435
498 Seo H, Na DG, Kim JH, Kim KW and Yoon JW. Ultrasound-Based Risk Stratification for Malignancy in Thyroid Nodules: A Four-Tier Categorization System. Eur Radiol 2015/02/15 ed2015.PMID: 25680723. KQ2E2C25680723
499 Sevim T. Risk factors for permanent laryngeal nerve paralysis in patients with thyroid carcinoma. Clinical Otolaryngology 2007. p. 378-83.PMID: 17883559. KQ5e3a17883559
500 Shan CX, Zhang W, Jiang DZ, Zheng XM, Liu S and Qiu M. Routine central neck dissection in differentiated thyroid carcinoma: a systematic review and meta-analysis. Laryngoscope 2012. p. 797-804.PMID: 22294492. KQ5e222294492
501 Shao J, Shen Y, Lu J and Wang J. Ultrasound scoring in combination with ultrasound elastography for differentiating benign and malignant thyroid nodules. Clin Endocrinol (Oxf). 2014/08/21 ed2014.PMID: 25138622. KQ2E3A, KQ3E3A25138622
502 Sharen G, Zhang B, Zhao R, Sun J, Gai X and Lou H. Retrospective epidemiological study of thyroid nodules by ultrasound in asymptomatic subjects. Chinese Medical Journal 2014. p. 1661-5.PMID: 24791871. KQ2E3A24791871
503 Shaub M and Wilson R. The ultrasonic evaluation of nonfunctioning thyroid nodules. Western Journal of Medicine 1975. p. 265-8.PMID: 1199079. KQ2E2C, KQ3E51199079
504 Shen WT, Ogawa L, Ruan D, Suh I, Kebebew E, Duh QY and Clark OH. Central neck lymph node dissection for papillary thyroid cancer: comparison of complication and recurrence rates in 295 initial dissections and reoperations. Archives of Surgery 2010. p. 272-5.PMID: 20231628. KQ5E520231628
505 Shore RE, Hildreth N, Dvoretsky P, Andresen E, Moseson M and Pasternack B. Thyroid cancer among persons given X-ray treatment in infancy for an enlarged thymus gland. American Journal of Epidemiology 1993. p. 1068-80.PMID: 8317436. KQ2E58317436
506 Siebers G, Neumann C and Ritzl EK. Thyroid carcinoma: a follow-up study of 11 years. Radiation & Environmental Biophysics 1987. p. 283-8.PMID: 3685251. KQ5E23685251
507 Silberstein EB. Reducing the incidence of 131I-induced sialadenitis: the role of pilocarpine. Journal of nuclear medicine 2008. p. 546-9.PMID: CN-00638377. KQ5e2b18344428
508 Sinnott B, Ron E and Schneider AB. Exposing the thyroid to radiation: a review of its current extent, risks, and implications. Endocr Rev 2010/07/24 ed2010. p. 756-73.PMID: 20650861. KQALLE220650861
509 Slowinnska-Klencka D, Sporny S, Klencki M and Lewinnski A. Non-diagnostic cytological outcome of thyroid biopsy and the risk of thyroid malignancy. Endocrine pathology 2004. p. 65-75.PMID: 15067178. KQ3e515067178
510 Slowinska-Klencka D, Popowicz B, Lewinski A, Sporny S and Klencki M. The fine-needle aspiration biopsy efficacy of small thyroid nodules in the area of recently normalized iodine supply. European Journal of Endocrinology 2008. p. 747-54.PMID: 18794209. KQ3e318794209
511 Smith JA, Sharma N, Nankivell P and Watkinson JC. The presentation, natural history and outcome of T1 a/b thyroid cancer with regard to new grading systems. European archives of oto-rhino-laryngology 2015. p. 439-44.PMID: 24643850. KQ5E224643850
512 Smith-Bindman R, Lebda P, Feldstein VA, Sellami D, Goldstein RB, Brasic N, Jin C and Kornak J. Risk of thyroid cancer based on thyroid ultrasound imaging characteristics: results of a population-based study. JAMA Internal Medicine 2013. p. 1788-96.PMID: 23978950. KQ2e2c, KQ3e523978950
513 Solbiati L, Volterrani L, Rizzatto G, Bazzocchi M, Busilacci P, Candiani F, Ferrari F, Giuseppetti G, Maresca G, Mirk P and . The thyroid gland with low uptake lesions: evaluation by ultrasound. Radiology 1985/04/01 ed1985. p. 187-91.PMID: 3883413. KQ2E2C3883413
514 Solomon NP, Helou LB, Henry LR, Howard RS, Coppit G, Shaha AR and Stojadinovic A. Utility of the voice handicap index as an indicator of postthyroidectomy voice dysfunction. Journal of Voice 2013. p. 348-54.PMID: 23294708. KQ5e223294708
515 Somerville HM, Steinbeck KS, Stevens G, Delbridge LW, Lam AH and Stevens MM. Thyroid neoplasia following irradiation in adolescent and young adult survivors of childhood cancer. Medical Journal of Australia 2002. p. 584-7.PMID: 12064957. KQ2e4e, KQ3e4e12064957
516 Son SK, Kim JH, Bae JS and Lee SH. Surgical Safety and Oncologic Effectiveness in Robotic versus Conventional Open Thyroidectomy in Thyroid Cancer: A Systematic Review and Meta-Analysis. Ann Surg Oncol 2015/01/31 ed2015.PMID: 25634780. KQ5E425634780
517 Song HJ, Qiu ZL, Shen CT, Wei WJ and Luo QY. Pulmonary metastases in differentiated thyroid cancer: efficacy of radioiodine therapy and prognostic factors. European Journal of Endocrinology 2015. p. 399-408.PMID: 26104753. KQ5E3A26104753
518 Songun I, Kievit J and van de Velde CJ. Complications of thyroid surgery. Annals of surgical oncology 1995. p. 56-60.PMID: 7834455. KQ5E4D7834455
519 Songun I, Kievit J, Wobbes T, Peerdeman A and van de Velde CJ. Extent of thyroidectomy in nodular thyroid disease. European Journal of Surgery 1999. p. 839-42.PMID: 10533757. KQ5E4D10533757
520 Soreide O, Varhaug JE and Heimann P. Thyroid carcinoma: diagnosis and treatment in 106 patients. Acta Chirurgica Scandinavica 1979. p. 137-41.PMID: 494958. KQ1E1, KQ2E1, KQ3E1, KQ4E6G, KQ5E6G494958
521 Souza MC, Momesso DP, Vaisman F, Vieira Neto L, Martins RA, Corbo R and Vaisman M. Is radioactive iodine- 131 treatment related to the occurrence of non-synchronous second primary malignancy in patients with differentiated thyroid cancer? Arch Endocrinol Metab 2015/07/30 ed2015. p. 0.PMID: 26222230. KQ5E3A26222230
522 Spencer R, Brown MC and Annis D. Ultrasonic scanning of the thyroid gland as a guide to the treatment of the clinically solitary nodule. British journal of surgery 1977. p. 841-6.PMID: 588980. KQ5E6G588980
523 Stacul F, Bertolotto M, De Gobbis F, Calderan L, Cioffi V, Romano A, Zanconati F and Cova MA. US, colour-Doppler US and fine-needle aspiration biopsy in the diagnosis of thyroid nodules. Radiologia Medica 2007. p. 751-62.PMID: 17657415. KQ2e2c17657415
524 Stacul F, Bertolotto M, Zappetti R, Zanconati F and Cova MA. The radiologist and the cytologist in diagnosing thyroid nodules: results of cooperation. Radiologia Medica 2007. p. 597-602.PMID: 17563853. KQ2e5, KQ3e517563853
525 Staren ED, D'Amore MJ, Kluskens LF, Martirano M and Economou SG. Importance of repeat fine-needle biopsy in the management of thyroid nodules. American journal of surgery 1993. p. 350-2.PMID: 8214290. KQ3E58214290
526 Steinmuller T, Klupp J, Wenking S and Neuhaus P. Complications associated with different surgical approaches to differentiated thyroid carcinoma. Langenbecks Archives of Surgery 1999/06/15 ed1999. p. 50-3.PMID: 10367630. KQ5E6G10367630
527 Stockwell RM, Barry M and Davidoff F. Managing thyroid abnormalities in adults exposed to upper body irradiation in childhood: a decision analysis. Should patients without palpable nodules be scanned and those with scan defects be subjected to subtotal thyroidectomy? Journal of Clinical Endocrinology & Metabolism 1984. p. 804-12.PMID: 6707185. KQ2E56707185
528 Stojadinovic A, Shaha AR, Orlikoff RF, Nissan A, Kornak MF, Singh B, Boyle JO, Shah JP, Brennan MF and Kraus DH. Prospective functional voice assessment in patients undergoing thyroid surgery. Annals of surgery 2002. p. 823-32.PMID: 12454521. KQ5e512454521
529 Stokkel MP, Hoekstra A and van Rijk PP. The detection of small carcinoma with 18F-FDG using a dual head coincidence camera. European journal of radiology 1999. p. 160-2.PMID: 10632552. KQALLE2C10632552
530 Strong EW. Complications after total thyroidectomy. Otolaryngology - Head & Neck Surgery 1989. p. 472-5.PMID: 2508025. KQ5E42508025
531 Sturniolo G, D'Alia C, Tonante A, Gagliano E, Taranto F and Lo Schiavo MG. The recurrent laryngeal nerve related to thyroid surgery. Am J Surg 1999/07/22 ed1999. p. 485-8.PMID: 10414699. KQ45E4D10414699
532 Subramanian S, Goldstein DP, Parlea L, Thabane L, Ezzat S, Ibrahim-Zada I, Straus S, Brierley JD, Tsang RW, Gafni A, Rotstein L and Sawka AM. Second primary malignancy risk in thyroid cancer survivors: a systematic review and meta-analysis. Thyroid 2007. p. 1277-88.PMID: 18020916. KQ5E818020916
533 Sugitani I, Toda K, Yamada K, Yamamoto N, Ikenaga M and Fujimoto Y. Three distinctly different kinds of papillary thyroid microcarcinoma should be recognized: our treatment strategies and outcomes. World journal of surgery 2010. p. 1222-31.PMID: 20066418. KQ5e520066418
534 Sugitani I, Toda K, Yamamoto N, Sakamoto A and Fujimoto Y. Re-evaluation of histopathological factors affecting prognosis of differentiated thyroid carcinoma in an iodine-sufficient country. World J Surg 2009/12/03 ed2010. p. 1265-73.PMID: 19953247. KQALLE519953247
535 Suh CH, Baek JH, Lee JH, Choi YJ, Kim JK, Sung TY, Yoon JH and Shong YK. The Role of Core-Needle Biopsy as a First-Line Diagnostic Tool for Initially Detected Thyroid Nodules. Thyroid 2015/12/15 ed2016.PMID: 26651390. KQ3E626651390
536 Sun GH, Peress L and Pynnonen MA. Systematic review and meta-analysis of robotic vs conventional thyroidectomy approaches for thyroid disease. Otolaryngology - Head & Neck Surgery 2014. p. 520-32.PMID: 24500878. KQ4e2b, KQ5e824500878
537 Svendsen FM, Badsgard SE, Nielsen PH and Egeblad K. [Recurrent nerve injury after goiter surgery]. Ugeskr Laeger. 1990/04/30 ed1990. p. 1288-90.PMID: 2343481. KQALLE42343481
538 Tae HJ, Lim DJ, Baek KH, Park WC, Lee YS, Choi JE, Lee JM, Kang MI, Cha BY, Son HY, Lee KW and Kang SK. Diagnostic value of ultrasonography to distinguish between benign and malignant lesions in the management of thyroid nodules. Thyroid 2007. p. 461-6.PMID: 17542676. KQ2E2C17542676
539 Tae K, Song CM, Ji YB, Kim KR, Kim JY and Choi YY. Comparison of surgical completeness between robotic total thyroidectomy versus open thyroidectomy. Laryngoscope 2014. p. 1042-7.PMID: 24338236. KQ5E6H24338236
540 Takahashi T, Trott KR, Fujimori K, Simon SL, Ohtomo H, Nakashima N, Takaya K, Kimura N, Satomi S and Schoemaker MJ. An investigation into the prevalence of thyroid disease on Kwajalein Atoll, Marshall Islands. Health Phys 1997/07/01 ed1997. p. 199-213.PMID: 9199230. KQALLE49199230
541 Takamura Y, Miyauchi A, Yabuta T, Kihara M, Ito Y and Miya A. Attenuation of postmenopausal bone loss in patients with transient hypoparathyroidism after total thyroidectomy. World journal of surgery 2013. p. 2860-5.PMID: 24045966. KQ5E2B24045966
542 Tan GH, Gharib H and Reading CC. Solitary thyroid nodule. Comparison between palpation and ultrasonography. Archives of Internal Medicine 1995. p. 2418-23.PMID: 7503600. KQ2E2C7503600
543 Tan Z, Gu J, Han Q, Wang W, Wang K, Ge M and Shang J. Comparison of Conventional Open Thyroidectomy and Endoscopic Thyroidectomy via Breast Approach for Papillary Thyroid Carcinoma. International Journal of Endocrinology Print 2015. p. 239610.PMID: 26379706. KQ5E6H26379706
544 Tanriover O, Comunoglu N, Eren B, Comunoglu C, Turkmen N, Dogan M and Gundogmus UN. Occult papillary thyroid carcinoma: prevalence at autopsy in Turkish people. European Journal of Cancer Prevention 2011/04/06 ed2011. p. 308-12.PMID: 21464719. KQ1E2, KQ2E2, KQ3E3A, KQ4E2, KQ5E221464719
545 Tay SY, Chen CY and Chan WP. Sonographic criteria predictive of benign thyroid nodules useful in avoiding unnecessary ultrasound-guided fine needle aspiration. Journal of the Formosan Medical Association 2015. p. 590-7.PMID: 24866975. KQ2E2C24866975
546 Taylor T, Specker B, Robbins J, Sperling M, Ho M, Ain K, Bigos ST, Brierley J, Cooper D, Haugen B, Hay I, Hertzberg V, Klein I, Klein H, Ladenson P, Nishiyama R, Ross D, Sherman S and Maxon HR. Outcome after treatment of high-risk papillary and non-Hurthle-cell follicular thyroid carcinoma. Annals of internal medicine 1998. p. 622-7.PMID: 9786809. KQ4E2B, KQ5E59786809
547 Teng CJ, Hu YW, Chen SC, Yeh CM, Chiang HL, Chen TJ and Liu CJ. Use of Radioactive Iodine for Thyroid Cancer and Risk of Second Primary Malignancy: A Nationwide Population-Based Study. Journal of the National Cancer Institute 2016.PMID: 26538627. KQ5E3B26538627
548 Terris DJ, Bonnett A, Gourin CG and Chin E. Minimally invasive thyroidectomy using the Sofferman technique. Laryngoscope 2005. p. 1104-8.PMID: 15933531. KQ4e2b, KQ5e6h15933531
549 Terris DJ, Gourin CG and Chin E. Minimally invasive thyroidectomy: basic and advanced techniques. Laryngoscope 2006. p. 350-6.PMID: 16540887. KQ5e616540887
550 Testini M, Nacchiero M, Portincasa P, Miniello S, Piccinni G, Di Venere B, Campanile L, Lissidini G and Bonomo GM. Risk factors of morbidity in thyroid surgery: analysis of the last 5 years of experience in a general surgery unit. International surgery 2004. p. 125-30.PMID: 15521247. KQ4e2b, KQ5e4d15521247
551 Thachil J, Gatt A and Martlew V. Management of surgical patients receiving anticoagulation and antiplatelet agents. Br J Surg 2008/11/11 ed2008. p. 1437-48.PMID: 18991253. KQALLE118991253
552 Thermann M, Feltkamp M, Elies W and Windhorst T. [Recurrent laryngeal nerve paralysis after thyroid gland operations. Etiology and consequences]. Chirurg. 1998/11/17 ed1998. p. 951-6.PMID: 9816453. KQ5E99816453
553 Thomson DB, Grammes CF, Starkey RH, Monsaert RP and Sunderlin FS. Thyroid abnormalities in patients previously treated with irradiation for acne vulgaris. Southern Medical Journal 1984. p. 21-3.PMID: 6229881. KQ2E76229881
554 Tomoda C, Takamura Y, Ito Y, Miya A and Miyauchi A. Transient vocal cord paralysis after fine-needle aspiration biopsy of thyroid tumor. Thyroid 2006. p. 697-9.PMID: 16889495. KQ3e516889495
555 Toniato A, Boschin IM, Piotto A, Pelizzo MR, Guolo A, Foletto M and Casalide E. Complications in thyroid surgery for carcinoma: one institution's surgical experience. World journal of surgery 2008. p. 572-5.PMID: 18204947. KQ4e5, KQ5e6h18204947
556 Trerotoli P, Ciampolillo A, Marinelli G, Giorgino R and Serio G. Prevalence of thyroid nodules in an occupationally radiation exposed group: a cross sectional study in an area with mild iodine deficiency. BMC Public Health 2005. p. 73.PMID: 16000179. KQ3e416000179
557 Trimboli P, Nasrollah N, Amendola S, Rossi F, Ramacciato G, Romanelli F, Aurello P, Crescenzi A, Laurenti O, Condorelli E, Ventura C and Valabrega S. Should we use ultrasound features associated with papillary thyroid cancer in diagnosing medullary thyroid cancer? Endocr J 2012/03/27 ed2012. p. 503-8.PMID: 22447142. KQ1E2B, KQ2E2C, KQ3E4, KQ4E4, KQ5E422447142
558 Trimboli P, Treglia G, Sadeghi R, Romanelli F and Giovanella L. Reliability of real-time elastography to diagnose thyroid nodules previously read at FNAC as indeterminate: a meta-analysis. Endocrine 2014/12/24 ed2014.PMID: 25534701. KQ2E225534701
559 TS W, Goffredo P, Sosa JA and Roman SA. Papillary thyroid microcarcinoma: an over-treated malignancy? World journal of surgery 2014. p. 2297-303.PMID: 24791670. KQ4E5, KQ5E524791670
560 Tseng LM, Lee CH, Wang HC, Shyr YM, Chiu JH, Wu CW, Lui WY and P'Eng F K. The surgical treatment and prognostic factors of well-differentiated thyroid cancers in Chinese patients: a 20-year experience. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal 1996. p. 121-31.PMID: 8915115. KQ4E2B, KQ5E6G8915115
561 Tseng YT and Chang TC. Multimodality treatment of anaplastic thyroid cancer with nearly resolved effect. Journal of the Formosan Medical Association 2014/04/24 ed2014.PMID: 24755268. KQ4E2A, KQ5E2A24755268
562 Tucker MA, Jones PH, Boice JD, Jr., Robison LL, Stone BJ, Stovall M, Jenkin RD, Lubin JH, Baum ES, Siegel SE and . Therapeutic radiation at a young age is linked to secondary thyroid cancer. The Late Effects Study Group Cancer Res 1991/06/11 ed1991. p. 2885-8.PMID: 1851664. KQALLE51851664
563 Tunbridge WM, Evered DC, Hall R, Appleton D, Brewis M, Clark F, Evans JG, Young E, Bird T and Smith PA. The spectrum of thyroid disease in a community: the Whickham survey. Clin Endocrinol (Oxf). 1977/12/01 ed1977. p. 481-93.PMID: 598014. KQALLE1598014
564 Tunca F, Giles Y, Terzioglu T, Mudun A, Adalet I, Salmaslioglu A and Tezelman S. Does intraoperative radioguided surgery influence the complication rates and completeness of completion thyroidectomy? American journal of surgery 2008. p. 40-6.PMID: CN-00638978. KQ4e2b, KQ5e4
565 Ukrainski MB, Pribitkin EA and Miller JL. Increasing Incidence of Thyroid Nodules and Thyroid Cancer: Does Increased Detection of a Subclinical Reservoir Justify the Associated Anxiety and Treatment? Clinical Therapeutics 2015/10/06 ed2015.PMID: 26434793. KQALLE526434793
566 Uppal A, White MG, Nagar S, Aschebrook-Kilfoy B, Chang PJ, Angelos P, Kaplan EL and Grogan RH. Benign and Malignant Thyroid Incidentalomas Are Rare in Routine Clinical Practice: A Review of 97,908 Imaging Studies. Cancer Epidemiology, Biomarkers & Prevention 2015. p. 1327-31.PMID: 26160694. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E526160694
567 Uruno T, Miyauchi A, Shimizu K, Tomoda C, Takamura Y, Ito Y, Miya A, Kobayashi K, Matsuzuka F, Amino N and Kuma K. Favorable surgical results in 433 elderly patients with papillary thyroid cancer. World journal of surgery 2005. p. 1497-501; discussion 1502-3.PMID: 16222446. KQ4E7, KQ5E516222446
568 Vaiman M, Nagibin A and Olevson J. Complications in primary and completed thyroidectomy. Surgery today 2010. p. 114-8.PMID: 20107949. KQ5e3a20107949
569 Valachis A and Nearchou A. High versus low radioiodine activity in patients with differentiated thyroid cancer: a meta-analysis. Acta Oncologica 2013. p. 1055-61.PMID: 23193961. KQ5e623193961
570 Valerio L, Viola D, Materazzi G, Miccoli P, Basolo F, Sensi E, Faviana P, Molinaro E, Agate L and Elisei R. Prophylactic central compartment lymph node dissection (CCND) does not improve the outcome of papillary thyroid cancer (PTC) patients: Results from the first prospective cohort study. European Thyroid Journal 2013. p. 94.PMID: CN-01100913. KQALLE7 (ONLY ABSTRACT AVAILABLE)
571 Valerio L, Viola D, Materazzi G, Miccoli P, Basolo F, Sensi E, Faviana P, Molinaro E, Agate L, Pinchera A and Elisei R. Pros and cons of prophylactic central compartment lymph node dissection in differentiated thyroid cancer patients. European Thyroid Journal 2012. p. 181.PMID: CN-01088909. KQALLE7 (ONLY ABLSTRACT AVAILABLE)
572 Valle LA and Kloos RT. The prevalence of occult medullary thyroid carcinoma at autopsy. Journal of Clinical Endocrinology & Metabolism. 2010/10/15 ed2011. p. E109-13.PMID: 20943788. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E120943788
573 Van de Velde CJ, Goslings BM, Schelfhout LJ, Fleuren GJ, Hermans J and Zwaveling A. Prognosis and morbidity after total thyroidectomy for papillary, follicular and medullary thyroid cancer. European Journal of Cancer & Clinical Oncology 1989. p. 1317-23.PMID: 2806355. KQ5E6G2806355
574 Van Fossen VL, Wilhelm SM, Eaton JL and McHenry CR. Association of thyroid, breast and renal cell cancer: a population-based study of the prevalence of second malignancies. Annals of surgical oncology 2013. p. 1341-7.PMID: 23263698. KQ5e623263698
575 van Heerden JA, Groh MA and Grant CS. Early postoperative morbidity after surgical treatment of thyroid carcinoma. Surgery 1987. p. 224-7.PMID: 3810493. KQ5E6G3810493
576 Vanderpump MP, Alexander L, Scarpello JH and Clayton RN. An audit of the management of thyroid cancer in a district general hospital. Clinical endocrinology 1998. p. 419-24.PMID: 9640408. KQ4E5, KQ5E59640408
577 Varverakis E and Neonakis E. Contribution of high-resolution ultrasonography in the differential diagnosis of benign from malignant thyroid nodules. Hormones 2002. p. 51-6.PMID: 17018439. KQ2E517018439
578 Varverakis E, Neonakis E, Tzardi M and Chrysos E. Role of color Doppler ultrasonography in the preoperative management of cold thyroid nodules. Hormones 2007. p. 44-51.PMID: 17324917. KQ2e2c17324917
579 Vega-Vazquez MA, Gonzalez-Rodriguez L, Santiago-Rodriguez EJ, Garces-Dominguez A, Shum LM, Tirado-Gomez M and Ramirez-Vick M. Quality of life-in patients with differentiated thyroid cancer at the general endocrinology clinics of the University Hospital of Puerto Rico. Boletin - Asociacion Medica de Puerto Rico 2015. p. 25-31.PMID: 26035981. KQ2E2C26035981
580 Verbeek HH, Meijer JA, Zandee WT, Kramp KH, Sluiter WJ, Smit JW, Kievit J, Links TP and Plukker JT. Fewer cancer reoperations for medullary thyroid cancer after initial surgery according to ATA guidelines. Annals of surgical oncology 2015. p. 1207-13.PMID: 25316487. KQ5E425316487
581 Verburg FA, Stokkel MP, Duren C, Verkooijen RB, Mader U, van Isselt JW, Marlowe RJ, Smit JW, Reiners C and Luster M. No survival difference after successful (131)I ablation between patients with initially low-risk and high-risk differentiated thyroid cancer. European Journal of Nuclear Medicine & Molecular Imaging 2010. p. 276-83.PMID: 20091165. KQ5e520091165
582 Verkooijen RB, Smit JW, Romijn JA and Stokkel MP. The incidence of second primary tumors in thyroid cancer patients is increased, but not related to treatment of thyroid cancer. European Journal of Endocrinology 2006. p. 801-6.PMID: 17132748. KQ5E217132748
583 Vincent G. Thyroidectomy over a quarter of a century in the Belgian Ardennes: a retrospective study of 1207 patients. Acta Chirurgica Belgica 2008. p. 542-7.PMID: 19051463. KQ5e419051463
584 Vini L, Hyer S, Al-Saadi A, Pratt B and Harmer C. Prognosis for fertility and ovarian function after treatment with radioiodine for thyroid cancer. Postgraduate Medical Journal 2002. p. 92-3.PMID: 11807191. KQ5E611807191
585 Viola D, Valerio L, Faviana P, Molinaro E, Sensi E, Agate L, Materazzi G, Basolo F, Miccoli P, Vitti P and Elisei R. Advantages and disadvantages of prophylactic central compartment lymph node dissection for differentiated thyroid cancer: The first randomized controlled study from a single referral center. Endocrine reviews 2013.PMID: CN-01049521. KQALLE7 (only abstract available)
586 Wada N, Hasegawa S, Masudo Y, Hirakawa S, Matsuzu K, Suganuma N, Nakayama H, Rino Y and Imada T. Clinical outcome by AMES risk definition in Japanese differentiated thyroid carcinoma patients. Asian Journal of Surgery 2007. p. 102-7.PMID: 17475578. KQ5E517475578
587 Walker J, Findlay D, Amar SS, Small PG, Wastie ML and Pegg CA. A prospective study of thyroid ultrasound scan in the clinically solitary thyroid nodule. British Journal of Radiology 1985. p. 617-9.PMID: 3893613. KQ5E6G3893613
588 Walter MA, Turtschi CP, Schindler C, Minnig P, Muller-Brand J and Muller B. The dental safety profile of high-dose radioiodine therapy for thyroid cancer: long-term results of a longitudinal cohort study. Journal of nuclear medicine 2007. p. 1620-5.PMID: 17873131. KQ5e6H17873131
589 Wang LY, Roman BR, Palmer FL, Tuttle RM, Shaha AR, Shah JP, Patel SG and Ganly I. Effectiveness of routine ultrasonographic surveillance of patients with low-risk papillary carcinoma of the thyroid. Surgery 2016/01/10 ed2015.PMID: 26747227. KQ4E5, KQ5E526747227
590 Wang Y and Wang W. Increasing Incidence of Thyroid Cancer in Shanghai, China, 1983-2007. Asia Pac J Public Health. 2012/02/22 ed2012.PMID: 22345304. KQ3E222345304
591 Wei X, Li Y, Zhang S and Gao M. A Meta-analysis of thyroid imaging reporting and data system in the ultrasonographic diagnosis of 10,437 thyroid nodules. Head Neck 2014/09/23 ed2014.PMID: 25244250. KQ2E2C25244250
592 Wei X, Li Y, Zhang S, Li X, Luo J and Ming G. WITHDRAWN:Evaluation of microcirculation of thyroid cancer in Chinese females with breast cancer using contrast-enhanced ultrasound (CEUS) combined with VEGF and microvessel density (MVD). Clinical Hemorheology & Microcirculation. 2013/03/13 ed2013.PMID: 23478226. KQ2E2, KQ3E223478226
593 Weinrib SL, Lane WS and Rappaport JM. Successful management of differentiated thyroid cancer in a community-based endocrine practice. Endocrine practice 2012. p. 170-8.PMID: 21940280. KQ3E521940280
594 Welch K and McHenry CR. Selective lateral compartment neck dissection for thyroid cancer. Journal of surgical research 2013. p. 193-9.PMID: 23816244. KQ5e2b23816244
595 Weng HF, Huang MJ, Huang BY, Huang HS and Jeng LB. Thyroid cancer treated in Chang Gung Memorial Hospital (northern Taiwan) during the period 1979-1992: clinical presentation, pathological finding, analysis of prognostic variables, and results of treatment. Journal of surgical oncology 1994. p. 252-9; discussion 259-60.PMID: 7990481. KQ3E5, KQ5E6G7990481
596 Wichers M, Benz E, Palmedo H, Biersack HJ, Grunwald F and Klingmuller D. Testicular function after radioiodine therapy for thyroid carcinoma. European journal of nuclear medicine 2000. p. 503-7.PMID: 10853804. KQ5E510853804
597 Widder S, Guggisberg K, Khalil M and Pasieka JL. A pathologic re-review of follicular thyroid neoplasms: the impact of changing the threshold for the diagnosis of the follicular variant of papillary thyroid carcinoma. Surgery 2008. p. 80-5.PMID: 18571588. KQ3e118571588
598 Wienhold R, Scholz M, Adler JR, C GN and Paschke R. The management of thyroid nodules: a retrospective analysis of health insurance data. Deutsches Arzteblatt International 2013. p. 827-34.PMID: 24355935. KQ5e4d24355935
599 Wiest PW, Hartshorne MF, Inskip PD, Crooks LA, Vela BS, Telepak RJ, Williamson MR, Blumhardt R, Bauman JM and Tekkel M. Thyroid palpation versus high-resolution thyroid ultrasonography in the detection of nodules. Journal of ultrasound in medicine 1998. p. 487-96.PMID: 9697951. KQ2E2B9697951
600 Wilhelm SM, Robinson AV, Krishnamurthi SS and Reynolds HL. Evaluation and management of incidental thyroid nodules in patients with another primary malignancy. Surgery 2007. p. 581-6; discussion 586-7.PMID: 17950351. KQ2e5b17950351
601 Winchester DJ. Total lobectomy and total thyroidectomy in the management of thyroid lesions. Archives of Surgery 1993. p. 1060-3; discussion 1064.PMID: 8368926. KQ5E4D8368926
602 Wingo PA, Tong T and Bolden S. Cancer statistics, 1995. CA Cancer J Clin 1995/01/01 ed1995. p. 8-30.PMID: 7528632. KQALLE67528632
603 Wiseman SM, Baliski C, Irvine R, Anderson D, Wilkins G, Filipenko D, Zhang H and Bugis S. Hemithyroidectomy: the optimal initial surgical approach for individuals undergoing surgery for a cytological diagnosis of follicular neoplasm. Annals of surgical oncology 2006. p. 425-32.PMID: 16485160. KQ5e516485160
604 Witt RL and McNamara AM. Prognostic factors in mortality and morbidity in patients with differentiated thyroid cancer. Ear, Nose, & Throat Journal 2002. p. 856-63.PMID: 12516384. KQ5e512516384
605 Wolinski K, Szkudlarek M, Szczepanek-Parulska E and Ruchala M. Usefulness of different ultrasound features of malignancy in predicting the type of thyroid lesions: a meta-analysis of prospective studies. Polskie Archiwum Medycyny Wewnetrznej 2014. p. 97-104.PMID: 24473342. KQ2e824473342
606 Wu JQ, Feng HJ, Ouyang W, Sun YG, Chen P, Wang J, Xian JL and Huang LH. Systematic evaluation of salivary gland damage following I-131 therapy in differentiated thyroid cancer patients by quantitative scintigraphy and clinical follow-up. Nuclear Medicine Communications 2015. p. 819-26.PMID: 25932534. KQ5E3A25932534
607 Wu Q, Wang Y, Li Y, Hu B and He ZY. Diagnostic value of contrast-enhanced ultrasound in solid thyroid nodules with and without enhancement. Endocrine 2016/01/07 ed2016.PMID: 26732040. KQ2E3A26732040
608 Xia Q, Dong S, Bian PD, Wang J and Li CJ. Effects of endocrine therapy on the prognosis of elderly patients after surgery for papillary thyroid carcinoma. Eur Arch Otorhinolaryngol 2015/03/07 ed2015.PMID: 25744048. KQ5E525744048
609 Xue H, Takahashi H, Cangir A and Andrassy RJ. Iodine 131 thyroid ablation in female children and adolescents: long-term risk of infertility and birth defects. Annals of surgical oncology 1994. p. 128-31.PMID: 7834437. KQ5E47834437
610 Xue S, Wang P, Liu J, Li R, Zhang L and Chen G. Prophylactic central lymph node dissection in cN0 patients with papillary thyroid carcinoma: A retrospective study in China. Asian J Surg 2015/06/29 ed2015.PMID: 26117203. KQ5E3A26117203
611 Yamashita H, Noguchi S, Watanabe S, Uchino S, Kawamoto H, Toda M, Murakami N, Nakayama I and Yamashita H. Thyroid cancer associated with adenomatous goiter: an analysis of the incidence and clinical factors. Surgery today 1997. p. 495-9.PMID: 9306541. KQ2E4, KQ3E49306541
612 Yang GC, LiVolsi VA and Baloch ZW. Thyroid microcarcinoma: fine-needle aspiration diagnosis and histologic follow-up. International Journal of Surgical Pathology 2002. p. 133-9.PMID: 12075406. KQ3e512075406
613 Yi H, Long B, Ye X, Zhang L, Liu X and Zhang C. Autophagy: A potential target for thyroid cancer therapy (Review). Mol Clin Oncol 2014/07/24 ed2014. p. 661-665.PMID: 25054028. KQALLE425054028
614 Yi O, Yoon JH, Lee YM, Sung TY, Chung KW, Kim TY, Kim WB, Shong YK, Ryu JS and Hong SJ. Technical and oncologic safety of robotic thyroid surgery. Annals of surgical oncology 2013. p. 1927-33.PMID: 23306957. kq5e6h23306957
615 Yokozawa T, Miyauchi A, Kuma K and Sugawara M. Accurate and simple method of diagnosing thyroid nodules the modified technique of ultrasound-guided fine needle aspiration biopsy. Thyroid 1995. p. 141-5.PMID: 7647575. KQ2E2, KQ3E27647575
616 Yoo JY, Chae YJ, Cho HB, Park KH, Kim JS and Lee SY. Comparison of the incidence of postoperative nausea and vomiting between women undergoing open or robot-assisted thyroidectomy. Surg Endosc 2012/12/15 ed2013. p. 1321-5.PMID: 23239293. kq5e523239293
617 Yoon JH, Kwak JY, Kim EK, Moon HJ, Kim MJ, Kim JY, Koo HR and Kim MH. How to approach thyroid nodules with indeterminate cytology. Annals of surgical oncology 2010. p. 2147-55.PMID: 20217250. KQ1E2C, KQ3E420217250
618 Yoon JH, Lee HS, Kim EK, Moon HJ and Kwak JY. Malignancy Risk Stratification of Thyroid Nodules: Comparison between the Thyroid Imaging Reporting and Data System and the 2014 American Thyroid Association Management Guidelines. Radiology 2015/09/09 ed2015. p. 150056.PMID: 26348102. KQ2E2C26348102
619 Yoon JH, Shin HJ, Kim EK, Moon HJ, Roh YH and Kwak JY. Quantitative Evaluation of Vascularity Using 2-D Power Doppler Ultrasonography May Not Identify Malignancy of the Thyroid. Ultrasound in medicine & biology 2015. p. 2873-83.PMID: 26298035. KQ2E2C26298035
620 You YN and Wells SA, Jr. Role of surgeons in clinical trials for thyroid cancer. World journal of surgery 2007. p. 987-95.PMID: 17426898. KQ4e2, KQ5e217426898
621 Younes J, Ghorra C, Abadjian G, Sidaoui J and Abboud B. Differentiated thyroid carcinoma in early adulthood patients. Acta Chirurgica Belgica 2014. p. 388-92.PMID: 26021683. KQ5E6H26021683
622 Young S, Harari A, Smooke-Praw S, Ituarte PH and Yeh MW. Effect of reoperation on outcomes in papillary thyroid cancer. Surgery 2013. p. 1354-61; discussion 1361-2.PMID: 24238053. KQ4e2b24238053
623 Yu XM, Wan Y, Sippel RS and Chen H. Should all papillary thyroid microcarcinomas be aggressively treated? An analysis of 18,445 cases. Annals of surgery 2011. p. 653-60.PMID: 21876434. KQ3e2, KQ4e2b21876434
624 Yuan WH, Chiou HJ, Chou YH, Hsu HC, Tiu CM, Cheng CY and Lee CH. Gray-scale and color Doppler ultrasonographic manifestations of papillary thyroid carcinoma: analysis of 51 cases. Clinical imaging 2006. p. 394-401.PMID: 17101408. KQ2e2c17101408
625 Ywata de Carvalho A, Chulam TC and Kowalski LP. Long-term Results of Observation vs Prophylactic Selective Level VI Neck Dissection for Papillary Thyroid Carcinoma at a Cancer Center. JAMA Otolaryngology-- Head & Neck Surgery 2015. p. 599-606.PMID: 25997016. KQ5E3A25997016
626 Zeppa P, Benincasa G, Lucariello A and Palombini L. Association of different pathologic processes of the thyroid gland in fine needle aspiration samples. Acta cytologica 2001. p. 347-52.PMID: 11393065. KQ3E511393065
627 Zhang J, Chen Z and Anil G. Ultrasound-guided thyroid nodule biopsy: outcomes and correlation with imaging features. Clin Imaging 2014/12/06 ed2014.PMID: 25475702. KQ2E2C, KQ3E2C25475702
628 Zhang J, Liu BJ, Xu HX, Xu JM, Zhang YF, Liu C, Wu J, Sun LP, Guo LH, Liu LN, Xu XH and Qu S. Prospective validation of an ultrasound-based thyroid imaging reporting and data system (TI-RADS) on 3980 thyroid nodules. International journal of clinical and experimental medicine 2015. p. 5911-7.PMID: 26131184. KQ2E2C26131184
629 Zhang L, Liu Z, Liu Y, Gao W and Zheng C. The clinical prognosis of patients with cN0 papillary thyroid microcarcinoma by central neck dissection. World journal of surgical oncology 2015. p. 138.PMID: 25889385. KQ5E3A25889385
630 Zhang S, Zheng XQ, Wei X, Zhao J, Zhang Y and Gao M. Evaluation of ultrasound application in diagnosis and clinical staging of thyroid cancers. Indian Journal of Cancer 2014/12/11 ed2014. p. 193-199.PMID: 25494104. KQ3E3A, KQ2E3A25494104
631 Zhang Y, Liang J, Li H, Cong H and Lin Y. Risk of second primary breast cancer after radioactive iodine treatment in thyroid cancer: a systematic review and meta-analysis. Nuclear Medicine Communications 2016. p. 110-5.PMID: 26513055. KQ5E226513055
632 Zhang YF, Xu HX, Xu JM, Liu C, Guo LH, Liu LN, Zhang J, Xu XH, Qu S and Xing M. Acoustic Radiation Force Impulse Elastography in the Diagnosis of Thyroid Nodules: Useful or Not Useful? Ultrasound in medicine & biology 2015. p. 2581-93.PMID: 26119458. KQ2E2C26119458
633 Zhang YF, Xu JM, Xu HX, Liu C, Bo XW, Li XL, Guo LH, Liu BJ, Liu LN and Xu XH. Acoustic Radiation Force Impulse Elastography: A Useful Tool for Differential Diagnosis of Thyroid Nodules and Recommending Fine-Needle Aspiration: A Diagnostic Accuracy Study. Medicine 2015. p. e1834.PMID: 26496325. KQ2E2C26496325
634 Zhao ZH, Li FQ, Han JK and Li XJ. Effect of I ‘clear residual thyroid tissue’ after surgery on the function of parathyroid gland in differentiated thyroid cancer. Exp Ther Med 2015/12/17 ed2015. p. 2079-2082.PMID: 26668598. KQ5E3A26668598
635 Zhu W, Zhong M and Ai Z. Systematic evaluation of prophylactic neck dissection for the treatment of papillary thyroid carcinoma. Japanese Journal of Clinical Oncology 2013. p. 883-8.PMID: 23858039. KQ5E2A23858039
636 Zuniga S and Sanabria A. Prophylactic central neck dissection in stage N0 papillary thyroid carcinoma. Archives of Otolaryngology -- Head & Neck Surgery 2009. p. 1087-91.PMID: 19917919. KQ4e2b, KQ5e3a19917919