# Appendix B Ongoing Studies

We searched selected grey literature sources, including ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP), for ongoing trials. From these sources no screening focused studies were identified. Multiple studies found focus on the effectiveness of surgery in people with low risk papillary carcinomas. The majority of these focus on people with low-risk papillary thyroid cancer or microcarcinomas of the thyroid. There are two randomized trials addressing efficacy and safety of prophylactic central lymph node dissection, both of which are still in the recruiting phase; the South Korean based study is expected to be completed in 2022^155^and the U.S. based study is expected to be completed in 2020.^156^ Outcomes will include harms of surgery. For papillary microcarcinomas there are three ongoing studies that would contribute to the evidence around overdiagnosis or harms of treatment. Two studies from South Korea on the comparative effectiveness of surgical treatment of papillary microcarcinomas may report the harms.^157, 158^ Another study will evaluate why patients with papillary microcarcinoma choose treatement versus active surveillance.^159^