# Appendix A Search Strategy

Databases searched:

OVID MEDLINE

PubMed, publisher-supplied

Cochrane Central Register of Controlled Trials (CENTRAL)

Key:

- / = MeSH subject heading
- ? = wildcard
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- adj# = adjacent within # number of words
- fs = floating subheading
- us = ultrasonography
- dt = drug therapy
- rt = radiotherapy
- su = surgery
- th = therapy

MEDLINE

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) <1946 to Present>, Ovid MEDLINE(R) Daily Update <January 12, 2016>

Search Strategy:

--------------------------------------------------------------------------------------

1. Thyroid Neoplasms/
2. Thyroid Nodule/
3. Thyroid Carcinoma, Anaplastic/
4. Carcinoma/
5. Carcinoma, Papillary/
6. Carcinoma, Medullary/
7. Carcinoma, Papillary, Follicular/
8. Adenocarcinoma, Follicular/
9. Adenocarcinoma, Papillary/
10. Adenocarcinoma/
11. Thyroid Gland/
12. 11 and (4 or 5 or 6 or 7 or 8 or 8 or 10)
13. (thyroid adj3 (cancer* or carcinoma* or adenoma* or nodule* or tumo?r* or neoplasm* or lymphoma* or adenocarcinoma* or sarcoma* or papillar* or follicular* or hurthle* or oxyphil* or medullar* or anaplast* or malignan*)).ti.
14. 1 or 2 or 3 or 12 or 13
15. Ultrasonography/
16. Elasticity Imaging Techniques/
17. Elasticity/
18. Mass Screening/
19. Multiphasic Screening/
20. “Early Detection of Cancer”/
21. early diagnosis/
22. Palpation/
23. Population Surveillance/
24. Sentinel Surveillance/
25. (screen* or surveil*).ti,ab.
26. (test* or exam* or detect* or predict* or identif* or discover* or diagnos*).ti.
27. case finding.ti,ab.
28. ultrasound*.ti,ab.
29. ultrasonograph*.ti,ab.
30. elastogra*.ti,ab.
31. echotomograph*.ti,ab.
32. echograph*.ti,ab.
33. ultrasonic*.ti,ab.
34. sonograph*.ti,ab.
35. sonogram*.ti,ab.
36. (palpat* or palpab*).ti,ab.
37. Thyroid Neoplasms/us [Ultrasonography]
38. Thyroid Nodule/us [Ultrasonography]
39. Carcinoma/us [Ultrasonography]
40. Carcinoma, Papillary/us [Ultrasonography]
41. Carcinoma, Medullary/us [Ultrasonography]
42. Carcinoma, Papillary, Follicular/us [Ultrasonography]
43. Adenocarcinoma, Follicular/us [Ultrasonography]
44. Adenocarcinoma, Papillary/us [Ultrasonography]
45. Adenocarcinoma/us [Ultrasonography]
46. 37 or 38
47. 11 and (39 or 40 or 41 or 42 or 43 or 44 or 45)
48. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
49. Clinical Trials as Topic/
50. Controlled Clinical Trials as Topic/
51. Randomized Controlled Trials as Topic/
52. Meta-Analysis as Topic/
53. Control Groups/
54. Double-Blind Method/
55. Single-Blind Method/
56. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
57. random*.ti,ab.
58. clinical trial*.ti,ab.
59. controlled trial*.ti,ab.
60. meta analy*.ti,ab.
61. 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60
62. (14 and 48) or 46 or 47
63. 61 and 62
64. remove duplicates from 63
65. “Sensitivity and Specificity”/
66. “Predictive Value of Tests”/
67. ROC Curve/
68. False Negative Reactions/
69. False Positive Reactions/
70. Diagnostic Errors/
71. “Reproducibility of Results”/
72. Reference Values/
73. Reference Standards/
74. Observer Variation/
75. receiver operat*.ti,ab.
76. roc curv*.ti,ab.
77. sensitivit*.ti,ab.
78. specificit*.ti,ab.
79. predictive value.ti,ab.
80. accuracy.ti,ab.
81. false positive*.ti,ab.
82. false negative*.ti,ab.
83. miss rate*.ti,ab.
84. error rate*.ti,ab.
85. 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84
86. (14 and 48) or 46 or 47
87. 85 and 86
88. remove duplicates from 87
89. Mortality/
90. Morbidity/
91. Death/
92. “Drug-Related Side Effects and Adverse Reactions”/
93. Fatal Outcome/
94. “Quality of Life”/
95. Stress, Psychological/
96. Anxiety/
97. Reoperation/
98. Recurrence/
99. Neoplasm Recurrence, Local/
100. Hypocalcemia/
101. Voice Disorders/
102. Voice Quality/
103. Voice/ (6278)
104. Hypesthesia/
105. safety.ti,ab.
106. harm*.ti,ab.
107. mortality.ti,ab.
108. complication*.ti,ab.
109. (death or deaths or die or dying).ti,ab.
110. (adverse adj2 (interaction* or response* or effect* or event* or reaction* or outcome* or feature*)).ti,ab.
111. adverse effects.fs.
112. mortality.fs.
113. overdiagnos*.ti,ab.
114. over diagnos*.ti,ab.
115. unnecessary exam*.ti,ab.
116. unnecessary procedure*.ti,ab.
117. unnecessary test*.ti,ab.
118. unneeded exam*.ti,ab.
119. unneeded procedure*.ti,ab.
120. unneeded test*.ti,ab.
121. unneeded surger*.ti,ab.
122. unnecessary surger*.ti,ab.
123. reoperation*.ti,ab.
124. recur*.ti,ab.
125. overtreat*.ti,ab.
126. over treat*.ti,ab.
127. (secondary adj3 malignan*).ti,ab.
128. psychosocial*.ti,ab.
129. (anxiet* or anxious* or distress* or nervous*).ti,ab.
130. (burden* or challenge*).ti,ab.
131. side effect*.ti,ab.
132. hypocalcem*.ti,ab.
133. hypocalcaem*.ti,ab.
134. voice.ti,ab.
135. numb*.ti,ab.
136. hypesthes*.ti,ab.
137. incidence/
138. Time Factors/
139. Prognosis/
140. Autopsy/
141. (incidence or prognos* or natural histor* or autopsy or autopsies).ti,ab.
142. ((time or temporal) adj3 trend*).ti,ab.
143. 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 or 142
144. Clinical Trials as Topic/
145. Controlled Clinical Trials as Topic/
146. Randomized Controlled Trials as Topic/
147. Meta-Analysis as Topic/
148. Control Groups/
149. Double-Blind Method/
150. Single-Blind Method/
151. Cohort Studies/
152. Longitudinal Studies/
153. Follow-Up Studies/
154. Prospective Studies/
155. Retrospective Studies/
156. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
157. random*.ti,ab.
158. clinical trial*.ti,ab.
159. controlled trial*.ti,ab.
160. meta analy*.ti,ab.
161. cohort.ti,ab.
162. longitudinal.ti,ab.
163. (follow up or followup).ti,ab.
164. case-control studies/
165. (case adj2 (control* or base* or comparison* or referrent or referent or compeer*)).ti,ab.
166. 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156 or 157 or 158 or 159 or 160 or 161 or 162 or 163 or 164 or 165
167. (14 and 48) or 46 or 47
168. 143 and 166 and 167
169. remove duplicates from 168
170. Thyroidectomy/
171. Lymph Node Excision/
172. Neck Dissection/
173. Iodine Radioisotopes/
174. Iodine Isotopes/
175. surgery.ti,ab.
176. surgical.ti,ab.
177. treat*.ti.
178. thyroidect*.ti,ab.
179. lobect*.ti,ab.
180. ((thyroid or neck or lymph) adj3 (remov* or dissect* or excis* or extract*)).ti,ab.
181. lymphadenect*.ti,ab.
182. radioactive iodin*.ti,ab.
183. radioiodin*.ti,ab.
184. radio iodin*.ti,ab.
185. radio nuclide*.ti,ab.
186. radionuclide*.ti,ab.
187. (iodine adj2 ablat*).ti,ab.
188. i-131.ti,ab.
189. 131-i.ti,ab.
190. Thyroid Neoplasms/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
191. Thyroid Nodule/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
192. Thyroid Carcinoma, Anaplastic/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
193. Carcinoma/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
194. Carcinoma, Papillary/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
195. Carcinoma, Medullary/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
196. Carcinoma, Papillary, Follicular/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
197. Adenocarcinoma, Follicular/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
198. Adenocarcinoma, Papillary/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
199. Adenocarcinoma/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
200. 190 or 191 or 192
201. 11 and (193 or 194 or 195 or 196 or 197 or 198 or 199)
202. 170 or 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181 or 182 or 183 or 184 or 185 or 186 or 187 or 188 or 189
203. 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156 or 157 or 158 or 159 or 160 or 161 or 162 or 163
204. (14 and 202) or 200 or 201
205. 203 and 204
206. (14 and 202) or 200 or 201
207. 143 and 166 and 206
208. 64 or 88 or 169 or 205 or 207
209. limit 208 to yr=“1966 -Current”
210. limit 209 to english language
211. animals/ not (humans/ and animals/)
212. 210 not 211

PubMed [publisher supplied references only]

Search | Query
#44 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #41 AND #42 AND #43
#43 (http://www.ncbi.nlm.nih.gov/pubmed) | Search English[language]
#42 (http://www.ncbi.nlm.nih.gov/pubmed) | Search publisher[sb]
#41 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #18 OR #40
#40 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #39
#39 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #19 OR #20 OR # 21 OR #22 OR #23 OR #26 OR # 27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38
#38 (http://www.ncbi.nlm.nih.gov/pubmed) | Search iodine radio isotope*[tiab]
#37 (http://www.ncbi.nlm.nih.gov/pubmed) | Search iodine radioisotope*[tiab]
#36 (http://www.ncbi.nlm.nih.gov/pubmed) | Search iodine isotope*[tiab]
#35 (http://www.ncbi.nlm.nih.gov/pubmed) | Search 131 I[tiab]
#34 (http://www.ncbi.nlm.nih.gov/pubmed) | Search I 131[tiab]
#33 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ablat*[ti]
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search radionuclide*[tiab]
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search radio nuclide*[tiab]
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search radio iodin*[tiab]
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search radioiodin*[tiab]
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search radioactive iodin*[tiab]
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search lymphadenect*[tiab]
#26 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #24 AND #25
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search remov*[ti] OR dissect*[ti] OR excis*[ti] OR extract*[ti]
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search thyroid[ti] OR neck[ti] OR lymph[ti]
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search lobect*[tiab]
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search thyroidect*[tiab]
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search treat*[ti]
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search surgical[tiab]
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search surger*[tiab]
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #17
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search elastic imag*[tiab]
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search palpat*[tiab] or palpab*[tiab]
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search sonogram*[tiab]
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search sonograph*[tiab]
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ultrasonic*[tiab]
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search echograph*[tiab]
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search echotomograph*[tiab]
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search elastogra*[tiab]
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ultrasonograph*[tiab]
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ultrasound*[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search case finding*[tiab]
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search test*[ti] OR exam*[ti] OR detect*[ti] OR predict*[ti] OR identif*[ti] OR discover*[ti] OR diagnos*[ti]
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search screen*[tiab] OR surveil*[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search cancer*[ti] OR carcinoma*[ti] OR adenoma*[ti] OR nodule*[ti] OR tumor*[ti] OR tumour*[ti] OR neoplasm*[ti] OR lymphoma*[ti] OR adenocarcinoma*[ti] OR sarcoma*[ti] OR papillar*[ti] OR follicular*[ti] OR hurthle*[ti] OR oxyphil*[ti] OR medullar*[ti] OR anaplast*[ti] OR malignan*[ti]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search thyroid[ti]

Cochrane Central Register of Controlled Clinical Trials (CENTRAL)

#1 (thyroid):ti,ab,kw near/3 (cancer* or carcinoma* or adenoma* or nodule* or tumo?r* or neoplasm* or lymphoma* or adenocarcinoma* or sarcoma* or papillar* or follicular* or hurthle* or oxyphil* or medullar* or anaplast* or malignan*):ti,ab,kw
#2 (screen* or surveil*):ti,ab,kw
#3 (test* or exam* or detect* or predict* or identif* or discover* or diagnos*):ti
#4 “case finding”:ti,ab,kw
#5 ultrasound*:ti,ab,kw
#6 ultrasonograph*:ti,ab,kw
#7 elastogra*:ti,ab,kw
#8 echotomograph*:ti,ab,kw
#9 echograph*:ti,ab,kw
#10 ultrasonic*:ti,ab,kw
#11 sonograph*:ti,ab,kw
#12 sonogram*:ti,ab,kw
#13 (palpat* or palpab*):ti,ab,kw
#14 (elasti*):ti,ab,kw near/3 (image or imaging):ti,ab,kw
#15 #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14
#16 #1 and #15
#17 “receiver operat*”:ti,ab,kw
#18 “roc curv*”:ti,ab,kw
#19 sensitivit*:ti,ab,kw
#20 specificit*:ti,ab,kw
#21 “predictive value*”:ti,ab,kw
#22 accuracy:ti,ab,kw
#23 “false positive*”:ti,ab,kw
#24 “false negative*”:ti,ab,kw
#25 “miss rate*”:ti,ab,kw
#26 “error rate*”:ti,ab,kw
#27 reference near/3 standard*:ti,ab,kw
#28 reference near/3 value*:ti,ab,kw
#29 “observer variation*”:ti,ab,kw
#30 #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 58443
#31 #16 and #30
#32 safety:ti,ab,kw
#33 harm*:ti,ab,kw
#34 mortality:ti,ab,kw
#35 complication*:ti,ab,kw
#36 (death or deaths or die or dying or fatal*):ti,ab,kw
#37 adverse:ti,ab,kw near/2 (interaction* or response* or effect* or event* or reaction* or outcome* or feature*):ti,ab,kw
#38 overdiagnos*:ti,ab,kw
#39 “over diagnos*”:ti,ab,kw
#40 “unnecessary exam*”:ti,ab,kw
#41 “unnecessary procedure*”:ti,ab,kw
#42 “unnecessary test*”:ti,ab,kw
#43 “unneeded exam*”:ti,ab,kw
#44 “unneeded procedure*”:ti,ab,kw
#45 “unneeded test*”:ti,ab,kw
#46 “unneeded surger*”:ti,ab,kw
#47 “unnecessary surger*”:ti,ab,kw
#48 reoperation*:ti,ab,kw
#49 recur*:ti,ab,kw
#50 overtreat*:ti,ab,kw
#51 “over treat*”:ti,ab,kw
#52 (secondary near/3 malignan*):ti,ab,kw
#53 psychosocial*:ti,ab,kw
#54 (anxiet* or anxious* or distress* or nervous*):ti,ab,kw
#55 (burden* or challenge*):ti,ab,kw
#56 “side effect*”:ti,ab,kw
#57 hypocalcem*:ti,ab,kw
#58 hypocalcaem*:ti,ab,kw
#59 voice:ti,ab,kw
#60 numb*:ti,ab,kw
#61 hypesthes*:ti,ab,kw
#62 (incidence or prognos* or “natural histor*” or autopsy or autopsies):ti,ab,kw
#63 (time or temporal):ti,ab,kw near/3 (trend* or factor*):ti,ab,kw
#64 morbidit*:ti,ab,kw
#65 “quality of life”:ti,ab,kw
#66 #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 or #55 or #56 or #57 or #58 or #59 or #60 or #61 or #62 or #63 or #64 or #65
#67 #16 and #66
#68 (surger* or surgical):ti,ab,kw
#69 treat*:ti
#70 thyroidect*:ti,ab,kw
#71 lobect*:ti,ab,kw
#72 (thyroid or neck or lymph*):ti,ab,kw near/3 (remov* or dissect* or excis* or extract*):ti,ab,kw 1757
#73 lymphadenect*:ti,ab,kw
#74 “radioactive iodin*”:ti,ab,kw
#75 radioiodin*:ti,ab,kw
#76 “radio iodin*”:ti,ab,kw
#77 iodin*:ti,ab,kw near/3 (isotope* or radioisotope* or “radio isotope*”):ti,ab,kw
#78 “radio nuclide*”:ti,ab,kw
#79 radionuclide*:ti,ab,kw
#80 (iodine near/2 ablat*):ti,ab,kw
#81 “i-131”:ti,ab,kw
#82 “131-i”:ti,ab,kw
#83 #68 or #69 or #70 or #71 or #72 or #73 or #74 or #75 or #76 or #77 or #78 or #79 or #80 or #81 or #82
#84 #1 and #83
#85 #1 and #83 and #66
#86 #16 or #31 or #67 or #84 or #85 in Trials

Appendix A Table 1 Quality Assessment Criteria

Study Design | Quality Criteria
Randomized controlled trials USPSTF methods^49^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid, and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^50^ | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid, and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?
Diagnostic accuracy studies adapted from QUADAS I and II ^51, 52^ | - Screening test relevant, available for primary care, and adequately described; - Study uses a credible reference standard performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate results in a reasonable manner; - Spectrum of patients included in study; - Sample size reported; - Administration of reliable screening test

Abbreviations: USPSTF=U.S. Preventive Services Task Force; QUADAS=Quality Assessment of Diagnostic Accuracy Studies.

Appendix A Table 2 Inclusion and Exclusion Criteria

| Include | Exclude
Populations | - Asymptomatic adults age ≥18 years; - High-risk populations (those with a history of radiation exposure or family history of thyroid cancer) | - Persons who are already under surveillance for thyroid cancer because of previous thyroid cancer; - Persons who have symptoms that may lead to thyroid evaluation; - Persons with known inherited genetic syndromes, such as multiple endocrine neoplasia type II, as selection criteria for studies; - Persons with thyroid disease; - Children and adolescents
Screening tests | KQs 1–3: Palpation or ultrasound of the neck conducted by primary care providers or specialists as part of a routine well care visit | - Enhanced ultrasound methods, such as elastography or ultrasound with contrast media; - Diagnostic procedures (e.g., fine needle aspiration) will be excluded as screening tests but reviewed under harms of screening; - Other imaging tests (e.g., magnetic resonance imaging, positron emission tomography) that incidentally identify thyroid nodules; - Blood tests (e.g., calcitonin, thyroid-stimulating hormone); - Self-examination; - Diagnostic accuracy studies in persons with known nodules
Treatment interventions | KQs 4, 5: Surgery, including lobectomy, near-total thyroidectomy, total thyroidectomy, and lymphadenectomy; radioactive iodine ablation | - Chemotherapy; - External beam radiation therapy; - Nonsurgical ablative treatment, such as thermal ablation, radiofrequency ablation, or ultrasound-guided percutaneous ethanol injection; - Older treatment studies pre-1990
Comparisons | KQs 1–3: No screening KQs 4, 5: No treatment
Outcomes | KQs 1, 4: Reduced morbidity associated with any thyroid cancer (including papillary, follicular, medullary, and anaplastic), including:; - Improved quality of life; - Decreased thyroid cancer mortality; - Decreased all-cause mortality; KQ 2: Sensitivity, specificity, positive predictive value, false-positives, false-negatives, nodule detection rates, and cancer detection rates KQs 3, 5: Any harm from screening or treatment, including overdiagnosis,^*^ diagnostic tests, overtreatment,^**^ psychosocial harms, secondary malignancies, or procedure-related adverse events | Incidentally identified thyroid nodules
Settings | - U.S. primary care settings; - Nations categorized as “High” on the Human Development Index (as defined by the World Health Organization) | Nations with environmental disasters that lead to very high radiation exposure (e.g., Ukraine, Japan)
Study designs | Fair- to good-quality studies published between January 1, 1966 and March 31, 2015 KQ 1: Randomized, controlled trials KQ 2: Diagnostic accuracy studies with a reference standard, systematic evidence reviews KQs 3, 5: Randomized, controlled trials; controlled clinical trials; cohort studies; case-control studies KQ 4: Randomized, controlled trials; controlled clinical trials; cohort studies | Poor-quality studies with a fatal flaw; studies outside of the publication window; case reports and case series; decision analyses

* Diagnosis of nonpalpable nodules measuring <1 cm and/or fine needle aspiration of nodules not meeting revised 2009 American Thyroid Association criteria for fine needle aspiration.

** Including treatment of an overdiagnosed nodule and extended followup of benign nodules.

Appendix A Figure 1 Literature Flow Diagram

Abbreviation: KQ=key question.

Appendix Figure 1 is a flow chart that summarizes the search and selection of articles. There were 11,687 citations identified through literature databases. An additional 178 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 10,424 unique citations were screened at the title/abstract stage. The full text of 707 citations were examined for inclusion for one or more of the eight Key Questions, or for contextual questions.