# References

1 Barlow SE. Expert committee recommendations regarding the prevention, assessment, and treatment of child and adolescent overweight and obesity: summary report. Pediatrics. 2007;120 Suppl 4:S164–S92. PMID: 18055651.18055651
2 Nassis GP, Sidossis LS. Methods for assessing body composition, cardiovascular and metabolic function in children and adolescents: implications for exercise studies. Curr Opin Clin Nutr Metab Care. 2006;9(5):560–7. PMID: 16912551.16912551
3 Kuczmarski R, Ogden C, Guo S, . 2000 CDC Growth Charts for the United States: methods and development. Vital Health Stat 11. 2002;246:1–190. PMID: 12043359.12043359
4 Cole TJ, Bellizzi MC, Flegal KM, . Establishing a standard definition for child overweight and obesity worldwide: international survey. BMJ. 2000;320(7244):1240–3. PMID: 10797032.10797032
5 Cole TJ, Freeman JV, Preece MA. Body mass index reference curves for the UK, 1990. Arch Dis Child. 1995;73(1):25–9. PMID: 7639544.7639544
6 Rosner B, Prineas R, Loggie J, . Percentiles for body mass index in U.S. children 5 to 17 years of age. J Pediatr. 1998;132(2):211–22. PMID: 9506630.9506630
7 Kromeyer-Hauschild K, Wabitsch M, Kunze D, . Perzentile für den Body-mass-Index für das Kindes- und Jugendalter unter Heranziehung verschiedener deutscher Stichproben. Monatsschrift Kinderheilkunde. 2001;149(8):807–18.
8 Kelly AS, Barlow SE, Rao G, . Severe obesity in children and adolescents: identification, associated health risks, and treatment approaches: a scientific statement from the American Heart Association. Circulation. 2013;128(15):1689–712. PMID: 24016455.24016455
9 Pedrosa C, Correia F, Seabra D, . Prevalence of overweight and obesity among 7–9-year-old children in Aveiro, Portugal: comparison between IOTF and CDC references. Public Health Nutr. 2011;14(1):14–9. PMID: 19825211.19825211
10 Krakauer NY, Krakauer JC. A new body shape index predicts mortality hazard independently of body mass index. PLoS One. 2012;7(7):e39504. PMID: 22815707.22815707
11 Krakauer NY, Krakauer JC. An Anthropometric Risk Index Based on Combining Height, Weight, Waist, and Hip Measurements. J Obes. 2016;2016:8094275. PMID: 27830087.27830087
12 Thomson CA, Garcia DO, Wertheim BC, . Body shape, adiposity index, and mortality in postmenopausal women: Findings from the Women’s Health Initiative. Obesity (Silver Spring). 2016;24(5):1061–9. PMID: 26991923.26991923
13 Krakauer NY, Krakauer JC. Dynamic association of mortality hazard with body shape. PLoS One. 2014;9(2):e88793. PMID: 24586394.24586394
14 Xu Y, Yan W, Cheung YB. Body shape indices and cardiometabolic risk in adolescents. Ann Hum Biol. 2015;42(1):70–5. PMID: 24734976.24734976
15 Duncan MJ, Mota J, Vale S, . Associations between body mass index, waist circumference and body shape index with resting blood pressure in Portuguese adolescents. Ann Hum Biol. 2013;40(2):163–7. PMID: 23327095.23327095
16 Ogden CL, Carroll MD, Kit BK, . Prevalence of childhood and adult obesity in the United States, 2011–2012. JAMA. 2014;311(8):806–14. PMID: 24570244.24570244
17 Skinner AC, Skelton JA. Prevalence and trends in obesity and severe obesity among children in the United States, 1999–2012. JAMA Pediatr. 2014. PMID: 24710576.24710576
18 Dietz WH, Economos CD. Progress in the control of childhood obesity. Pediatrics. 2015;135(3):e559–61. PMID: 25667238.25667238
19 Whitlock EP, Williams SB, Gold R, . Screening and interventions for childhood overweight: a summary of evidence for the US Preventive Services Task Force. Pediatrics. 2005;116(1):e125–e44. PMID: 15995013.15995013
20 Simmonds M, Burch J, Llewellyn A, . The use of measures of obesity in childhood for predicting obesity and the development of obesity-related diseases in adulthood: a systematic review and meta-analysis. Health Technol Assess. 2015;19(43):1–336. PMID: 26108433.26108433
21 Park MH, Sovio U, Viner RM, . Overweight in childhood, adolescence and adulthood and cardiovascular risk in later life: pooled analysis of three british birth cohorts. PLOS ONE. 2013;8(7):e70684. PMID: 23894679.23894679
22 Friedemann C, Heneghan C, Mahtani K, . Cardiovascular disease risk in healthy children and its association with body mass index: systematic review and meta-analysis. BMJ. 2012;345:e4759. PMID: 23015032.23015032
23 Silveira LS, Monteiro PA, Antunes BM, . Intra-abdominal fat is related to metabolic syndrome and non-alcoholic fat liver disease in obese youth. BMC Pediatr. 2013;13:115. PMID: 2391959223919592
24 Skinner AC, Perrin EM, Moss LA, . Cardiometabolic risks and severity of obesity in children and young adults. N Engl J Med. 2015;373(14):1307–17. PMID: 26422721.26422721
25 Bocca G, Ongering EC, Stolk RP, . Insulin resistance and cardiovascular risk factors in 3- to 5-year-old overweight or obese children. Horm Res Paediatr. 2013;80(3):201–6. PMID: 24051674.24051674
26 May AL, Kuklina EV, Yoon PW. Prevalence of cardiovascular disease risk factors among US adolescents, 1999–2008. Pediatrics. 2012;129(6):1035–41. PMID: 22614778.22614778
27 Pecin I, Samovojska R, Heinrich B, . Hypertension, overweight and obesity in adolescents: the CRO-KOP study. Coll Antropol. 2013;37(3):761–4. PMID: 24308213.24308213
28 Mazor-Aronovitch K, Lotan D, Modan-Moses D, . Blood pressure in obese and overweight children and adolescents. Isr Med Assoc J. 2014;16(3):157–61. PMID: 24761703.24761703
29 Ayer J, Charakida M, Deanfield JE, . Lifetime risk: childhood obesity and cardiovascular risk. Eur Heart J. 2015;36(22):1371–6. PMID: 25810456.25810456
30 Egan KB, Ettinger AS, Bracken MB. Childhood body mass index and subsequent physician-diagnosed asthma: a systematic review and meta-analysis of prospective cohort studies. BMC Pediatr. 2013;13(1):121. PMID: 23941287.23941287
31 Bell LM, Byrne S, Thompson A, . Increasing body mass index z-score is continuously associated with complications of overweight in children, even in the healthy weight range. J Clin Endocrinol Metab. 2007;92(2):517–22. PMID: 17105842.17105842
32 Ul-Haq Z, Mackay DF, Fenwick E, . Meta-analysis of the association between body mass index and health-related quality of life among children and adolescents, assessed using the Pediatric Quality of Life Inventory Index. J Pediatr. 2013;162(2):280–6. PMID: 22959137.22959137
33 Griffiths LJ, Parsons TJ, Hill AJ. Self-esteem and quality of life in obese children and adolescents: A systematic review. Int J Pediatr Obes. 2010;5(4):282–304. PMID: 20210677.20210677
34 Trevino RP, Pham TH, Edelstein SL. Obesity and preference-weighted quality of life of ethnically diverse middle school children: the HEALTHY study. J Obes. 2013;2013:206074. PMID: 23853717.23853717
35 Puhl RM, Luedicke J, Heuer C. Weight-Based Victimization toward Overweight Adolescents: Observations and Reactions of Peers. Journal of School Health. 2011;81(11):696–703. PMID: 21972990.21972990
36 Jansen PW, Verlinden M, Dommisse-van Berkel A, . Teacher and peer reports of overweight and bullying among young primary school children. Pediatrics. 2014;134(3):473–80. PMID: 25157018.25157018
37 van Geel M, Vedder P, Tanilon J. Are overweight and obese youths more often bullied by their peers? A meta-analysis on the correlation between weight status and bullying. Int J Obes (Lond). 2014;38(10):1263–7. PMID: 25002148.25002148
38 Swallen KC, Reither EN, Haas SA, . Overweight, obesity, and health-related quality of life among adolescents: the National Longitudinal Study of Adolescent Health. Pediatrics. 2005;115(2):340–7. PMID: 15687442.15687442
39 Smith E, Sweeting H, Wright C. ‘Do I care?’ Young adults’ recalled experiences of early adolescent overweight and obesity: a qualitative study. Int J Obes (Lond). 2013;37(2):303–8. PMID: 22450852.22450852
40 Park MH, Falconer C, Viner RM, . The impact of childhood obesity on morbidity and mortality in adulthood: a systematic review. Obes Rev. 2012;13(11):985–1000. PMID: 22731928.22731928
41 Lloyd LJ, Langley-Evans SC, McMullen S. Childhood obesity and risk of the adult metabolic syndrome: a systematic review. Int J Obes (Lond). 2012;36(1):1–11. PMID: 22041985.22041985
42 Owen CG, Whincup PH, Orfei L, . Is body mass index before middle age related to coronary heart disease risk in later life? Evidence from observational studies. Int J Obes (Lond). 2009;33(8):866–77. PMID: 19506565.19506565
43 Reilly JJ, Kelly J. Long-term impact of overweight and obesity in childhood and adolescence on morbidity and premature mortality in adulthood: systematic review. Int J Obes (Lond). 2011;35(7):891–8. PMID: 20975725.20975725
44 Tailor AM, Peeters PHM, Norat T, . An update on the prevalence of the metabolic syndrome in children and adolescents. Int J Obes. 2010;5(3):202–13. PMID: 19878092.19878092
45 Su TC, Liao CC, Chien KL, . An overweight or obese status in childhood predicts subclinical atherosclerosis and prehypertension/hypertension in young adults. J Atheroscler Thromb. 2014;21(11):1170–82. PMID: 25030049.25030049
46 Sundaram ME, Berg RL, Economos C, . The relationship between childhood BMI and adult serum cholesterol, LDL, and ankle brachial index. Clin. 2014;12(1–2):33–9. PMID: 24415747.24415747
47 Cook MB, Freedman ND, Gamborg M, . Childhood body mass index in relation to future risk of oesophageal adenocarcinoma. Br J Cancer. 2015;112(3):601–7. PMID: 25562436.25562436
48 Twig G, Yaniv G, Levine H, . Body-Mass Index in 2.3 Million Adolescents and Cardiovascular Death in Adulthood. N Engl J Med. 2016. PMID: 27074389.27074389
49 Juonala M, Magnussen CG, Berenson GS, . Childhood adiposity, adult adiposity, and cardiovascular risk factors. N Engl J Med. 2011;365(20):1876–85. PMID: 22087679.22087679
50 Schuster DP. Changes in physiology with increasing fat mass. Semin Pediatr Surg. 2009;18(3):126–35. PMID: 19573754.19573754
51 Nan C, Guo B, Warner C, . Heritability of body mass index in pre-adolescence, young adulthood and late adulthood. Eur J Epidemiol. 2012;27(4):247–53. PMID: 22426805.22426805
52 Centers for Disease Control and Prevention. A Growing Problem. http://www.cdc.gov/obesity/childhood/problem.html. Accessed 3/17/2017, 2017.
53 Wells JC. The evolution of human adiposity and obesity: where did it all go wrong? Dis Model Mech. 2012;5(5):595–607. PMID: 22915021.22915021
54 Keith SW, Redden DT, Katzmarzyk PT, . Putative contributors to the secular increase in obesity: exploring the roads less traveled. Int J Obes (Lond). 2006;30(11):1585–94. PMID: 16801930.16801930
55 Cunningham SA, Kramer MR, Narayan KM. Incidence of childhood obesity in the United States. N Engl J Med. 2014;370(5):403–11. PMID: 24476431.24476431
56 Bayer O, Kruger H, von KR, . Factors associated with tracking of BMI: a meta-regression analysis on BMI tracking. Obesity (Silver Spring). 2011;19(5):1069–76. PMID: 20948517.20948517
57 Leibel RL, Rosenbaum M, Hirsch J. Changes in energy expenditure resulting from altered body weight. N Engl J Med. 1995;332(10):621–8. PMID: 7632212.7632212
58 Rosenbaum M, Kissileff HR, Mayer LE, . Energy intake in weight-reduced humans. Brain Res. 2010;1350:95–102. PMID: 20595050.20595050
59 Waters L, George AS, Chey T, . Weight change in control group participants in behavioural weight loss interventions: a systematic review and meta-regression study. BMC Med Res Methodol. 2012;12:120. PMID: 22873682.22873682
60 Reilly JJ, Armstrong J, Dorosty AR, . Early life risk factors for obesity in childhood: cohort study. BMJ. 2005;330(7504):1357. PMID: 15908441.15908441
61 Bammann K, Peplies J, De HS, . Early life course risk factors for childhood obesity: the IDEFICS case-control study. PLoS ONE. 2014;9(2):e86914. PMID: 24551043.24551043
62 Chivers P, Parker H, Bulsara M, . Parental and early childhood influences on adolescent obesity: a longitudinal study. Early Child Dev Care. 2012;182(8):1071–87.
63 Costa-Font J, Jofre-Bonet M, Le Grand J. Vertical transmission of overweight: evidence from english adoptees. CEP Discussion Paper No 1324. London: Centre for Economic Performance & London School of Economics and Political Science; 2015.
64 Riddoch CJ, Leary SD, Ness AR, . Prospective associations between objective measures of physical activity and fat mass in 12–14 year old children: the Avon Longitudinal Study of Parents and Children (ALSPAC). BMJ. 2009;339:b4544. PMID: 19942665.19942665
65 Te ML, Mallard S, Mann J. Dietary sugars and body weight: systematic review and meta-analyses of randomised controlled trials and cohort studies. BMJ. 2012;346:e7492. PMID: 2332148623321486
66 Cox R, Skouteris H, Rutherford L, . The association between television viewing and preschool child body mass index: A systematic review of English papers published from 1995 to 2010. J Child Media. 2012;6(2):198–220.
67 Tremblay MS, LeBlanc AG, Kho ME, . Systematic review of sedentary behaviour and health indicators in school-aged children and youth. Int J Behav Nutr Phys Act. 2011;8:98. PMID: 21936895.21936895
68 Fatima Y, Doi SA, Mamun AA. Longitudinal impact of sleep on overweight and obesity in children and adolescents: a systematic review and bias-adjusted meta-analysis. Obes Rev. 2015;16(2):137–49. PMID: 25589359.25589359
69 Tanofsky-Kraff M, Cohen ML, Yanovski SZ, . A prospective study of psychological predictors of body fat gain among children at high risk for adult obesity. Pediatrics. 2006;117(4):1203–9. PMID: 16585316.16585316
70 Tamayo T, Christian H, Rathmann W. Impact of early psychosocial factors (childhood socioeconomic factors and adversities) on future risk of type 2 diabetes, metabolic disturbances and obesity: a systematic review. BMC Public Health. 2010;10:525. PMID: 20809937.20809937
71 Nau C, Schwartz BS, Bandeen-Roche K, . Community socioeconomic deprivation and obesity trajectories in children using electronic health records. Obesity. 2015;23(1):207–12. PMID: 25324223.25324223
72 Hoyt LT, Kushi LH, Leung CW, . Neighborhood influences on girls’ obesity risk across the transition to adolescence. Pediatrics. 2014;134(5):942–9. PMID: 25311606.25311606
73 Anderson SE, Whitaker RC. Household routines and obesity in US preschool-aged children. Pediatrics. 2010;125(3):420–8. PMID: 20142280.20142280
74 Monasta L, Batty GD, Cattaneo A, . Early-life determinants of overweight and obesity: a review of systematic reviews. Obes Rev. 2010;11(10):695–708. PMID: 20331509.20331509
75 Weng SF, Redsell SA, Nathan D, . Estimating overweight risk in childhood from predictors during infancy. Pediatrics. 2013;132(2):e414–21. PMID: 23858427.23858427
76 Rossen LM. Neighbourhood economic deprivation explains racial/ethnic disparities in overweight and obesity among children and adolescents in the U.S.A. J Epidemiol Community Health. 2014;68(2):123–9. PMID: 24072744.24072744
77 Zilanawala A, Davis-Kean P, Nazroo J, . Race/ethnic disparities in early childhood BMI, obesity and overweight in the United Kingdom and United States. Int J Obes (Lond). 2015;39(3):520–9. PMID: 25219529.25219529
78 Taveras EM, Gillman MW, Kleinman K, . Racial/ethnic differences in early-life risk factors for childhood obesity. Pediatrics. 2010;125(4):686–95. PMID: 20194284.20194284
79 Flegal KM, Ogden CL, Yanovski JA, . High adiposity and high body mass index-for-age in US children and adolescents overall and by race-ethnic group. Am J Clin Nutr. 2010;91(4):1020–6. PMID: 20164313.20164313
80 Lear SA, Toma M, Birmingham CL, . Modification of the relationship between simple anthropometric indices and risk factors by ethnic background. Metabolism. 2003;52(10):1295–301. PMID: 14564681.14564681
81 Lundahl A, Kidwell KM, Nelson TD. Parental underestimates of child weight: a meta-analysis. Pediatrics. 2014;133(3):e689–703. PMID: 24488736.24488736
82 Krebs NF, Himes JH, Jacobson D, . Assessment of child and adolescent overweight and obesity. Pediatrics. 2007;120(Supplement 4):S193–S228. PMID: 1805565218055652
83 Fildes A, Charlton J, Rudisill C, . Probability of an obese person attaining normal body weight: cohort study using electronic health records. Am J Public Health. 2015:e1–e6. PMID: 26180980.26180980
84 Centers for Disease Control and Prevention. Growth charts. http://www.cdc.gov/growthcharts/. Accessed 2017.
85 Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents, National Heart L, and Blood Institute,. Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: summary report. Pediatrics. 2011;128:Suppl-56. PMID: 22084329.22084329
86 Javed A, Jumean M, Murad MH, . Diagnostic performance of body mass index to identify obesity as defined by body adiposity in children and adolescents: a systematic review and meta-analysis. Pediatr Obes. 2014. PMID: 24961794.24961794
87 National Institute of Diabetes and Digestive and Kidney Diseases. Bariatric surgery for severe obesity. Bethesda: National Institute of Health; 2011.
88 Michalsky M, Reichard K, Inge T, . ASMBS pediatric committee best practice guidelines. Surg Obes Relat Dis. 2012;8(1):1–7. PMID: 22030146.22030146
89 Hillman JB, Corathers SD, Wilson SE. Pediatricians and screening for obesity with body mass index: does level of training matter? Public Health Rep. 2009;124(4):561–7. PMID: 19618793.19618793
90 Arterburn DE, Alexander GL, Calvi J, . Body mass index measurement and obesity prevalence in ten U.S. health plans. Clin. 2010;8(3–4):126–30. PMID: 20682758.20682758
91 Coleman KJ, Hsii AC, Koebnick C, . Implementation of clinical practice guidelines for pediatric weight management. J Pediatr. 2012;160(6):918–22. PMID: 22240108.22240108
92 Flower KB, Perrin EM, Viadro CI, . Using body mass index to identify overweight children: barriers and facilitators in primary care. Ambul Pediatr. 2007;7(1):38–44. PMID: 17261481.17261481
93 Barlow SE, Bobra SR, Elliott MB, . Recognition of childhood overweight during health supervision visits: Does BMI help pediatricians? Obesity (Silver Spring). 2007;15(1):225–32. PMID: 17228051.17228051
94 O’Brien SH, Holubkov R, Reis EC. Identification, evaluation, and management of obesity in an academic primary care center. Pediatrics. 2004;114(2):e154–e9. PMID: 1528625115286251
95 Kant AK, Miner P. Physician advice about being overweight: association with self-reported weight loss, dietary, and physical activity behaviors of US adolescents in the National Health and Nutrition Examination Survey, 1999–2002. Pediatrics. 2007;119(1):e142–e7. PMID: 1720024117200241
96 Chelvakumar G, Levin L, Polfuss M, . Perception and documentation of weight management practices in pediatric primary care. WMJ. 2014;113(4):149–53; quiz 54. PMID: 25211802.25211802
97 Sharifi M, Rifas-Shiman SL, Marshall R, . Evaluating the implementation of expert committee recommendations for obesity assessment. Clin Pediatr (Phila). 2013;52(2):131–8. PMID: 23378479.23378479
98 Nader N, Singhal V, Javed A, . Temporal trends in the diagnosis and management of childhood obesity/overweight in primary care. Journal of primary care & community health. 2014;5(1):44–9. PMID: 24327587.24327587
99 Lenhart CM, Bauer KW, Patterson F. Weight status and weight-management behaviors among Philadelphia high school students, 2007–2011. Prev Chronic Dis. 2013;10:E164. PMID: 24070036.24070036
100 Majka A. Weight-control practices reported by students in a Maine middle school. J Ext. 2011;49.(2)
101 Kumanyika SK, Obarzanek E, Stettler N, . Population-based prevention of obesity: the need for comprehensive promotion of healthful eating, physical activity, and energy balance: a scientific statement from American Heart Association Council on Epidemiology and Prevention, Interdisciplinary Committee for Prevention (formerly the expert panel on population and prevention science). Circulation. 2008;118(4):428–64. PMID: 18591433.18591433
102 Keener D, Goodman K, Lowry A, . Recommended community strategies and measurements to prevent obesity in the United States: implementation and measurement guide. Atlanta, GA: Centers for Disease Control and Prevention; 2009.
103 National Committee for Quality Assurance (NCQA). HEDIS 2014: Healthcare Effectiveness Data and Information Set. Washington, DC: National Committee for Quality Assurance (NCQA); 2013.
104 US Preventive Services Task Force, Barton M. Screening for obesity in children and adolescents: US Preventive Services Task Force recommendation statement. Pediatrics. 2010;125(2):361–7. PMID: 20083515.20083515
105 Whitlock EP, O’Connor EA, Williams SB, . Effectiveness of weight management interventions in children: a targeted systematic review for the USPSTF. Pediatrics. 2010;125(2):e396–e418. PMID: 20083531.20083531
106 Whitlock EP, O’Connor EA, Williams SB, . Effectiveness of primary care interventions for weight management in children and adolescents: an updated, targeted systematic review for the USPSTF. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
107 Turner EH. How to access and process FDA drug approval packages for use in research. BMJ. 2013;347:f5992. PMID: 24126858.24126858
108 Yanovski J. Safety and efficacy of xenical in children and adolescents with obesity-related diseases. NCT00001723. https://clinicaltrials.gov/ct2/show/NCT00001723. Accessed 02/05/2016, 2017.
109 Organization for Economic Cooperation and Development. List of OECD Member countries - ratification of the convention of the OECD. http://www.oecd.org/about/membersandpartners/list-oecd-member-countries.htm. Accessed 2017.
110 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21–35. PMID: 11306229.11306229
111 Higgins JPT, Green Se. Cochrane handbook for systematic reviews of interventions: Cochrane Book Series. Higgins JPT, Green S, editors. Chichester, UK: John Wiley & Sons Ltd; 2008.
112 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–88. PMID: 3802833.3802833
113 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780.12939780
114 Harville DA. Maximum likelihood approaches to variance component estimation and to related problems. J Am Stat Assoc. 1977;72(358):320–38.
115 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619–29. PMID: 8731004.8731004
116 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919.12111919
117 Boudreau AD, Kurowski DS, Gonzalez WI, . Latino families, primary care, and childhood obesity: a randomized controlled trial. Am J Prev Med. 2013;44(3 Suppl 3):S247–57. PMID: 23415190.23415190
118 Boutelle KN, Zucker N, Peterson CB, . An intervention based on Schachter’s externality theory for overweight children: The Regulation of Cues pilot. J Pediatr Psychol. 2014;39(4):405–17. PMID: 24459240.24459240
119 Broccoli S, Davoli AM, Bonvicini L, . Motivational interviewing to treat overweight children: 24-month follow-up of a randomized controlled trial. Pediatrics. 2016;137(1):1–10. PMID: 26702030.26702030
120 Bryant M, Farrin A, Christie D, . Results of a feasibility randomised controlled trial (RCT) for WATCH IT: a programme for obese children and adolescents. Clin Trials. 2011;8(6):755–64. PMID: 22024104.22024104
121 Burgert TS, Duran EJ, Goldberg-Gell R, . Short-term metabolic and cardiovascular effects of metformin in markedly obese adolescents with normal glucose tolerance. Pediatr Diabetes. 2008;9(6):567–76. PMID: 18761646.18761646
122 Chanoine JP, Hampl S, Jensen C, . Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. JAMA. 2005;293(23):2873–83. PMID: 15956632.15956632
123 Clarson CL, Brown HK, Dejesus S, . Effects of a comprehensive, intensive lifestyle intervention combined with metformin extended release in obese adolescents. International Scholarly Research Notices. 2014;2014(659410):1. PMID: 27433488.27433488
124 Croker H, Viner RM, Nicholls D, . Family-based behavioural treatment of childhood obesity in a UK National Health Service setting: randomized controlled trial. Int J Obes (Lond). 2012;36(1):16–26. PMID: 21931327.21931327
125 Davis JN, Ventura EE, Tung A, . Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012;7(1):16–27. PMID: 22434736.22434736
126 DeBar LL, Stevens VJ, Perrin N, . A primary care-based, multicomponent lifestyle intervention for overweight adolescent females. Pediatrics. 2012;129(3):e611–20. PMID: 22331335.22331335
127 Evia-Viscarra ML, Rodea-Montero ER, Apolinar-Jimenez E, . The effects of metformin on inflammatory mediators in obese adolescents with insulin resistance: controlled randomized clinical trial. J Pediatr Endocrinol. 2012;25(1–2):41–9. PMID: 22570949.22570949
128 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 2001;107(4):E55. PMID: 11335776.11335776
129 Gerards SM, Dagnelie PC, Gubbels JS, . The effectiveness of lifestyle triple p in the Netherlands: a randomized controlled trial. PLoS One. 2015;10(4):e0122240. PMID: 25849523.25849523
130 Golley RK, Magarey AM, Baur LA, . Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: a randomized, controlled trial. Pediatrics. 2007;119(3):517–25. PMID: 17332205.17332205
131 Hofsteenge GH, Chinapaw MJ, Delemarre-van de Waal HA, . Long-term effect of the Go4it group treatment for obese adolescents: a randomised controlled trial. Clin Nutr. 2014;33(3):385–91. PMID: 23810626.23810626
132 Kalarchian MA, Levine MD, Arslanian SA, . Family-based treatment of severe pediatric obesity: randomized, controlled trial. Pediatrics. 2009;124(4):1060–8. PMID: 19786444.19786444
133 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31(10):1500–8. PMID: 17438555.17438555
134 Kay JP, Alemzadeh R, Langley G, . Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001;50(12):1457–61. PMID: 11735093.11735093
135 Kendall D, Vail A, Amin R, . Metformin in obese children and adolescents: the MOCA trial. J Clin Endocrinol Metab. 2013;98(1):322–9. PMID: 23175691.23175691
136 Kong AS, Sussman AL, Yahne C, . School-based health center intervention improves body mass index in overweight and obese adolescents. J Obes. 2013;2013:575016. PMID: 23589771.23589771
137 Lison JF, Real-Montes JM, Torro I, . Exercise intervention in childhood obesity: a randomized controlled trial comparing hospital-versus home-based groups. Acad Pediatr. 2012;12(4):319–25. PMID: 22634075.22634075
138 Looney SM, Raynor HA. Examining the effect of three low-intensity pediatric obesity interventions: a pilot randomized controlled trial. Clin Pediatr (Phila). 2014;53(14):1367–74. PMID: 25006118.25006118
139 Love-Osborne K, Fortune R, Sheeder J, . School-based health center-based treatment for obese adolescents: feasibility and body mass index effects. Child Obes. 2014;10(5):424–31. PMID: 25259781.25259781
140 Love-Osborne K, Sheeder J, Zeitler P. Addition of metformin to a lifestyle modification program in adolescents with insulin resistance. J Pediatr. 2008;152(6):817–22. PMID: 18492523.18492523
141 Maahs D, de Serna DG, Kolotkin RL, . Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocr Pract. 2006;12(1):18–28. PMID: 16524859.16524859
142 McCallum Z, Wake M, Gerner B, . Outcome data from the LEAP (Live, Eat and Play) trial: a randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes (Lond). 2007;31(4):630–6. PMID: 17160087.17160087
143 Mellin LM, Slinkard LA, Irwin CE, Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program. J Am Diet Assoc. 1987;87(3):333–8. PMID: 3819254.3819254
144 Nemet D, Barkan S, Epstein Y, . Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443–e9. PMID: 15805347.15805347
145 Norman G, Huang J, Davila EP, . Outcomes of a 1-year randomized controlled trial to evaluate a behavioral ‘stepped-down’ weight loss intervention for adolescent patients with obesity. Pediatr Obes. 2016;11(1):18–25. PMID: 25702630.25702630
146 Nowicka P, Hoglund P, Pietrobelli A, . Family Weight School treatment: 1-year results in obese adolescents. Int J Pediatr Obes. 2008;3(3):141–7. PMID: 18608623.18608623
147 O’Connor TM, Hilmers A, Watson K, . Feasibility of an obesity intervention for paediatric primary care targeting parenting and children: Helping HAND. Child Care Health Dev. 2013;39(1):141–9. PMID: 22066521.22066521
148 Raynor HA, Osterholt KM, Hart CN, . Efficacy of U.S. paediatric obesity primary care guidelines: two randomized trials. Pediatr Obes. 2012;7(1):28–38. PMID: 22434737.22434737
149 Reinehr T, de Sousa G, Toschke AM, . Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 2006;84(3):490–6. PMID: 16960161.16960161
150 Reinehr T, Kleber M, Toschke AM. Lifestyle intervention in obese children is associated with a decrease of the metabolic syndrome prevalence. Atherosclerosis. 2009;207(1):174–80. PMID: 19442975.19442975
151 Reinehr T, Schaefer A, Winkel K, . An effective lifestyle intervention in overweight children: findings from a randomized controlled trial on “Obeldicks light”. Clin Nutr. 2010;29(3):331–6. PMID: 20106567.20106567
152 Resnicow K, McMaster F, Bocian A, . Motivational interviewing and dietary counseling for obesity in primary care: an RCT. Pediatrics. 2015;135(4):649–57. PMID: 25825539.25825539
153 Sacher PM, Kolotourou M, Chadwick PM, . Randomized controlled trial of the MEND program: a family-based community intervention for childhood obesity. Obesity (Silver Spring). 2010;18 Suppl 1. PMID: 20107463.20107463
154 Saelens BE, Sallis JF, Wilfley DE, . Behavioral weight control for overweight adolescents initiated in primary care. Obes Res. 2002;10(1):22–32. PMID: 11786598.11786598
155 Savoye M, Caprio S, Dziura J, . Reversal of early abnormalities in glucose metabolism in obese youth: results of an intensive lifestyle randomized controlled trial. Diabetes Care. 2014;37(2):317–24. PMID: 24062325.24062325
156 Savoye M, Shaw M, Dziura J, . Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697–704. PMID: 17595270.17595270
157 Sherwood NE, JaKa MM, Crain AL, . Pediatric primary care-based obesity prevention for parents of preschool children: a pilot study. Child Obes. 2015;11(6):674–82. PMID: 26478951.26478951
158 Srinivasan S, Ambler GR, Baur LA, . Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006;91(6):2074–80. PMID: 16595599.16595599
159 Stark LJ, Clifford LM, Towner EK, . A pilot randomized controlled trial of a behavioral family-based intervention with and without home visits to decrease obesity in preschoolers. J Pediatr Psychol. 2014;39(9):1001–12. PMID: 25080605.25080605
160 Stark LJ, Spear S, Boles R, . A pilot randomized controlled trial of a clinic and home-based behavioral intervention to decrease obesity in preschoolers. Obesity (Silver Spring). 2011;19(1):134–41. PMID: 20395948.20395948
161 Stettler N, Wrotniak BH, Hill DL, . Prevention of excess weight gain in paediatric primary care: beverages only or multiple lifestyle factors. The Smart Step Study, a cluster-randomized clinical trial. Pediatr Obes. 2014. PMID: 25251166.25251166
162 Tanofsky-Kraff M, Wilfley DE, Young JF, . A pilot study of interpersonal psychotherapy for preventing excess weight gain in adolescent girls at-risk for obesity. Int J Eat Disord. 2010;43(8):701–6. PMID: 19882739.19882739
163 Taveras EM, Gortmaker SL, Hohman KH, . Randomized controlled trial to improve primary care to prevent and manage childhood obesity: the High Five for Kids study. Arch Pediatr Adolesc Med. 2011;165(8):714–22. PMID: 21464376.21464376
164 Taveras EM, Marshall R, Kleinman KP, . Comparative effectiveness of childhood obesity interventions in pediatric primary care: a cluster-randomized clinical trial. JAMA Pediatr. 2015;169(6):535–42. PMID: 25895016.25895016
165 Taylor RW, Cox A, Knight L, . A tailored family-based obesity intervention: a randomized trial. Pediatrics. 2015;136(2):281–9. PMID: 26195541.26195541
166 van Grieken A, Veldhuis L, Renders CM, . Population-based childhood overweight prevention: outcomes of the ‘Be active, eat right’ study. PLoS ONE. 2013;8(5):e65376. PMID: 23741491.23741491
167 Vos RC, Wit JM, Pijl H, . Long-term effect of lifestyle intervention on adiposity, metabolic parameters, inflammation and physical fitness in obese children: a randomized controlled trial. Nutr Diabetes. 2011;1:e9. PMID: 23455021.23455021
168 Wake M, Baur LA, Gerner B, . Outcomes and costs of primary care surveillance and intervention for overweight or obese children: the LEAP 2 randomised controlled trial. BMJ. 2009;339:b3308. PMID: 19729418.19729418
169 Wake M, Lycett K, Clifford SA, . Shared care obesity management in 3–10 year old children: 12 month outcomes of HopSCOTCH randomised trial. BMJ. 2013;346:f3092. PMID: 23751902.23751902
170 Weigel C, Kokocinski K, Lederer P, . Childhood obesity: concept, feasibility, and interim results of a local group-based, long-term treatment program. J Nutr Educ Behav. 2008;40(6):369–73. PMID: 18984493.18984493
171 Wiegand S, l’Allemand D, Hubel H, . Metformin and placebo therapy both improve weight management and fasting insulin in obese insulin-resistant adolescents: a prospective, placebo-controlled, randomized study. Eur J Endocrinol. 2010;163(4):585–92. PMID: 20639355.20639355
172 Wilson DM, Abrams SH, Aye T, . Metformin extended release treatment of adolescent obesity: a 48-week randomized, double-blind, placebo-controlled trial with 48-week follow-up. Arch Pediatr Adolesc Med. 2010;164(2):116–23. PMID: 20124139.20124139
173 Yanovski JA, Krakoff J, Salaita CG, . Effects of metformin on body weight and body composition in obese insulin-resistant children: a randomized clinical trial. Diabetes. 2011;60(2):477–85. PMID: 21228310.21228310
174 Adeyemo MA, McDuffie JR, Kozlosky M, . Effects of metformin on energy intake and satiety in obese children. Diabetes Obes Metab. 2015;17(4):363–70. PMID: 25483291.25483291
175 Chanoine JP, Richard M. Early weight loss and outcome at one year in obese adolescents treated with orlistat or placebo. Int J Pediatr Obes. 2011;6(2):95–101. PMID: 20858149.20858149
176 Clarson CL, Brown H, Dejesus S, ., editors. Structured lifestyle intervention with metformin extended release or placebo in obese adolescents. Diabetes; 2013.
177 Condarco TA, Sherafat-Kazemzadeh R, McDuffie JR, ., editors. Long-term follow-up of a randomized, placebo-controlled trial of orlistat in African-American and caucasian adolescents with obesity-related comorbid conditions. The Endocrine Society’s 95th Annual Meeting and Expo; 2013 June 15; San Francisco, CA.
178 Davoli AM, Broccoli S, Bonvicini L, . Pediatrician-led motivational interviewing to treat overweight children: an RCT. Pediatrics. 2013;132(5):e1236–46. PMID: 24144717.24144717
179 Etu SF. A test of the compensation and capitalization models in group interpersonal psychotherapy for adolescent girls at risk for obesity. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2012;72(10-B):6412.
180 Fortune R, Love-Osborne K, Sheeder J. Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 2012;50(2 suppl. 1):S33.
181 Freemark M. Liver dysfunction in paediatric obesity: a randomized, controlled trial of metformin. Acta Paediatrica. 2007;96(9):1326–32. PMID: 17718786.17718786
182 Gerards SM, Dagnelie PC, Jansen MW, . Lifestyle Triple P: a parenting intervention for childhood obesity. BMC Public Health. 2012;12:267. PMID: 22471971.22471971
183 Glasofer DR. Self-efficacy in adolescent girls at risk for overweight during an obesity prevention program. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(7-B):4420.
184 Golley RK, Magarey AM, Daniels LA. Children’s food and activity patterns following a six-month child weight management program. Int J Pediatr Obes. 2011;6(5–6):409–14. PMID: 21838569.21838569
185 Golley RK, Magarey AM, Steinbeck KS, . Comparison of metabolic syndrome prevalence using six different definitions in overweight pre-pubertal children enrolled in a weight management study. Int J Obes (Lond). 2006;30(5):853–60. PMID: 16404409.16404409
186 Golley RK, Perry RA, Magarey A, . Family-focused weight management program for five- to nine-year-olds incorporating parenting skills training with healthy lifestyle information to support behaviour modification. Nutr Diet. 2007;64(3):144–50. PMID: 24843434.24843434
187 Hofsteenge GH, Chinapaw MJ, Weijs PJ, . Go4it; study design of a randomised controlled trial and economic evaluation of a multidisciplinary group intervention for obese adolescents for prevention of diabetes mellitus type 2. BMC Public Health. 2008;8:410. PMID: 19087330.19087330
188 Hofsteenge GH, Weijs PJ, Delemarre-van de Waal HA, . Effect of the Go4it multidisciplinary group treatment for obese adolescents on health related quality of life: a randomised controlled trial. BMC Public Health. 2013;13:939. PMID: 24103472.24103472
189 Incledon E, Gerner B, Hay M, . Psychosocial predictors of 4-year BMI change in overweight and obese children in primary care. Obesity (Silver Spring). 2013;21(3):E262–70. PMID: 23404919.23404919
190 Kalavainen M, Korppi M, Nuutinen O. Long-term efficacy of group-based treatment for childhood obesity compared with routinely given individual counselling. Int J Obes. 2011;35(4):530–3. PMID: 2128594321285943
191 Kalavainen M, Utriainen P, Vanninen E, . Impact of childhood obesity treatment on body composition and metabolic profile. World J Pediatr. 2012;8(1):31–7. PMID: 22105574.22105574
192 McCallum Z, Wake M, Gerner B, . Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. J Paediatr Child Health. 2005;41(9–10):488–94. PMID: 16150065.16150065
193 McDuffie JR, Calis KA, Uwaifo GI, . Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10(7):642–50. PMID: 12105286.12105286
194 Reinehr T, Schaefer A, Winkel K, . Development and evaluation of the lifestyle intervention “obeldicks light” for overweight children and adolescents. J Public Health (Oxf). 2011;19(4):377–84. PMID: 26811110.26811110
195 Reinehr T, Temmesfeld M, Kersting M, . Four-year follow-up of children and adolescents participating in an obesity intervention program. Int J Obes (Lond). 2007;31(7):1074–7. PMID: 17471300.17471300
196 Resnicow K, McMaster F, Woolford S, . Study design and baseline description of the BMI2 trial: reducing paediatric obesity in primary care practices. Pediatr Obes. 2012;7(1):3–15. PMID: 22434735.22434735
197 Rudolf M, Christie D, McElhone S, . WATCH IT: a community based programme for obese children and adolescents. Arch Dis Child. 2006;91(9):736–9. PMID: 16531453.16531453
198 Sanders MR. Triple P-Positive Parenting Program: towards an empirically validated multilevel parenting and family support strategy for the prevention of behavior and emotional problems in children. Clin Child Fam Psychol Rev. 1999;2(2):71–90. PMID: 11225933.11225933
199 Savoye M, Caprio S, Dziura J, . A community-based intervention for diabetes risk reduction in innercity obese adolescents. Diabetologia. 2013;56(Suppl 1):S342.
200 Savoye M, Nowicka P, Shaw M, . Long-term results of an obesity program in an ethnically diverse pediatric population. Pediatrics. 2011;127(3):402–10. PMID: 21300674.21300674
201 Shaw M, Savoye M, Cali A, . Effect of a successful intensive lifestyle program on insulin sensitivity and glucose tolerance in obese youth. Diabetes Care. 2009;32(1):45–7. PMID: 18840769.18840769
202 Sonneville KR, Rifas-Shiman SL, Kleinman KP, . Associations of obesogenic behaviors in mothers and obese children participating in a randomized trial. Obesity (Silver Spring). 2012;20(7):1449–54. PMID: 22349735.22349735
203 Taveras EM, Hohman KH, Price SN, . Correlates of participation in a pediatric primary care-based obesity prevention intervention. Obesity (Silver Spring). 2011;19(2):449–52. PMID: 20847735.20847735
204 Taveras EM, Marshall R, Horan CM, . Improving children’s obesity-related health care quality: process outcomes of a cluster-randomized controlled trial. Obesity (Silver Spring). 2014;22(1):27–31. PMID: 23983130.23983130
205 Taveras EM, Marshall R, Horan CM, . Rationale and design of the STAR randomized controlled trial to accelerate adoption of childhood obesity comparative effectiveness research. Contemp Clin Trials. 2013;34(1):101–8. PMID: 23099100.23099100
206 Taylor RW, Brown D, Dawson AM, . Motivational interviewing for screening and feedback and encouraging lifestyle changes to reduce relative weight in 4–8 year old children: design of the MInT study. BMC Public Health. 2010;10:271. PMID: 20497522.20497522
207 Van Allen J, Kuhl ES, Filigno SS, . Changes in parent motivation predicts changes in body mass index z-score (zBMI) and dietary intake among preschoolers enrolled in a family-based obesity intervention. J Pediatr Psychol. 2014;39(9):1028–37. PMID: 25016604.25016604
208 van Grieken A, Renders CM, Veldhuis L, . Promotion of a healthy lifestyle among 5-year-old overweight children: health behavior outcomes of the ‘Be active, eat right’ study. BMC Public Health. 2014;14:59. PMID: 24447459.24447459
209 Veldhuis L, Struijk MK, Kroeze W, . ‘Be active, eat right’, evaluation of an overweight prevention protocol among 5-year-old children: design of a cluster randomised controlled trial. BMC Public Health. 2009;9:177. PMID: 19505297.19505297
210 Vos RC, Huisman SD, Houdijk EC, . The effect of family-based multidisciplinary cognitive behavioral treatment on health-related quality of life in childhood obesity. Qual Life Res. 2012;21(9):1587–94. PMID: 22161746.22161746
211 Vos RC, Wit JM, Pijl H, . The effect of family-based multidisciplinary cognitive behavioral treatment in children with obesity: study protocol for a randomized controlled trial. Trials. 2011;12:110. PMID: 21548919.21548919
212 Wake M, Gold L, McCallum Z, . Economic evaluation of a primary care trial to reduce weight gain in overweight/obese children: the LEAP trial. Ambul Pediatr. 2008;8(5):336–41. PMID: 18922508.18922508
213 Wake M, Lycett K, Sabin MA, . A shared-care model of obesity treatment for 3–10 year old children: protocol for the HopSCOTCH randomised controlled trial. BMC Pediatrics. 2012;12:39. PMID: 22455381.22455381
214 Weijs PJ, Hofsteenge AG, Chinapaw M, . Long-term effect of the Go4it group treatment for obese adolescents: A randomised controlled trial. Clinical Nutrition. 2012;7(1 Suppl):130. PMID: 23810626.23810626
215 Wildes JE, Marcus MD, Kalarchian MA, . Self-reported binge eating in severe pediatric obesity: impact on weight change in a randomized controlled trial of family-based treatment. Int J Obes (Lond). 2010;34(7):1143–8. PMID: 20157322.20157322
216 Wilson AJ, Prapavessis H, Jung ME, . Lifestyle modification and metformin as long-term treatment options for obese adolescents: study protocol. BMC Public Health. 2009;9:434. PMID: 19943971.19943971
217 Woo Baidal JA, Price SN, Gonzalez-Suarez E, . Parental perceptions of a motivational interviewing-based pediatric obesity prevention intervention. Clin Pediatr (Phila). 2013;52(6):540–8. PMID: 23564304.23564304
218 Rooney BL, Gritt LR, Havens SJ, . Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54–60. PMID: 16138517.16138517
219 Epstein LH, Roemmich JN, Robinson JL, . A randomized trial of the effects of reducing television viewing and computer use on body mass index in young children. Arch Pediatr Adolesc Med. 2008;162(3):239–45. PMID: 18316661.18316661
220 Doyle AC, Goldschmidt A, Huang C, . Reduction of overweight and eating disorder symptoms via the Internet in adolescents: a randomized controlled trial. J Adolesc Health. 2008;43(2):172–9. PMID: 18639791.18639791
221 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behav Psychother. 1985;13(4):287.
222 Flodmark CE, Ohlsson T, Ryden O, . Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91(5):880–4. PMID: 8474806.8474806
223 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. J Pediatr Endocrinol Metab. 2007;20(2):197–203. PMID: 17396436.17396436
224 Reinehr T, de SG, Toschke AM, . Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 2006;84(3):490–6. PMID: 16960161.16960161
225 U.S. Food and Drug Administration. Glucophage Label. FDA Application Number: (NDA) 020357. http://www.accessdata.fda.gov/drugsatfda_docs/label/2008/020357s031,021202s016lbl.pdf. Accessed 10/22/2015, 2017.
226 U.S. Food and Drug Administration. Xenical Label. FDA Application Number: (NDA) 020766. http://www.accessdata.fda.gov/drugsatfda_docs/label/2015/020766s035lbl.pdf. Accessed 3/31/2017, 2017.
227 Atabek ME, Pirgon O. Use of metformin in obese adolescents with hyperinsulinemia: a 6-month, randomized, double-blind, placebo-controlled clinical trial. J Pediatr Endocrinol Metab. 2008;21(4):339–48. PMID: 18556965.18556965
228 Merry MS, Voigt K. Risk, harm and intervention: the case of child obesity. Med Health Care Philos. 2014;17(2):191–200. PMID: 24346516.24346516
229 Markert J, Herget S, Petroff D, . Telephone-based adiposity prevention for families with overweight children (T.A.F.F.-Study): one year outcome of a randomized, controlled trial. Int J Environ Res Public Health. 2014;11(10):10327–44. PMID: 25286167.25286167
230 Wiegand S, Keller KM, Lob-Corzilius T, . Predicting weight loss and maintenance in overweight/obese pediatric patients. Horm Res Paediatr. 2014;82(6):380–7. PMID: 25531074.25531074
231 Ford AL, Hunt LP, Cooper A, . What reduction in BMI SDS is required in obese adolescents to improve body composition and cardiometabolic health? Arch Dis Child. 2010;95(4):256–61. PMID: 19966092.19966092
232 Reinehr T, Andler W. Changes in the atherogenic risk factor profile according to degree of weight loss. Arch Dis Child. 2004;89(5):419–22. PMID: 15102630.15102630
233 Kolsgaard ML, Joner G, Brunborg C, . Reduction in BMI z-score and improvement in cardiometabolic risk factors in obese children and adolescents. The Oslo Adiposity Intervention Study - a hospital/public health nurse combined treatment. BMC Pediatr. 2011;11:47. PMID: 21619652.21619652
234 Reinehr T, Lass N, Toschke C, . Which Amount of BMI-SDS Reduction Is Necessary to Improve Cardiovascular Risk Factors in Overweight Children? The Journal of Clinical Endocrinology & Metabolism. 2016;101(8):3171–9. PMID: 27285295.27285295
235 Abrams P, Levitt Katz LE, Moore RH, . Threshold for improvement in insulin sensitivity with adolescent weight loss. J Pediatr. 2013;163(3):785–90. PMID: 23706362.23706362
236 Kirk S, Zeller M, Claytor R, . The relationship of health outcomes to improvement in BMI in children and adolescents. Obes Res. 2005;13(5):876–82. PMID: 15919841.15919841
237 National Heart Lung and Blood Institute. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults. the evidence report. Bethesda, MD (USA): National Institutes of Health; 1998.
238 WeightWatchers. What Losing 10 Percent Can Do. Learn the health benefits of reaching that first milestone goal. http://www.weightwatchers.com/util/art/index_art.aspx?tabnum=1&art_id=41231&sc=3001. Accessed 12/15/15.
239 National Heart Lung and Blood Institute. Aim for a healthy weight - facts about healthy weight. http://www.nhlbi.nih.gov/health-pro/resources/heart/aim-facts-html. Accessed 12/15/15, 2017.
240 Pietrzykowska N. Benefits of 5–10 Percent Weight-loss. http://www.obesityaction.org/educational-resources/resource-articles-2/general-articles/benefits-of-5-10-percent-weight-loss. Accessed 12/15/15, 2017.
241 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Guidance for industry. Developing products for weight management: Draft Guidance. http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm071612.pdf. Accessed 12/18/15, 2017.
242 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Background Memorandum: The role of cardiovascular assesment in the pre- and post-approval settings for drugs developed for the treatment of obesity. http://www.fda.gov/downloads/advisorycommittees/committeesmeetingmaterials/drugs/endocrinologicandmetabolicdrugsadvisorycommittee/ucm297240.pdf. Accessed 12/18/15, 2017.
243 Knowler WC, Barrett-Connor E, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393–403. PMID: 11832527.11832527
244 Poirier P, Giles TD, Bray GA, . Obesity and cardiovascular disease: pathophysiology, evaluation, and effect of weight loss: an update of the 1997 American Heart Association Scientific Statement on Obesity and Heart Disease from the Obesity Committee of the Council on Nutrition, Physical Activity, and Metabolism. Circulation. 2006;113(6):898–918. PMID: 16380542.16380542
245 Douketis JD, Macie C, Thabane L, . Systematic review of long-term weight loss studies in obese adults: clinical significance and applicability to clinical practice. Int J Obes (Lond). 2005;29(10):1153–67. PMID: 15997250.15997250
246 Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343–50. PMID: 11333990.11333990
247 Eriksson KF, Lindgarde F. Prevention of type 2 (non-insulin-dependent) diabetes mellitus by diet and physical exercise. The 6-year Malmo feasibility study. Diabetologia. 1991;34(12):891–8. PMID: 1778354.1778354
248 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006.19299006
249 Flegal KM, Graubard BI, Williamson DF, . Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA. 2007;298(17):2028–37. PMID: 17986696.17986696
250 Calle EE, Thun MJ, Petrelli JM, . Body-mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341(15):1097–105. PMID: 10511607.10511607
251 Engeland A, Bjorge T, Sogaard AJ, . Body mass index in adolescence in relation to total mortality: 32-year follow-up of 227,000 Norwegian boys and girls. Am J Epidemiol. 2003;157(6):517–23. PMID: 12631541.12631541
252 Must A, Jacques PF, Dallal GE, . Long-term morbidity and mortality of overweight adolescents. A follow-up of the Harvard Growth Study of 1922 to 1935. N Engl J Med. 1992;327(19):1350–5. PMID: 14068361406836
253 Peirson L, Fitzpatrick-Lewis D, Morrison K, . Treatment of overweight and obesity in children and youth: a systematic review and meta-analysis. CMAJ Open. 2015;3(1):E35–46. PMID: 25844368.25844368
254 Ho M, Garnett SP, Baur L, . Effectiveness of lifestyle interventions in child obesity: systematic review with meta-analysis. Pediatrics. 2012;130(6):e1647–71. PMID: 23166346.23166346
255 Oude LH, Baur L, Jansen H, . Interventions for treating obesity in children. Cochrane Database of Systematic Reviews. 2009(1):Art. No.: CD001872. PMID: 19160202.19160202
256 Janicke DM, Steele RG, Gayes LA, . Systematic review and meta-analysis of comprehensive behavioral family lifestyle interventions addressing pediatric obesity. Journal of Pediatric Psychology. 2014;39(8):809–25. PMID: 24824614.24824614
257 Altman M, Wilfley DE. Evidence update on the treatment of overweight and obesity in children and adolescents. J Clin Child Adolesc Psychol. 2015;44(4):521–37. PMID: 25496471.25496471
258 Gilles A, Cassano M, Shepherd EJ, . Comparing active pediatric obesity treatments using meta-analysis. J Clin Child Adolesc Psychol. 2008;37(4):886–92. PMID: 18991137.18991137
259 Sargent GM, Pilotto LS, Baur LA. Components of primary care interventions to treat childhood overweight and obesity: a systematic review of effect. Obesity Reviews. 2011;12(5):e219–e35. PMID: 2063002520630025
260 Jelalian E, Foster GD, Sato AF, . Treatment adherence and facilitator characteristics in a community based pediatric weight control intervention. Int J Behav Nutr Phys Act. 2014;11:17. PMID: 24524280.24524280
261 Resnicow K, Taylor R, Baskin M, . Results of go girls: a weight control program for overweight African-American adolescent females. Obesity Research. 2005;13(10):1739–48. PMID: 16286521.16286521
262 Steele RG, Aylward BS, Jensen CD, . Comparison of a family-based group intervention for youths with obesity to a brief individual family intervention: a practical clinical trial of positively fit. J Pediatr Psychol. 2012;37(1):53–63. PMID: 21852343.21852343
263 Larsen LM, Hertel NT, Molgaard C, . Early intervention for childhood overweight: a randomized trial in general practice. Scand J Prim Health Care. 2015;33(3):184–90. PMID: 26194172.26194172
264 Nguyen B, Shrewsbury VA, O’Connor J, . Twelve-month outcomes of the loozit randomized controlled trial: a community-based healthy lifestyle program for overweight and obese adolescents. Arch Pediatr Adolesc Med. 2012;166(2):170–7. PMID: 22312175.22312175
265 Berkowitz RI, Rukstalis MR, Bishop-Gilyard CT, . Treatment of adolescent obesity comparing self-guided and group lifestyle modification programs: a potential model for primary care. J Pediatr Psychol. 2013;38(9):978–86. PMID: 23750019.23750019
266 Epstein LH, Wing RR, Penner BC, . Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107(3):358–61. PMID: 4032130.4032130
267 Epstein LH, Paluch RA, Roemmich JN, . Family-based obesity treatment, then and now: twenty-five years of pediatric obesity treatment. Health Psychol. 2007;26(4):381–91. PMID: 17605557.17605557
268 Thompson DR, Obarzanek E, Franko DL, . Childhood overweight and cardiovascular disease risk factors: the National Heart, Lung, and Blood Institute Growth and Health Study. J Pediatr. 2007;150(1):18–25. PMID: 17188606.17188606
269 Stovitz SD, Hannan PJ, Lytle LA, . Child height and the risk of young-adult obesity. Am J Prev Med. 2010;38(1):74–7. PMID: 20117560.20117560
270 Puhl RM, Heuer CA. The stigma of obesity: a review and update. Obesity (Silver Spring). 2009;17(5):941–64. PMID: 19165161.19165161
271 Puhl RM, Luedicke J, Grilo CM. Obesity bias in training: attitudes, beliefs, and observations among advanced trainees in professional health disciplines. Obesity (Silver Spring). 2014;22(4):1008–15. PMID: 24124078.24124078
272 Persky S, Eccleston CP. Medical student bias and care recommendations for an obese versus non-obese virtual patient. Int J Obes (Lond). 2011;35(5):728–35. PMID: 20820169.20820169
273 Puhl RM, Heuer CA. Obesity stigma: important considerations for public health. Am J Public Health. 2010;100(6):1019–28. PMID: 20075322.20075322
274 Jackson SE, Beeken RJ, Wardle J. Perceived weight discrimination and changes in weight, waist circumference, and weight status. Obesity (Silver Spring). 2014;22(12):2485–8. PMID: 25212272.25212272
275 Spear BA. Does dieting increase the risk for obesity and eating disorders? J Am Diet Assoc. 2006;106(4):523–5. PMID: 16567146.16567146
276 Neumark-Sztainer D, Wall M, Guo J, . Obesity, disordered eating, and eating disorders in a longitudinal study of adolescents: how do dieters fare 5 years later? J Am Diet Assoc. 2006;106(4):559–68. PMID: 16567152.16567152
277 Pietilainen KH, Saarni SE, Kaprio J, . Does dieting make you fat? A twin study. Int J Obes (Lond). 2012;36(3):456–64. PMID: 21829159.21829159
278 Sonneville KR, Calzo JP, Horton NJ, . Body satisfaction, weight gain and binge eating among overweight adolescent girls. Int J Obes (Lond). 2012;36(7):944–9. PMID: 22565419.22565419
279 van den Berg P, Neumark-Sztainer D. Fat ‘n happy 5 years later: is it bad for overweight girls to like their bodies? J Adolesc Health. 2007;41(4):415–7. PMID: 17875468.17875468
280 McDonagh MS, Selph S, Ozpinar A, . Systematic review of the benefits and risks of metformin in treating obesity in children aged 18 years and younger. JAMA Pediatr. 2014;168(2):178–84. PMID: 24343296.24343296
281 Rezvanian H, Hashemipour M, Kelishadi R, . A randomized, triple masked, placebo-controlled clinical trial for controlling childhood obesity. World J Pediatr. 2010;6(4):317–22. PMID: 21080144.21080144
282 Clarson CL, Mahmud FH, Baker JE, . Metformin in combination with structured lifestyle intervention improved body mass index in obese adolescents, but did not improve insulin resistance. Endocrine. 2009;36(1):141–6. PMID: 19387874.19387874
283 Mauras N, DelGiorno C, Hossain J, . Metformin use in children with obesity and normal glucose tolerance--effects on cardiovascular markers and intrahepatic fat. J Pediatr Endocrinol Metab. 2012;25(1–2):33–40. PMID: 22570948.22570948
284 Lavine JE, Schwimmer JB, Van Natta ML, . Effect of vitamin E or metformin for treatment of nonalcoholic fatty liver disease in children and adolescents: the TONIC randomized controlled trial. JAMA. 2011;305(16):1659–68. PMID: 21521847.21521847
285 Libman IM, Miller KM, DiMeglio LA, . Effect of metformin added to insulin on glycemic control among overweight/obese adolescents with type 1 diabetes: a randomized clinical trial. JAMA. 2015;314(21):2241–50. PMID: 26624824.26624824
286 Osterberg L, Blaschke T. Adherence to medication. N Engl J Med. 2005;353(5):487–97. PMID: 16079372.16079372
287 Freemark M. Pharmacotherapy of childhood obesity: an evidence-based, conceptual approach. Diabetes Care. 2007;30(2):395–402. PMID: 17259519.17259519
288 August GP, Caprio S, Fennoy I, . Prevention and treatment of pediatric obesity: an endocrine society clinical practice guideline based on expert opinion. J Clin Endocrinol Metab. 2008;93(12):4576–99. PMID: 18782869.18782869
289 Boland CL, Harris JB, Harris KB. Pharmacological management of obesity in pediatric patients. Ann Pharmacother. 2015;49(2):220–32. PMID: 25366340.25366340
290 Dunican KC, Desilets AR, Montalbano JK. Pharmacotherapeutic options for overweight adolescents. Ann Pharmacother. 2007;41(9):1445–55. PMID: 17652127.17652127
291 Catoira N, Nagel M, Di Girolamo G, . Pharmacological treatment of obesity in children and adolescents: current status and perspectives. Expert Opin Pharmacother. 2010;11(18):2973–83. PMID: 20958104.20958104
292 Hsia Y, Dawoud D, Sutcliffe AG, . Unlicensed use of metformin in children and adolescents in the UK. Br J Clin Pharmacol. 2012;73(1):135–9. PMID: 21762204.21762204
293 Hampp C, Kang EM, Borders-Hemphill V. Use of prescription antiobesity drugs in the United States. Pharmacotherapy. 2013;33(12):1299–307. PMID: 24019195.24019195
294 Viner RM, Hsia Y, Neubert A, . Rise in antiobesity drug prescribing for children and adolescents in the UK: a population-based study. Br J Clin Pharmacol. 2009;68(6):844–51. PMID: 20002078.20002078
295 van der Aa MP, Elst MA, van Mil EG, . METFORMIN: an efficacy, safety and pharmacokinetic study on the short-term and long-term use in obese children and adolescents - study protocol of a randomized controlled study. Trials. 2014;15:207. PMID: 24899137.24899137
296 James WP, Caterson ID, Coutinho W, . Effect of sibutramine on cardiovascular outcomes in overweight and obese subjects. N Engl J Med. 2010;363(10):905–17. PMID: 20818901.20818901
297 Kim GW, Lin JE, Blomain ES, . Antiobesity pharmacotherapy: new drugs and emerging targets. Clin Pharmacol Ther. 2014;95(1):53–66. PMID: 24105257.24105257
298 U.S. Food and Drug Administration. FDA approves weight-management drug Contrave. FDA News Release. Silver Spring, MD (USA): U.S. Food and Drug Administration; 2014.
299 U.S. Food and Drug Administration. FDA approves weight-management drug Saxenda. FDA News Release. Silver Spring, MD (USA): U.S. Food and Drug Administration; 2014.
300 Kelly AS, Rudser KD, Nathan BM, . The effect of glucagon-like peptide-1 receptor agonist therapy on body mass index in adolescents with severe obesity: a randomized, placebo-controlled, clinical trial. JAMA Pediatr. 2013;167(4):355–60. PMID: 23380890.23380890
301 Floden L, Taren DL, Muramoto ML, . BMI changes in adolescents treated with bupropion SR for smoking cessation. Obesity. 2016;24(1):26–9. PMID: 26692579.26692579
302 Guerrini R, Rosati A, Segieth J, . A randomized phase III trial of adjunctive zonisamide in pediatric patients with partial epilepsy. Epilepsia. 2013;54(8):1473–80. PMID: 23837461.23837461
303 Tan HJ, Martland TR, Appleton RE, . Effectiveness and tolerability of zonisamide in children with epilepsy: a retrospective review. Seizure. 2010;19(1):31–5. PMID: 19942456.19942456
304 Aarsen FK, van den Akker EL, Drop SL, . Effect of topiramate on cognition in obese children. Neurology. 2006;67(7):1307–8. PMID: 17030778.17030778
305 Canadian Task Force on Preventive Health Care. Recommendations for growth monitoring, and prevention and management of overweight and obesity in children and youth in primary care. CMAJ. 2015;187(6):411–21. PMID: 25824498.25824498
306 National Association of Pediatric Nurse Practitioners. NAPNAP position statement on the prevention and identification of overweight and obesity in the pediatric population. J Pediatr Health Care. 2015;29(4):A13–5. PMID: 19882803.19882803
307 American Academy of Family Physicians (AAFP). Clinical preventive service recommendation: obesity. http://www.aafp.org/patient-care/clinical-recommendations/all/obesity.html. Accessed 2017.
308 Wilkinson J, Bass C, Diem S, . Preventive Services for Children and Adolescents. Bloomington, MN (USA): Institute for Clinical Systems Improvement; 2013.
309 Guide to Community Preventive Services. Obesity prevention and control: interventions in community settings. www.thecommunityguide.org/obesity/communitysettings.html. Accessed 2017.
310 Institute of Medicine. Early Childhood Obesity Prevention Policies: Goals, Recommendataions, and Potential Actions. Washington, DC: 2011.
311 Medicaid.gov. Reducing Obesity. http://www.medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Quality-of-Care/Reducing-Obesity.html. Accessed 2017.
312 Healthcare.gov. Health benefits & coverage: Preventive health services. https://www.healthcare.gov/what-are-my-preventive-care-benefits/#part=3. Accessed 2017.
313 Centers for Disease Control and Prevention. Overweight and obesity: prevention strategies & guidelines. http://www.cdc.gov/obesity/resources/recommendations.html. Accessed 2017.
314 Epstein LH, Valoski A, Wing RR, . Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13(5):373–83. PMID: 78056317805631
315 Singh AS, Mulder C, Twisk JW, . Tracking of childhood overweight into adulthood: a systematic review of the literature. Obes Rev. 2008;9(5):474–88. PMID: 18331423.18331423
316 Brisbois TD, Farmer AP, McCargar LJ. Early markers of adult obesity: a review. Obesity Reviews. 2012;13(4):347–67. PMID: 22171945.22171945
317 Craigie AM, Lake AA, Kelly SA, . Tracking of obesity-related behaviours from childhood to adulthood: A systematic review. Maturitas. 2011;70(3):266–84. PMID: 21920682.21920682
318 Kitscha CE, Brunet K, Farmer A, . Reasons for non-return to a pediatric weight management program. Canadian Journal of Dietetic Practice & Research. 2009;70(2):89–94. PMID: 19515272.19515272
319 Stewart L, Chapple J, Hughes AR, . The use of behavioural change techniques in the treatment of paediatric obesity: qualitative evaluation of parental perspectives on treatment. Journal of Human Nutrition & Dietetics. 2008;21(5):464–73. PMID: 18647212.18647212
320 McKee MD, Maher S, Deen D, . Counseling to prevent obesity among preschool children: acceptability of a pilot urban primary care intervention. Ann Fam Med. 2010;8(3):249–55. PMID: 20458109.20458109
321 Wilson LF. Adolescents’ Attitudes about Obesity and What They Want in Obesity Prevention Programs. Journal of School Nursing. 2007;23(4):229–38. PMID: 17676971.17676971
322 Lupi JL, Haddad MB, Gazmararian JA, . Parental perceptions of family and pediatrician roles in childhood weight management. J Pediatr. 2014;165(1):99–103 e2. PMID: 24721470.24721470
323 Andersen MK, Christensen B, Sondergaard J. Child overweight in general practice - parents’ beliefs and expectations - a questionnaire survey study. BMC Fam Pract. 2013;14:152. PMID: 2411892024118920
324 Bradford K, Kihlstrom M, Pointer I, . Parental attitudes toward obesity and overweight screening and communication for hospitalized children. Hosp Pediatr. 2012;2(3):126–32. PMID: 24319916.24319916
325 Dawson AM, Brown DA, Cox A, . Using motivational interviewing for weight feedback to parents of young children. Journal of Paediatrics & Child Health. 2014;50(6):461–70. PMID: 24617494.24617494
326 Falconer CL, Park MH, Croker H, . The benefits and harms of providing parents with weight feedback as part of the national child measurement programme: a prospective cohort study. BMC Public Health. 2014;14:549. PMID: 24888972.24888972
327 Syrad H, Falconer C, Cooke L, . Health and happiness is more important than weight’: a qualitative investigation of the views of parents receiving written feedback on their child’s weight as part of the National Child Measurement Programme. J Hum Nutr Diet. 2015;28(1):47–55. PMID: 26295077.26295077
328 Alia KA, Wilson DK, McDaniel T, . Development of an innovative process evaluation approach for the Families Improving Together (FIT) for weight loss trial in African American adolescents. Eval Program Plann. 2015;49:106–16. PMID: 25614139.25614139
329 Anderson YC, Wynter LE, Moller KR, . The effect of a multi-disciplinary obesity intervention compared to usual practice in those ready to make lifestyle changes: design and rationale of Whanau Pakari. BMC Obes. 2015;2:41. PMID: 26464806.26464806
330 Ayala GX, Ibarra L, Binggeli-Vallarta A, . Our Choice/Nuestra Opcion: the Imperial County, California, Childhood Obesity Research Demonstration study (CA-CORD). Childhood Obesity. 2015;11(1):37–47. PMID: 25584664.25584664
331 Bean MK, Jeffers AJ, Tully CB, . Motivational interviewing with parents of overweight children: study design and methods for the NOURISH + MI study. Contemp Clin Trials. 2014;37(2):312–21. PMID: 24530488.24530488
332 Boutelle KN, Liang J, Knatz S, . Design and implementation of a study evaluating extinction processes to food cues in obese children: the Intervention for Regulations of Cues Trial (iROC). Contemp Clin Trials. 2015;40:95–104. PMID: 25461494.25461494
333 Christie D, Hudson L, Mathiot A, . Assessing the efficacy of the Healthy Eating and Lifestyle Programme (HELP) compared with enhanced standard care of the obese adolescent in the community: study protocol for a randomized controlled trial. Trials. 2011;12:242. PMID: 22088133.22088133
334 Cohen TR, Hazell TJ, Vanstone CA, . A family-centered lifestyle intervention to improve body composition and bone mass in overweight and obese children 6 through 8 years: a randomized controlled trial study protocol. BMC Public Health. 2013;13:383. PMID: 23617621.23617621
335 Dalton WT, 3rd, Schetzina KE, McBee MT, . Parent report of child’s health-related quality of life after a primary-care-based weight management program. Child Obes. 2013;9(6):501–8. PMID: 24152081.24152081
336 Danielsen YS, Skjakodegard HF, Kolko RP, ., editors. T8:PO.093: Family-based behavioral treatment of obesity-the FABO-study. 22nd Congress of the European Congress on Obesity; 2015 May 6–9; Prague, Czech Republic. PMID: 2596914925969149.
337 Ek A, Chamberlain KL, Ejderhamn J, . The More and Less Study: a randomized controlled trial testing different approaches to treat obesity in preschoolers. BMC Public Health. 2015;15:735. PMID: 26231850.26231850
338 Eneli IU, Tylka TL, Hummel J, . Rationale and design of the Feeding Dynamic Intervention (FDI) study for self-regulation of energy intake in preschoolers. Contemporary Clinical Trials. 2015;41:325–34. PMID: 25616192.25616192
339 Farpour-Lambert N MAMXBDTSBM. Effects of family-based behavioral therapy in group or in individual setting in pre-pubertal obese children: A randomized controlled trial. Obesity Facts. 2012;5(Suppl 1):221.22647304
340 Foster BA, Aquino C, Gil M, . A randomized clinical trial of the effects of parent mentors on early childhood obesity: Study design and baseline data. Contemporary Clinical Trials. 2015;45(Pt B):164–9. PMID: 26343746.26343746
341 Hage RE, Rocher E, Chappard C, . P179: Effects of a 6-month physical training program on body composition, BMD and markers of bone remodeling in obese children. Osteoporos Int. 2013;24(Suppl 1):S121.
342 Hare ME, Coday M, Williams NA, . Methods and baseline characteristics of a randomized trial treating early childhood obesity: the Positive Lifestyles for Active Youngsters (Team PLAY) trial. Contemporary Clinical Trials. 2012;33(3):534–49. PMID: 22342450.22342450
343 Hingle MD, Turner T, Kutob R, . The EPIC Kids Study: a randomized family-focused YMCA-based intervention to prevent type 2 diabetes in at-risk youth. BMC Public Health. 2015;15(1):1253. PMID: 26679186.26679186
344 Janicke DM, Lim CS, Mathews AE, . The community-based healthy-lifestyle intervention for rural preschools (CHIRP) study: design and methods. Contemporary Clinical Trials. 2013;34(2):187–95. PMID: 23183252.23183252
345 Matthan NR, Xue X, Gao Q, . Effect of a family based intervention on biomarkers of diet quality/endogenous metabolism and BMI z-score. Circulation. 2015;131.
346 McGavock J, Hay J, Wittmeier K, . Physical activity intensity and type 2 diabetes risk in overweight youth: The power trial, a randomized, controlled trial. Diabetes. 2014;63:A317.
347 Moore SM, Borawski EA, Cuttler L, . IMPACT: a multi-level family and school intervention targeting obesity in urban youth. Contemp Clin Trials. 2013;36(2):574–86. PMID: 24008055.24008055
348 Onnerfalt J, Erlandsson LK, Orban K, . A family-based intervention targeting parents of preschool children with overweight and obesity: conceptual framework and study design of LOOPS- Lund overweight and obesity preschool study. BMC Public Health. 2012;12:879. PMID: 23072247.23072247
349 Polacsek M, Orr J, Letourneau L, . Impact of a primary care intervention on physician practice and patient and family behavior: keep ME Healthy---the Maine Youth Overweight Collaborative. Pediatrics. 2009;123 Suppl 5:S258–66. PMID: 19470601.19470601
350 Raben A, Fogelholm M, Larsen TM, ., editors. T7:PO.016: PREVIEW: Preventionof diabetes through lifestyle intervention and population studies in Europe and a round the world. Over 2,000 volunteers randomized to the 3-y RCT. 22nd Congress of the European Congress on Obesity; 2015 May 6–9; Prague, Czech Republic.
351 Robertson W, Stewart-Brown S, Stallard N, . Evaluation of the effectiveness and cost-effectiveness of Families for Health V2 for the treatment of childhood obesity: study protocol for a randomized controlled trial. Trials. 2013;14:81. PMID: 23514100.23514100
352 Sherwood NE, Levy RL, Langer SL, . Healthy Homes/Healthy Kids: a randomized trial of a pediatric primary care-based obesity prevention intervention for at-risk 5–10 year olds. Contemp Clin Trials. 2013;36(1):228–43. PMID: 2381649023816490
353 Sousa P, Fonseca H, Gaspar P, . Internet-based intervention programme for obese adolescents and their families (Next.Step): research protocol of a controlled trial. Journal of Advanced Nursing. 2014;70(4):904–14. PMID: 24020828.24020828
354 Stoner L, Shultz SP, Lambrick DM, . The Combating Obesity in Maori and Pasifika Adolescent School-Children Study: COMPASS Methodology and Study Protocol. Int J Prev Med. 2013;4(5):565–79. PMID: 23930168.23930168
355 Taveras EM, Marshall R, Sharifi M, . Connect for Health: Design of a clinical-community childhood obesity intervention testing best practices of positive outliers. Contemporary Clinical Trials. 2015;45(Pt B):287–95. PMID: 26427562.26427562
356 Willeboordse M, van de Kant KD, de Laat MN, . Multifactorial intervention for children with asthma and overweight (Mikado): study design of a randomised controlled trial. BMC Public Health. 2013;13:494. PMID: 23692648.23692648