# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; William H. Dietz, MD, PhD, Cynthia Ogden, Sarah Barlow, MD, Sandra Hassink, MD, Brian Saelens, PhD, Muhammed Usman Ali, MD, and Kathryn Love-Osborne, MD, for providing expert review of the draft report; the Centers for Disease Control and Prevention’s National Center for Chronic Disease and Prevention; the U.S. Army; the National Heart, Lung, and Blood Institute; the National Institute of Child Health and Human Development; the National Institute for Diabetes and Digestive and Kidney Diseases; the National Institute for Nursing Home Research; and the National Institute of Health’s Office of Disease Prevention and Health Promotion for providing federal partner review of the draft report; and Smyth Lai, MLS, and Elizabeth Hess, MA, ELS(D), at the Kaiser Permanente Center for Health Research.