# 4 Discussion

Given the many factors that influence weight and the many ways our current environment conspires to make weight management difficult,^52, 54^ even for persons without a genetic predisposition for obesity, unprecedented levels of self-discipline are required to maintain a healthy weight, and even more so to lose excess weight.^57, 58^ Environmental challenges are strongest in economically disadvantaged communities, where safe play spaces are scarcest and access to healthy and delicious food is often limited due to a lack of availability, relatively high cost, and time required to prepare meals from scratch.^228^ The need to support children and families in their efforts to reduce excess weight in children is great, as evidenced by the large number of children resorting to ineffective and unhealthy methods to control their weight.^99, 100^

## Summary of Evidence

A fairly large and recent body of literature on lifestyle-based weight loss programs with at least 26 contact hours consistently demonstrated small average reductions in excess weight compared with usual care or other control groups among children and adolescents who were overweight or had obesity (Table 15). The literature also revealed no evidence of these programs causing harm. Relative reductions in zBMI of 0.20 or more were typical, but the absolute amount of weight loss was highly variable within studies, suggesting a wide possible range of benefit. Interventions with the most contact hours (targeting children ages 6 to 16 years, collectively) also demonstrated approximately 6- to 9-point reductions in SBP relative to the control groups, smaller reductions in DBP, some improvement in insulin and glucose parameters, but typically no improvements in fasting plasma glucose or lipid parameters. Behavior-based interventions with fewer contact hours rarely demonstrated benefit, although very limited evidence suggested that briefer interventions may be effective in children who are overweight but do not have obesity. Number of contact hours was the only study or intervention characteristic that was clearly related to effect size, with larger effects seen in trials with more contact hours. Use of metformin and orlistat were associated with very small reductions in excess weight in youth. Medications provided small or no benefit for intermediate cardiometabolic outcomes, including fasting glucose level. Evidence on metformin was primarily limited to youth with abnormalities of insulin or glucose metabolism, most of whom met adult criteria for severe obesity. The evidence base was small for metformin and even smaller for orlistat, with only three trials. Pooled metformin results showed very small effect sizes, so those results are vulnerable to change in statistical significance if newly published studies find no benefit. We found no direct evidence on the benefits or harms of screening for excess weight in children and adolescents.

Table 15 Summary of Evidence

Key Question Topic | # of Studies | # of Participants | Study Design | Summary of Findings | Consistency/Precision | Limitations (Includes Reporting Bias) | Overall Study Quality | Applicability
Key Question 1, 1a, 1b, 1c: Benefits of screening | 0 | NA | NA | NA | NA | NA | NA | NA
Key Question 2: Harms of screening | 0 | NA | NA | NA | NA | NA | NA | NA
Key Question 3: Health benefits treatment Behavior-based interventions | 11 | 1523 | RCTs | 11 trials reported generally small statistically nonsignificant relative increases in health-related quality of life or functioning scores, using a variety of specific measures, except 1 trial in young children that reported improved physical functioning with a larger effect size. Trials reported high variability in effects, suggesting a wide range of benefit to individuals within trials. In addition, 5 trials reported measures related to self-esteem and 5 of body satisfaction, with most finding no group differences. 1 trial reported no differences in percent screening positive for depression. | Consistency: Quality of life/functioning results reasonably consistent, other outcomes either inconsistent or had insufficient data to rate consistency for other outcomes Precision: Quality of life/functioning results imprecise, primarily due to confidence intervals that straddle 1.0 and wide variety of specific measures; other outcomes imprecise due to inconsistency or insufficient data to rate precision for other outcomes | Wide variety of measures and specific outcomes reported, raising concerns about reporting bias; however, since most results were not statistically significant this concern is mitigated. | Fair to good (5 good-quality trials, 6 fair-quality trials) | 5 trials conducted in the United States, 3 involved primary care
Key Questions 3a (common components of efficacious interventions) and 3b (differences in efficacy by subpopulation) Behavior-based interventions | 11 | 1523 | RCTs | Data were insufficient to examine variability in effects due to treatment components or differences in effect for important subpopulations. | Consistency: NA Precision: NA | Same as KQ3, and only 1 trial reporting clear benefit, with insufficient variability in effect size to examine further | Fair to good (5 good-quality trials, 6 fair-quality trials) | 5 trials conducted in the United States, 3 involved primary care
Key Questions 3, 3a, 3b Health benefits of treatment Pharmacologic interventions | 1 (Orlistat) | 40 | RCT | No difference in quality of life between users of orlistat and placebo. Insufficient data to examine common components of efficacious interventions or differences in efficacy by subpopulation. | Consistency: NA Precision: Imprecise | Single small study, short (6 month) followup | Fair | Conducted in the United States, but not in primary care.
Key Question 4, 4a: Benefits of behavior-based interventions on weight and cardiometabolic outcomes Lifestyle-based weight loss interventions | 42 | 6956 | 3 CCTs, 39 RCTs | Interventions with ≥26 hours of contact generally reported small average reductions in excess weight, with larger effects seen in trials with greater contact hours. Intervention groups receiving ≥26 hours of contact generally reported zBMI reductions of 0.10 to 0.77 while control group youth showed reductions of ≤0.20, or increased zBMI at followup. Trials reported high variability in effects, suggesting a wide range of benefit to individuals within trials. In trials with ≥52 hours of estimated contact, improvements were seen in SBP (−6.4, 95% CI −8.6 to −4.2) and DBP (−4.0, 95% CI −5.6 to −2.5) and some insulin/glucose parameters in some trials, but benefits were rare and cardiometabolic outcomes were sparsely reported in trials of lower-contact interventions. | Consistency: Reasonably consistent for weight outcomes, reasonably consistent for blood pressure and lipids, inconsistent for insulin/glucose measures Precision: Imprecise | No evidence of reporting bias was identified, but many included trials were limited by small sample sizes (n<40 per treatment arm) and fairly high (20%–40%) attrition. 16 trials were excluded for poor quality. For cardiometabolic outcomes, reporting bias was not apparent because most of the highest-contact trials reported these outcomes. Reporting was most spare in trials with <52 contact hours, where benefits were rarely found. | Fair to good (8 good-quality, 34 fair-quality) | Almost half of the trials were conducted in the United States, and over one-third were conducted in primary care settings, but trials with the highest contact hours and largest effects were not conducted in primary care, and access to similar programs is likely limited.
Key Question 4: Benefits of behavior-based interventions on weight Other weight loss interventions | 2 | 82 | RCTs | Small feasibility trials of interpersonal therapy and a regulation of cues intervention to limit overeating did not show group differences in BMI or zBMI change. | Consistency: NA Precision: Imprecise | Very limited data | Fair (both fair-quality) | Both trials conducted in the United States, one with substantial representation of black and Latino youth.
Key Question 4: Benefits of behavior-based interventions on weight Weight loss maintenance interventions | 1 | 61 | RCT | Small pilot study found that the addition of a maintenance group intervention after completing a weight loss intervention did not improve weight maintenance. | Consistency: NA Precision: Imprecise | Single very small trial. | Fair | Trials conducted in the United States, sample limited to black and Latino youth
Key Question 4, 4a: Benefits of pharmacologic interventions on weight and cardiometabolic outcomes Metformin | 8 | 616 | RCTs | Metformin was associated with a small statistically significant weight reduction with very low statistical heterogeneity despite differences in dose and background therapy. In pooled analyses, metformin reduced zBMI by −0.10 (95% CI, −0.17 to −0.03; k=6; I^2^=13.1) and BMI by −0.86 (95% CI, −1.44 to −0.29; k=6; I^2^=0). Results of trials that could not be pooled were generally consistent with pooled results. Metformin was associated with no statistically significant benefit for fasting glucose, lipid or blood pressure outcomes; where outcomes could be pooled, confidence intervals were wide and statistical heterogeneity was high for some outcomes. | Consistency: Reasonably consistent Precision: Imprecise | Small studies with wide confidence intervals; short trials primarily of 6 month duration; limited data about persistence of effect after discontinuation | Fair (1 good-quality, 7 fair-quality) | Most trials conducted in the United States, but none in primary care. 75% of trials required abnormalities of insulin or glucose for inclusion and mean baseline BMI of 36.0 kg/m^2^; reasonable representation of black and Hispanic youth
Key Question 4, 4a: Benefits of pharmacologic interventions on weight and cardiometabolic outcomes Orlistat | 3 | 779 | RCTs | Orlistat was associated with small between-group reductions in BMI ranging from −0.94 (95% CI, −1.58 to −0.30) to −0.50 (95% CI, −7.62 to 6.62) and weight ranging from −3.90 (−25.54 to 17.74) to −2.61 (95% CI, not reported, p<0.001) kg. The 1 trial reporting zBMI showed a between-group difference of −0.06 (95% CI, −0.12 to 0.00) favoring orlistat. Results were statistically significant only in the 2 larger trials. Where reported, changes in cardiometabolic risk factors were generally statistically nonsignificant, except for a diastolic blood pressure reduction in 1 large trial (mean between-group difference, −1.81 mm Hg [CI not reported], p=0.04). | Consistency: Reasonably consistent Precision: Imprecise | Small body of evidence (3 studies). 1 of 3 studies was small (n=40); 2 of 3 trials had short 6-month duration. No study followed weight change after medication use ended. | Fair (all fair-quality) | All trials conducted in the United States, but none in primary care. Mean baseline BMI of 37.4 kg/m^2^; reasonable representation of black and Hispanic youth.
Key Question 4b: Common components of efficacious interventions Lifestyle-based weight loss interventions | 42 | 6956 | 3 CCTs, 39 RCTs | Hours of contact was the only treatment characteristic clearly associated with effect size. Most successful interventions took place outside of the primary care setting, targeted both the parent and child, provided didactic information, helped parents and children engage in stimulus control (e.g., limiting access to tempting foods, limiting screening time), identified or helped participants identify specific goals, and encouraged self-monitoring and problem-solving to help achieve the goals, and included supervised physical activity sessions. | Consistency: Apparent dose-response effect for hours of contact, could not determine for other components Precision: NA | Interventions were highly variable and impact of specific components could not be evaluated. | Fair to good (8 good quality, 34 fair quality) | Almost ½ of the trials were conducted in the United States, and >1/3 were conducted in primary care settings, but trials with the highest contact hours and largest effects were not conducted in primary care, and access to similar programs is likely limited.
Key Question 4c: Differences in efficacy by key patient subgroups Lifestyle-based weight loss interventions | 42 | 6956 | 3 CCTs, 39 RCTs | Only 6 trials reported subgroup analyses, and neither these analyses nor evidence in trials limited to important subpopulations suggested that lifestyle-based weight loss interventions were more or less effective in subpopulations defined by age, race/ethnicity, sex, degree of excess weight, or socioeconomic status | Consistency: Inconsistent Precision: Imprecise | Only 6 trials included subgroups analyses, definitions of subpopulations varied across studies; many subgroups involved small sample sizes; statistical interaction testing was missing in several trials | Fair to good (8 good-quality, 34 fair-quality) | Almost half of the trials were conducted in the United States, and over one-third were conducted in primary care settings, but trials with the highest contact hours and largest effects were not conducted in primary care, and access to similar programs is likely limited.
Key Question 5: Harms of treatment Behavior-based interventions | 10 | 1232 | RCT | Among 10 trials reporting something related to adverse effects, 5 reported no adverse or serious adverse effects associated with the interventions; others reported no group differences on eating disorder pathology or body dissatisfaction. | Consistency: Consistent Precision: Imprecise | Sparsely and inconsistently reported. | Fair to good (4 good-quality,6 fair-quality) | 4 U.S.-based trials, 3 conducted in primary care, covering elementary age children and adolescents
Key Question 5: Harms of pharmacologic interventions Metformin | 11 | 705 | RCTs | Gastrointestinal side effects were common but not serious in participants taking metformin. Side effects were also frequently reported by those on placebo. Discontinuation due to adverse effects was relatively rare (<5%) and occurred in relatively similar proportions in metformin and placebo groups. | Consistency: Despite difference in how side effects were reported, results reasonably consistent Precision: Imprecise | Inconsistent definitions of side effects across studies. | 10 fair, 1 good | Most trials conducted in the United States, but none in primary care.
Key Question 5: Harms of pharmacologic interventions Orlistat | 3 | 779 | RCTs | Gastrointestinal side effects were very common among patients taking orlistat. Discontinuation due to adverse effects was relatively rare (<5%), and about twice as common in orlistat participants compared with those taking placebo. | Consistency: Despite difference in how side effects were reported, results reasonably consistent Precision: Imprecise | Evidence limited to 3 studies, 1 of which was small (n=40). | Fair (all fair-quality) | All trials conducted in the United States, but none in primary care.

Abbreviations: BMI=body mass index; CCT=controlled clinical trial; CI=confidence interval; KQ=Key Question; NA=not applicable; RCT=randomized, controlled trial; SBP=systolic blood pressure; zBMI=body mass index z score.

## Clinical Significance

The clinical importance of these changes in weight is difficult to understand. A German expert panel considers a zBMI reduction of 0.20 to be associated with clinically significant improvement,^229^ but we found no data to support any particular cutoff. The German panel, using German norms, noted that a reduction of 0.20 zBMI units typically corresponds to a weight reduction of 5 percent.^230^ Several prospective studies of children who had obesity have reported larger improvements in cardiometabolic measures among those who reduced their zBMI over time—and reported statistically significant linear trends in some cases—across four levels of zBMI improvement (e.g., zBMI increase, zBMI decrease of 0 to 0.25, zBMI decrease of 0.25 to 0.50, zBMI decrease >0.50). These studies typically found a greater likelihood of statistically detectable change in cardiometabolic risk factors with zBMI reductions of 0.125 to 0.500. ^231–234^ However, no clear or consistent threshold was apparent over the chosen zBMI change categories. Similarly, a study showing greater improvement in insulin sensitivity with an 8 percent reduction in BMI did not provide compelling data showing this level of BMI change to be an important threshold (e.g., compared with 6% or 10%) nor whether the amount of improvement in insulin sensitivity reported was clinically significant.^235^ Analysis of subjects who completed a short-term, family-based behavioral weight management program showed that the average zBMI reduction achieved in the intervention group (0.15) was associated with statistically significant improvements in lipid and insulin measures in linear regression analyses, as well as normalization of blood pressure, total cholesterol, and low-density lipoprotein cholesterol in a significant portion of participants with initially abnormal levels of these measures.^236^ While it may be useful to know, for example, that an 8 percent reduction in BMI is associated with a statistically detectable change in insulin sensitivity, statistical significance was the determinant of benefit in all of these studies, and is partially a function of sample size and may not reflect clinically meaningful change. However, setting aside the issue of degree of excess weight needed to improve cardiometabolic health, in many trials, children in the control groups were more likely to show a continued trajectory of increasing excess weight, on average, so simply arresting the gain in excess weight likely constitutes a clinically important benefit for many of these interventions.

In the literature on adult obesity, weight loss amounts of both 5 and 10 percent or more of baseline weight are commonly cited as thresholds of clinical significance to confer cardiovascular benefit. As in the pediatric literature, we found no direct evidence to justify any specific threshold. Older obesity guidelines and commercial weight loss programs claim that 10 percent weight loss is sufficient to significantly decrease the severity of obesity-related risk factors^237^ and improve several markers of overall health.^238^ Some literature targeted at consumers cite lower thresholds of 5 to 10 percent.^239, 240^ To guide industry about developing products for weight management, the FDA set efficacy benchmarks of mean weight loss of 5 percent or more, subsequently citing the Diabetes Prevention Program (DPP) and a narrative review of obesity epidemiology.^241–244^ In contrast, a systematic review of long-term (≥2 years) dietary-focused interventions for weight loss found that weight loss of at least 5 percent was not consistently associated with significant improvements in cardiovascular risk factors in an unselected adult population that was overweight or had obesity.^245^ Instead, substantial changes in risk factors occurred principally among those at increased cardiovascular risk, such as participants with impaired glucose tolerance.^243, 246, 247^

DPP, which included adults who were overweight, did not have diabetes, and had elevated glucose levels, set a weight loss goal of 7 percent in its lifestyle intervention group.^243^ About half of this intervention group achieved this weight loss goal at 24 weeks, although weight regain was steady after this point (but still remained below baseline). Despite some weight regain, the incidence of type 2 diabetes was reduced by 58 percent (95% CI, 48 to 66) with the lifestyle intervention over an average followup of 2.8 years. The DPP intervention was highly intensive and likely involved more than 26 contact hours: 16 individual sessions over the first 24 weeks, followed by subsequent monthly individual and group sessions, twice-weekly optional supervised physical activity sessions, and optional 4- to 6-week maintenance courses. This level of intensity, access to trained interventionists, and focus in a high-risk population limit applicability to unselected adults who are overweight or have obesity, let alone children and adolescents, in real-world practice.

Regardless of the lack of direct evidence for any specific threshold for clinical significance, there is strong evidence of a relationship between adiposity, intermediate risk factors, and long-term health outcomes. An individual patient data meta-analysis of nearly 900,000 adults showed a continuous positive association between BMI and overall and cause-specific mortality at a BMI greater than 22.5 kg/m^2^.^248^ On average, overall mortality in the individual patient data meta-analysis was about 30 percent higher for every 5-kg/m^2^ increment of BMI above 22.5 kg/m^2^, and proportional increases in risk were slightly larger at progressively younger age strata after an average 13 years of followup. However, controversy remains about the ill effects of overweight in the absence of obesity, since some large prospective studies have not shown increased mortality risk below a BMI of 25 kg/m^2^.^249, 250^ Smaller analyses suggested that the associations between adiposity and mortality are established in adolescence.^251, 252^ The relationship between adiposity and health outcomes, the close tracking of childhood and adolescent obesity into adulthood, and the difficulty of achieving and sustaining weight loss all underscore the importance of obesity prevention.

## Behavior-Based Lifestyle Interventions

The results of the current review are consistent with a recent review commissioned by the Canadian Task Force on Preventive Health Care, which included a different but overlapping body of evidence, including trials with no connection to a health care setting and limiting evidence to RCTs.^253^ These reviewers found that behavioral interventions aimed at weight management were associated with a small but robust average reduction in BMI (pooled mean difference, −1.15 kg/m^2^ [95% CI, −1.59 to −0.72]) as well as small improvements in blood pressure (pooled mean difference in SBP, −4.64 mm Hg [95% CI, −7.46 to −1.82]; pooled mean difference in DBP, −4.08 mm Hg [95% CI, −6.07 to −2.09]) and quality of life (pooled mean difference, 2.05 [95% CI, −0.31 to 4.40]). These pooled effect sizes are entirely consistent with the results in the trials included in our review. In addition, we primarily examined zBMI rather than BMI because of its relatively consistent interpretability across ages. Differences in BMI change in our review were typically greater than 1.0 kg/m^2^ for interventions with 26 or more contact hours and most commonly less than 1.0 kg/m^2^ with fewer contact hours. Other reviews have similarly reported favorable effects of lifestyle-based weight management interventions, particularly comprehensive programs involving parents and at least a moderate level of intervention intensity.^254–256^

Due to the wide range of ages in the included studies and the large variability in effects, even when ages were more restricted, it is difficult to characterize the amount of weight loss children and adolescents are likely to experience from participating in lifestyle-based weight loss interventions. Nine of the 13 trials with lifestyle-based weight loss interventions of 26 or more contact hours showed average zBMI reductions of 0.20 or more, and seven of the 13 trials reported reductions of 0.30 or more (Appendix D Table 4). Typically, most intervention group participants maintained their average baseline weight within approximately 5 lb while growing in height (Appendix D Table 5). These reductions were generally compared with small average increases in zBMI or reductions of 0.10 or less in control groups, or 5- to 17-lb average increases in weight. However, it is unknown how many children in control groups sought out formal weight loss programs and resources from their communities. Given the wide range of effects in the control groups (as in the intervention groups), some families may have received formal help. Few of the less intensive interventions reported zBMI reductions of 0.20 or more.

We were unable to identify specific characteristics or components that showed a clear association with effect size. As mentioned above, most successful interventions included sessions that targeted both the parent and child (separately, together, or both); offered individual family sessions as well as group sessions; provided information about healthy lifestyle choices; encouraged the use of stimulus control (e.g., limiting access to tempting foods, limiting screen time), goal-setting, self-monitoring, contingent rewards, and problem-solving; and included some supervised physical activity sessions. Parents were frequently asked to modify their behavior and were sometimes actively engaged in weight loss interventions themselves. These are typical of family-based behavioral treatment components, as described by Altman and Wilfley.^257^ They describe four target areas: dietary modification (reducing caloric intake), energy expenditure modification (increasing energy expenditure), behavior change techniques (goal-setting, self-monitoring, reward systems, stimulus control), and family involvement and support (shaping the home environment, modeling healthy eating and activity, parenting skills, and lifestyle goals for both parents and children) and provide specific strategies or goals for each area. For example, to shape the home environment, families are encouraged to “make the healthy choice the easy choice” by limiting availability of unhealthy foods in the house. Another review of child obesity treatment interventions noted the importance of parental involvement.^258^ A review focused on interventions in primary care found evidence to support training health professionals before intervention delivery; offering behavior change options; using a combination of counseling, education, written resources, support, and motivation; and tailoring intensity according to whether behavioral, anthropometric, or metabolic changes are the priority.^259^ One study examining interventionist characteristics found that adherence to the protocol showed the strongest association with greater weight loss.^260^

While we found that trials with more contact hours were associated with larger effect sizes, it is impossible to disentangle contact hours from the content of the interventions, and in particular, interventions with more contact hours tended to offer supervised exercise sessions. Our nonsystematic examination of the comparative effectiveness literature found little to shed further light on necessary or sufficient contact hours or the importance of supervised physical activity. Several trials have compared briefer with more extensive behavior-based interventions and most have shown small, statistically nonsignificant benefits favoring the higher-contact groups.^261–265^ These findings are similar to those of trials included in this review that included multiple intervention groups with varying levels of contact hours, along with a control group. Regarding the role of supervised physical activity, we found only one trial exploring the addition of approximately 22 hours of supervised physical activity to an already comprehensive (estimated 42-hour) behavior-based intervention.^266^ This study reported a statistically nonsignificant between-group difference at 12 months of followup (3.9-kg reduction with physical activity sessions vs. 1.4-kg reduction without, adjusting for baseline weight).

It is always questionable whether results reported in clinical trials will be comparable with those in real-world settings. For comparison, one study of 3,135 children who had attended a certified German pediatric obesity treatment center and had 2 years of continuous followup data had results fairly comparable with those seen in the higher-intensity trials in our review. That study reported that 47 percent of the children had reduced zBMI by 0.2 units or more after 2 years.^230^ Twenty-three percent of children who showed both initial weight loss success in the first 6 months (average zBMI reduction, 0.46) and continued improvement through 2 years ended up with a final average zBMI of 1.79, a decrease from an average of 2.4. Boys and children younger than age 12 years were most likely to show this pattern of success. However, 53 percent of children either did not maintain initial loss of excess weight or never showed substantial improvement in zBMI.

The included evidence was limited to followup of 1 to 2 years. Epstein et al published 10-year followup results from children completing several versions of a family-based comprehensive weight management intervention, a program that several included trials were modeled after.^267^ Children from four trials were combined for long-term followup; the interventions differed slightly across the four studies, but all involved an estimated 30 or more contact hours with the families. Epstein reported that 52.5 percent of the children undergoing these interventions met criteria for obesity at the 10-year followup. Children were ages 8 to 12 years at study entry (average age, 10.4 years) and were on average 49.9 ± 17.2 percent overweight; almost all participants likely met the criteria for obesity at baseline. Naturalistic longitudinal studies generally show higher rates of obesity at comparable followup, typically 64 to 87 percent, with U.S.-based studies falling in the higher end of the spectrum,^19, 20, 268, 269^ suggesting that family-based weight management programs improve the likelihood of avoiding future obesity, at least during early adulthood.

We found no harms associated with behavior-based weight management interventions in the included studies. However, in the United States, stigma against persons who are overweight or have obesity can be pronounced and are associated with prejudice and discrimination—including by health care providers^270–272^—in multiple domains of life.^273^ Obesity is usually blamed on the individual, and bullying, shaming, and discrimination are not uncommon. Encountering these events in the health care setting may lead persons with excess weight to avoid health care and delay preventive care.^270^ Further, a longitudinal study of 2,944 adults age 50 years and older found that perceived weight discrimination was associated with relative increases in weight (+1.66 kg; p<0.001) and waist circumference (+1.12 cm; p=0.046).^274^ Whether similar effects occur in children and adolescents is unknown.

One concern is that intentional weight loss, which weight management interventions such as those included in this review often encourage, could be associated with subsequent increases in weight and increased risk of unhealthy dieting and eating behaviors.^275^ For example, a longitudinal study in adolescents found that teens who reported dieting (changing eating habits to lose weight) had an increased likelihood of greater weight gain, being overweight or having obesity, and experiencing loss of control over eating 5 years later. This relationship was strongest in teens who reported unhealthy dieting behaviors at baseline (fasting, eating very little food, using food substitutes, skipping meals, smoking cigarettes, taking diet pills, vomiting, or using laxatives or diuretics).^276^ However, this study found some risk even in teens who reported only healthy dieting behaviors (exercising more, eating more fruits and vegetables, eating less high-fat food, eating fewer sweets), even after controlling for baseline BMI, weight control behaviors, socioeconomic status, and race/ethnicity; girls who engaged in healthy dieting behaviors were more likely to meet criteria of overweight or obesity and boys had increased likelihood of binge eating at followup.^276^ A study of twins suggests that most of the association between intentional weight loss and subsequent weight gain is because persons who are prone to gain weight are also likely to try to lose weight, but they also found that, among monozygotic twins, those with a history of intentional weight loss showed a small (0.4 kg/m^2^) increase in weight gain over 7 years compared with the twin who had no history of intentional weight loss.^277^ None of the interventions included in this review promoted unhealthy weight loss activities, and many described countermeasures such as emphasizing healthy incremental lifestyle changes over dieting. For example, the trial conducted by Kalvainen et al specifically stated that their program “focused on promoting healthy lifestyle and well-being of obese children instead of weight management.”^133^ Unfortunately, none of the trials reported on the use of unhealthy dieting practices in their participants.

Other studies have shown that body dissatisfaction is associated with future weight gain in adolescents,^278, 279^ and programs that target weight loss could increase body dissatisfaction if youth feel shamed or stigmatized. However, many of the included interventions directly addressed body image to combat body dissatisfaction. Based on measures related to acceptability of weight loss programs, evidence from 17 included trials suggests that participants did not feel stigmatized or shamed (Appendix E). On various satisfaction questionnaires, both parents and children rated their satisfaction with the weight management interventions highly. In most trials, 80 percent or more of participants had high satisfaction or acceptability ratings, and continuous satisfaction scores typically were above 4 on a 5-point scale.^118, 129, 130, 136, 147, 160, 163, 164^ The interventions were also rated high in quality and value; for example, all the parents in one fair-quality study rated the Positive Parenting Program as good to excellent.^130^ The participants of four included studies reported that the intervention met their particular weight loss needs.^126, 130, 147, 166^ Primary care providers also found the interventions to be of high quality,^143, 166^ helpful,^169^ and relevant.^142^

## Pharmacotherapy Interventions

Our systematic review of two pharmacotherapy agents found that they offer a small incremental benefit over background lifestyle therapy; between-group BMI reductions were of the magnitude of −0.86 kg/m^2^ for metformin and at most −0.94 kg/m^2^ for orlistat. In the context of high baseline BMI in included trials (36.0 kg/m^2^ for metformin and 37.4 kg/m^2^ for orlistat), these values represent a BMI reduction of only about 2 percent. The largest zBMI reduction seen in any intervention arm of a pharmacotherapy trial was 0.17,^123^ although only one orlistat trial reported zBMI and only six of the eight metformin trials did. These drugs generally showed little to no benefit for glucose, lipid, or blood pressure outcomes. Side effects for both metformin and orlistat were primarily gastrointestinal in nature and common but not serious, and discontinuation due to adverse effects was relatively rare (<5%). For metformin, our results for BMI change were generally similar but smaller in magnitude than those reported in a recent systematic review that showed a pooled BMI reduction of −1.16 kg/m^2^ (95% CI, −1.60 to −0.73).^280^ That review included trials that we excluded based on duration for efficacy analyses,^121, 127, 134^ setting,^281^ no use of a placebo in control groups,^282, 283^ quality,^227^ and study aim other than weight loss.^284^ Regardless, that review reached similar conclusions, namely that the magnitude of BMI change was small compared with the reductions needed for long-term health benefits.^280^ Our results were also similar to those of a recent trial of metformin added to insulin among 140 adolescents who were overweight or had obesity with type 1 diabetes; there was a similar between-group zBMI reduction of −0.1 (95% CI, −0.2 to −0.1) and no statistically significant improvements in glycemic control, blood pressure, or lipid levels with metformin at 6 months.^285^

Most metformin trials (75%)^128, 135, 140, 158, 171, 173^ were conducted in populations with hyperinsulinemia, insulin resistance, or impaired glucose tolerance, thereby limiting applicability to the general pediatric population with obesity. The two metformin trials that did not require insulin or glucose metabolism abnormalities for inclusion were fair-quality trials with about 70 participants each, children and adolescents ranging from ages 10 to 18 years with obesity; both trials showed statistically significant reductions in BMI of −1.1 and −1.86 kg/m^2^, respectively, at 1 year.^123, 172^ The body of evidence for pharmacotherapy was further limited by small trials of limited duration. Moreover, only one drug trial evaluated the effects after discontinuation; it showed that the effect of metformin disappears after 12 to 24 weeks off treatment.^172^ The benefits of pharmacologic treatment for the general population of patients with obesity may also be hindered by lower adherence than reported in trials, particularly given the general challenges of adherence in adolescent populations.^286^

Metformin reduces hepatic glucose production and plasma insulin, inhibits fat cell lipogenesis, and may increase peripheral insulin sensitivity and reduce appetite by raising levels of glucagon-like peptide-1 (GLP-1).^287^ Its precise mechanism of action for weight reduction, however, is not completely understood.^288–291^ Due to extremely wide variation in glucose and insulin outcomes, our data did not confirm nor rule out improvements in these outcomes as having a mediating effect on BMI. Metformin is FDA-approved for the treatment of type 2 diabetes among children age 10 years or older, but not for weight management (in children or adults). Data on the use of metformin for treatment of obesity in pediatric populations are limited and its use for this indication in the United States is unknown. An analysis of a large U.K. primary care database spanning 2000 to 2010 showed that among adolescents prescribed metformin, most had a diagnosis of diabetes. Only 8 percent of adolescents taking this medication were prescribed metformin for obesity alone.^292^

Orlistat inhibits intestinal lipases and reduces the gastrointestinal absorption of fat by 30 percent.^287^ Orlistat is FDA-approved for weight management in patients age 12 years or older and is available over the counter for adults age 18 years or older. Use of orlistat in the United States peaked in 2000 (the year after it was approved by the FDA) and has seen a dramatic decline since, with about 23,000 projected users in 2011, of whom 0.6 percent were age 16 years or younger.^293^ Just about half of orlistat users discontinue the medication after 30 days. A U.K. primary care database spanning 1999 to 2006 found a similar rate of orlistat discontinuation among persons younger than age 18 years.^294^ Reasons for discontinuation could include side effects or a perceived lack of effectiveness.^293^

The use of pharmacotherapy for obesity treatment is an active area of research, as evidenced by four newly included metformin studies in this updated review and one ongoing trial,^295^ one newly included orlistat trial,^108^ and additional literature on various agents for adult populations. Since the last systematic review for the USPSTF, sibutramine was removed from the market because of concerns about cardiovascular safety,^296^ and the following drugs were approved by the FDA for chronic weight management in adults: lorcaserin, phentermine-topiramate, bupropion-naltrexone, and liraglutide.^297–299^

However, investigation of these and other pharmacologic agents for use in general pediatric populations with obesity is very limited. Exenatide, a GLP-1 agonist used to improve glycemic control in adults with diabetes, demonstrated a statistically significant BMI reduction of −1.13 kg/m^2^ in a placebo-controlled 3-month randomized trial of 26 adolescents.^300^ GLP-1 agonists enhance satiety by slowing gastric emptying, and activation of GLP-1 receptors suppresses appetite.^289, 300^ This agent is administered via injection twice per day, which may limit its acceptability. Bupropion is a norepinephrine and dopamine reuptake inhibitor that can improve appetite regulation and decrease food cravings;^291^ its combination with naltrexone is FDA-approved for weight management in adults.^298^ Evidence for the use of bupropion in children and adolescents is limited. A 2016 study evaluating the efficacy of bupropion for smoking cessation in adolescents found that adolescents randomized to 300 mg/day had a small statistically significant reduction in zBMI at 6 weeks (−0.16 [95% CI, −0.29 to −0.04]) that was not maintained at 6 months compared with adolescents randomized to placebo or 150 mg/day.^301^

Studies designed to evaluate the efficacy and tolerability of the antiepileptic medications topiramate and zonisamide have demonstrated weight loss, but these studies were conducted in children and adolescents with epilepsy or otherwise nongeneralizable clinical history (i.e., treatment of brain tumor).^289, 302–304^ Adverse effects of topiramate included effects on language, attention, memory and psychomotor speed and somnolence, vomiting, and diarrhea for zonisamide.

The Expert Committee guidelines consider pharmacotherapy an intensive tertiary-care intervention that can be offered through a comprehensive, multidisciplinary intervention to some youth who have severe obesity and have previously attempted weight control.^1^ This 2007 guideline addressed only orlistat and sibutramine, the latter of which has since been withdrawn from the market. A 2008 guideline from the Endocrine Society similarly suggested that pharmacotherapy should be considered in children who have obesity only after failure to lose weight with an intensive lifestyle modification program and in children who are overweight if they have significant, severe comorbid conditions and have not responded to lifestyle intervention.^288^ Direct evidence for this stepped-care approach to pharmacotherapy is limited to one RCT of metformin (n=70 adolescents with insulin resistance), which restricted inclusion to participants with a previous unsuccessful lifestyle intervention, defined as BMI change less than 2 kg/m^2^ and persistent insulin resistance; this study showed no difference in between-group change in BMI or zBMI.^171^ The Canadian Task Force on Preventive Health Care, which evaluated only orlistat, recently issued a “weak” recommendation, based on moderate-quality evidence, that providers not routinely offer this drug to youth ages 12 to 17 years (and strongly recommended against offering orlistat to younger children).^305^ No guidelines explicitly recommend the use of metformin, mainly due to lack of regulatory approval for treatment of pediatric obesity.^288, 305^

## Role of Primary Care

Given the tremendous effort required to change a family’s dietary and activity patterns, some children and adolescents will cycle through weight management programs more than once before successfully and substantially reducing excess weight. Because weight management will likely be a lifelong struggle for many of these children, and because families’ energy and commitment to weight management likely varies over time, these children will need varying levels of support at different stages and will have times when they are more—or less—successful. Having access to multiple sources of support of varying levels of intensity over the course of many years would likely be ideal. Primary care providers are limited in the degree to which they can provide direct instruction and support for weight loss, but they could collaborate with their patients to determine the level of care needed at different points in their weight management journey, help connect them with appropriate resources, and provide a supportive “home base” throughout the process. A chronic care model envisioned by the 2007 Expert Committee remains an aspirational paradigm in which practices are linked to community resources that can provide more intensive support; have clinical information systems; and have in-house capability to support patient self-management, monitor patient and clinician adherence to evidence-based care pathways, and remind providers about routine tests and treatment. The Expert Committee noted that with regard to the obesity epidemic at large, “health care-centered efforts alone cannot effect change, but they can complement and potentially enhance evolving public health efforts, such as school wellness policies, parks and recreation programs, and shifts in child-targeted food advertisements.”^1^

## Limitations of the Review

This review identified several limitations to the evidence base, including no evidence related to the benefits or harms of screening for obesity. In the trials of treatment of excess weight, limitations included minimal long-term followup, many studies with small numbers of participants, methodologic limitations, and somewhat sparse reporting of health outcomes. In addition, it is difficult to interpret average effects in the presence of high within-study variability in results, and the results rarely allowed us to determine the proportion of children falling below obesity and overweight thresholds after participating in the interventions. The degree to which control groups participated in formal weight management programs is unknown but could attenuate the apparent benefit of the intervention. In addition, heterogeneity in population, study, and intervention characteristics along with inconsistent reporting made it impossible to understand how most of these characteristics affected the study results. The evidence base for pharmacologic studies was small, particularly for orlistat. Most pharmacotherapy trials only followed children for 6 months, and only one had planned followup after the medication was discontinued.

Estimated intervention contact hours showed a clear relationship with effect size, although our measure of this was imperfect. First, not all studies reported a detailed description that included contact hours, and we had to estimate session duration in many cases. In addition, we estimated planned hours of intervention but generally did not have access to actual hours received by participants. In addition, we divided the continuous variable into categories post hoc, on the basis of maintaining methods of the previous review, extending similar logic, and the distributional properties of the included studies, and not on clear differences in effectiveness at specific cutpoints. Thus, it is not apparent that a 25-hour intervention would be substantially less effective than a 26-hour intervention. However, the evidence did seem to demonstrate that a 60-hour intervention is much more likely than a 5-hour intervention to show an average treatment benefit.

Another concern is quality of life and intermediate cardiometabolic outcomes. Because trials were only included if they reported a weight outcome, it is possible that there may be additional trials that focused only on quality of life or cardiometabolic outcomes without reporting weight change, and were not included in this review. Similarly, we did not include behavioral outcomes such as changes in dietary composition and physical activity, which may be important benefits of these interventions.

Some bodies of literature not included in this review may provide relevant information. We limited our review to trials in which either the intervention or recruitment occurred in a health care setting, thereby increasing applicability to primary care, but interventions in some of the excluded studies were likely very similar to the included studies and at least somewhat applicable. Similarly, multilevel trials, such as those that involve school- and community-level interventions, may also include individually-targeted components in health care settings, but were not included. These trials might highlight the ability of health care–based interventions to potentiate other initiatives. Also, we did not systematically search for observational evidence of harms of behavior-based interventions, although we believe the reports of harms in longitudinal studies are prone to bias due to confounding, such as youth who are most prone to weight gain also being most prone to weight loss attempts. We did not include comparative effectiveness studies, which might have enabled us to better identify specific components that are associated with effectiveness. Many recent trials only included active comparators. Many researchers already believe the evidence supports treatment benefit, so they may consider it unethical to withhold treatment from the control group, and instead focus their research on questions related to treatment response in special populations, adaptations to improve treatment response, and generalization to other settings and providers.

## Future Research Needs

A number of future research needs were identified in our review. Trials of benefit and harms of screening for obesity in children and adolescents are needed. For example, a trial that implements a systematic screening program in one set of clinics or providers but continues with usual care in another set of clinics or providers would be valuable. Replication of existing successful treatment programs relative to usual care and full trials of small feasibility studies is a logical next step for many interventions, and indeed some such studies are under way (Appendix F). Specifically, examination of the full stepped-care approach recommended by the Expert Panel would be valuable, as well as further replication of the “Prevention Plus” step successfully explored in two small trials included in this review.^159, 160^ Also, studies of large-scale dissemination of interventions that were successful (e.g., Obeldicks^149–151^ in Germany, Bright Bodies^155, 156^ in the United States) would be very valuable in determining their potential for large-scale reach, especially with referral from or integration into primary care. Further, more intervention trials are needed that are conducted among low income and racial/ethnic minority children and adolescents, given the high burden of obesity in this group and inclusion of relatively few such children, with black children being particularly underrepresented in the existing studies.

While we did not systematically review the comparative effectiveness literature, our nonsystematic searches found little to shed light on exactly what components and amount of contact is necessary and sufficient to have a high probability of success. Our indirect comparisons suggested that 26 or more contact hours increased the likelihood of showing a beneficial effect, but more direct evidence of estimated effects with varying levels of intervention contact is needed, recognizing that patient characteristics such as the child’s age and degree of excess weight may modify the needed contact time.

More long-term followup is needed, particularly into adulthood, to determine the degree to which reductions in excess weight persist and to assess cardiometabolic health benefits. Also, evidence is needed about what constitutes clinically important health benefits and, ultimately, the amount of weight loss that is associated with such benefits. Also, although the quality of methods and reporting in more recent studies were generally much better than that of earlier literature, this field would benefit from greater consistency in reporting. In addition, individual patient meta-analysis could be very helpful in this field (with such large within-study differences in results) to start to understand the differences between patients who lose excess weight and those who do not. Finally, given the high level of stigma associated with excess weight, including prejudice or discrimination by health care clinicians, direct assessment of experiences of participation in weight management interventions would be desirable.

Douketis et al proposed a standardized framework for reporting weight loss intervention studies among adults, and much of this framework applies to studies of children and adolescents also.^245^ This group proposed reporting body weight (in kilograms), BMI, waist circumference (in centimeters), and clinical cardiovascular risk factors (e.g., blood pressure) at baseline and followup, to which we would add zBMI for children, and the norms on which zBMI is based. They also recommend reporting the effects of weight loss on cardiovascular risk factors according to the amount of weight lost, which also would be beneficial for children and adolescents. Other outcomes pertinent to children are the number and percentage that fall below the 85th percentile for age and sex, between the 85th and 95th percentile, and above the 95th percentile. Douketis et al also recommended reporting outcomes in high-risk groups, such as those with impaired glucose tolerance, because benefits may differ between those who are experiencing deleterious health effects and those who are not; this recommendation would also apply to adolescents and potentially to younger children as well. They further recommend followup of 4 years or more, followup in 80 percent or more of participants, reporting of the number and reason for participants leaving a study, and strenuous efforts to contact all participants at the final followup.

## Conclusion

We found no direct evidence on benefits or harms of screening for excess weight in children and adolescents. However, lifestyle-based weight management interventions with 26 or more hours of intervention contact generally increased weight reduction with no apparent harms, and some cardiometabolic measures were improved with 52 or more contact hours. Less intensive programs are unlikely to improve weight status, except perhaps for children who are overweight but do not yet have obesity. The clinical significance of the small benefits seen with the use of metformin and orlistat is unclear. The degree to which changes in excess weight are maintained in the long term, particularly into adulthood, are unknown.