# 3 Results

## Literature Search

We screened 9,491 abstracts and 464 full-text articles for inclusion. We included 59 studies^108, 117–173^ reporting results in 102 publications,^108, 117–217^ with one publication reporting results of two separate studies.^148^ All studies were included for the benefits and/or harms of weight management interventions. We did not identify any studies on the benefits and harms of screening (KQs 1 and 2).

## Results of Included Studies

We identified 59 trials that met our inclusion criteria; all reported benefits or harms of treatment for weight management. None of the trials addressed the KQs related to screening. Study and population characteristics are shown in Tables 6 and 7 and are summarized in more detail below, primarily under KQ 4. Forty-five studies examined the benefits of behavior-based interventions compared with a control group^117–120, 124–126, 129–133, 136–139, 142–157, 159–170^ and 11 studies examined the benefits of metformin (8 trials)^123, 128, 135, 140, 158, 171–173^ or orlistat (3 trials)^108, 122, 141^ compared with a placebo. Some of the efficacy trials also reported on adverse effects, and three additional trials were included that reported harms of orlistat or metformin use for weight loss but did not have sufficient followup to be included in our examination of treatment benefits.^121, 127, 134^

Table 6 Summary of Treatment Studies, Grouped by Intervention Type, Sorted by Descending Estimated Intervention Contact Hours (KQs 3–5)

Author, Year and Quality | Design | Setting | N Rand | Months F/U (% F/U 12 Months or Closest) | Population | Intervention | Est Hours Contact (Sessions) | Control | Key Question
Author, Year and Quality | Design | Setting | N Rand | Months F/U (% F/U 12 Months or Closest) | Population | Intervention | Est Hours Contact (Sessions) | Control | 1 | 2 | 3 | 4 | 5
Lifestyle-based weight loss interventions (includes minimizing weight gain with growth in height)
Lison, 2012^137^ Fair | RCT | Spain Health Care | 110 | 6 (76.4) | 6 to 16 year old Caucasians who are overweight or have obesity (≥85th percentile but zBMI ≤2.5 for age and sex [IOTF]) | Hospital-based group exercise | 122 (122) | Lifestyle instruction during regular visits | | | | X
Weigel, 2008^170^ Fair | RCT | Germany Other | 73 | 6; 12 (90.4) | 7 to 15 year olds with obesity (>97th percentile [German norms]) | Sea Lion Club | 114.1 (104) | Brief advice | | | | X
Savoye, 2007^156, 200, 201^ Fair | RCT | United States Health Care | 209 | 6; 12 (68.4) | 8 to 16 year olds with obesity (BMI > 95th percentile [CDC]) | Bright Bodies | 82.33 (64) | Semi-annual individual counseling | | | | X
Savoye, 2014^155, 199^ Fair | RCT | United States Health Care | 75 | 6 (77.3) | 10 to 16 year olds with obesity (BMI > 95th percentile [CDC]) | Bright Bodies | 78 (52) | General advice + brief psychosocial counseling | | | | X
Reinehr, 2006^149, 195^ Fair | CCT | Germany Health Care | 240 | 12; 24 (87.9) | 6 to 14 year olds with obesity (BMI ≥ 97th percentile [German norms]) | Obeldicks | 77.5 (52) | Distance control | | | | X
Reinehr, 2009^150^ Fair | CCT | Germany Health Care | 474 | 12 (100) | 10 to 16 year olds with obesity (minimum BMI NR [German norms]) | Obeldicks | 77.5 (52) | Distance control | | | | X
Reinehr, 2010^151, 194^ Fair | RCT | Germany Health Care | 71 | 6 (84.5) | 8 to 16 year olds who are overweight (BMI 90–97th percentile [German norms]) | Obeldicks light | 67 (37) | Waitlist | | | | X | X
Vos, 2011^167, 210, 211^ Fair | RCT | Netherlands Health Care | 81 | 12 (82.7) | 8 to 17 year olds with obesity (IOTF) | Family-based multidisciplinary lifestyle intervention | 46.25 (19) | Waitlist | | | X | X
Kalarchian, 2009^132, 215^ Fair | RCT | United States Health Care | 192 | 6;12;18 (72.4) | 8 to 12 year olds with severe obesity (BMI ≥ 97th percentile [CDC]) | Family-based lifestyle intervention | 43.75 (26) | Nutrition consultation | | | X | X
Kalavainen, 2007^133, 190, 191^ Fair | RCT | Finland Health Care | 70 | 12 (98.6) | 7 to 9 year olds with obesity (weight for height 120–200% of median [UK norms]) | Health-promoting lifestyle | 43.5 (15) | Brief education + booklets | | | | X
Stark, 2011^160^ Fair | RCT | United States Primary Care and Home | 18 | 6; 12 (88.9) | 2 to 5 year olds with at least one overweight parent and who have obesity (≥95th BMI percentile but <100% above the mean BMI [CDC]) | LAUNCH | 38.25 (18) | Enhanced standard of care | | | X | X
Croker, 2012^124^ Fair | RCT | United Kingdom Health Care | 72 | 6 (68.1) | 8 to 12 year olds who are overweight or have obesity (IOTF) | Family-based behavioral therapy | 37.5 (15) | Waitlist | | | | X | X
DeBar, 2012^126^ Good | RCT | United States Health Care | 208 | 6; 12 (83.2) | 12 to 17 year old females who are overweight or have obesity (BMI ≥ 90th percentile [CDC]) | Multicomponent behavioral intervention | 36.5 (18) | PCP Meeting + materials | | | X | X | X
Sacher, 2010^153^ Fair | RCT | United Kingdom Other | 116 | 6 (70.7) | 8 to 12 year olds with obesity (BMI ≥ 98th percentile [UK 1990 reference norms]) | MEND | 36 (18) | Waitlist | | | X | X | X
Nemet, 2005^144^ Fair | RCT | Israel Health Care | 54 | 12 (74.1) | 6 to 16 year olds with obesity (definition NR) | Dietitian + PA sessions | 32.5 (34) | Nutrition referral | | | | X
Stark, 2014^159, 207^ Fair | RCT | United States Health Care | 27 | 6; 12 (85.2) | 2 to 5 year olds with at least one overweight parent and who have obesity (≥95th BMI percentile but <100% above the mean BMI [CDC]) | LAUNCH-clinic | 30 (10) | Enhanced standard of care | | | | X
Bryant, 2011^120, 197^ Fair | RCT | United Kingdom Other | 70 | 12 (75.7) | 8 to 16 year olds with obesity (BMI > 98th percentile, [NR]) | WATCH IT | 24 (16) | Waitlist | | | | X
Mellin, 1987^143^ Fair | RCT | United States Health Care | 66 | 6 (95.5) | 12 to 18 year olds with obesity (definition NR) | SHAPEDOWN | 24 (16) | Waitlist | | | | X
Golley, 2007^130, 184–186, 198^ Fair | RCT | Australia Health Care | 111 | 12 (82.0) | 6 to 9 year olds who are overweight or have obesity, but zBMI≤3.5 (IOTF) | Triple P + healthy lifestyle group | 23.75 (18) | Waitlist | | | | X
Hofsteenge, 2014^131, 187, 188, 214^ Fair | RCT | Netherlands Health Care | 122 | 6 (79.5) | 11 to 18 year olds who are overweight or have obesity (Dutch norms) | Go4it | 16.5 (11) | Usual care | | | X | X
Gerards, 2015^129, 182^ Fair | RCT | Netherlands Primary Care | 86 | 12 (77.9) | 4 to 8 year olds who are overweight or have obesity (IOTF) | Lifestyle Triple P | 16.5 (14) | Control | | | | X
Nowicka, 2008^146^ Fair | CCT | Sweden Health Care | 95 | 12 (92.6) | 12 to 19 year olds with obesity (IOTF) | Family Weight School | 16 (4) | Waitlist | | | | X
Boudreau, 2013^117^ Fair | RCT | United States Primary Care | 41 | 6 (63.4) | 9 to 12 year old Latinos who are overweight or had obesity (BMI ≥ 85th percentile [CDC]) | PowerUp + coaching | 10.5 (12) | Waitlist | | | X | X
Norman, 2015^145^ Fair | RCT | United States Primary Care | 106 | 8; 12 (80.2) | 11 to 13 year olds with obesity (BMI ≥ 95 percentile for age and gender [CDC]) | Stepped-down care | 8.25 (27) | Enhanced usual care | | | | X
Taylor, 2015^165, 206^ Good | RCT | New Zealand University and home | 206 | 12; 24 (87.9) | 4 to 8 years old who are overweight or have obesity (BMI ≥ 85th percentile [CDC]) | Tailored lifestyle support | 7.2^*^ (14) | Brief feedback and advice | | | X | X
Raynor, 2012a^148^ Fair | RCT | United States Other | 101 | 6; 12 (89.1) | 4 to 9 year olds who are overweight or have obesity (≥ 85th BMI percentile [CDC]) | DECREASE + Growth Monitoring | 6 (8) | Monthly newsletters + growth monitoring | | | | X | X
Raynor, 2012b^148^ Fair | RCT | United States Other | 81 | 6; 12 (91.4) | 4 to 9 year olds who are overweight or have obesity (≥ 85th BMI percentile [CDC]) | TRADITIONAL + Growth Monitoring | 6 (8) | Monthly newsletters + growth monitoring | | | | X | X
Kong, 2013^136^ Fair | SG-CRCT | United States Primary Care | 60 | 6 (85.0) | Students in 9th – 11th grades who are overweight or have obesity (BMI ≥ 85th percentile [CDC]) | ACTION | 4.25 (16) | Single PCP visit + booklet | | | | X
Stettler, 2014^161^ Fair | Cluster RCT | United States Primary Care | 173 | 6;12;24 (69.9) | 8 to 12 year olds who are overweight (75th–95th percentile [CDC]) and consuming average of ≥ 4 ounces of sugar sweetened beverages/day | Multiple-behavior change | 4 (12) | Attention control (bullying prevention) | | | | X
Saelens, 2002^154^ Fair | RCT | United States Primary Care | 44 | 7 (84.1) | 12 to 16 year olds who are overweight or have obesity (20% to 100% above median for BMI [NHANES]) | Healthy Habits Intervention | 3.75 (13) | Single pediatrician session | | | | X | X
Broccoli, 2016^119, 178^ Good | RCT | Italy Primary Care | 372 | 12 (95.4) | 4 to 7 year olds who are overweight (85th–95th BMI percentile [CDC]) | Motivational Interviewing | 3.75 (5) | Obesity prevention booklet | | | | X
O’Connor, 2013^147^ Fair | RCT | United States Primary Care | 40 | 7 (85) | 5 to 8 year olds who are overweight or have obesity (BMI 85th–98th percentile [CDC]) | Helping HAND | 3.5 (12) | Waitlist | | | | X
Sherwood, 2015^157^ Fair | RCT | United States Primary Care | 60 | 6 (91.7) | 2 to 4 year olds who are at risk for obesity (50th–85th BMI percentile [CDC 2000] with one parent who is overweight) or who is overweight (85th–95th BMI percentile [CDC 2000]) | Busy Bodies / Better Bites | 3.32 (9) | Attention control (safety education) | | | | X
Taveras, 2011^163, 202, 203, 217^ Good | Cluster RCT | United States Primary Care | 475 | 12; 24 (93.7) | 2 to 6 year olds who are overweight (≥ 85th percentile [CDC]) and have an overweight parent (BMI ≥ 25), or are obese (≥ 95th percentile) | MI + enhanced EMR and training | 2.67 (8) | Usual care | | | | X
Love-Osborne, 2014^139, 180^ Fair | RCT | United States Primary Care | 165 | 8 (90.3) | Middle and high school students at schools with high percentages of underserved, largely ethnic minority students who are overweight or have obesity (BMI ≥ 85th percentile [norms NR]) | Health educator visits | 2.5 (5) | Physical exam and lab screening if due, followup as needed | | | | X
Looney, 2014^138^ Fair | RCT | United States Primary Care | 22 | 6 (95) | 4 to 10 year olds who are overweight or have obesity (≥ 85th percentile [CDC]) | Newsletters + Growth Monitoring + Family-based Behavioral Counseling | 2.5 (6) | Newsletters | | | | X
Resnicow, 2015^152, 196^ Fair | Cluster RCT | United States Primary Care | 645 | 24 (70.9) | 2 to 8 year olds who are overweight or have obesity (BMI 85–97th percentile [CDC]) | PCP + RD MI | 2.5 (10) | Usual care | | | | X
Wake, 2013^169, 213^ Good | RCT | Australia Health Care | 118 | 12 (90.7) | 3 to 10 year olds with obesity (≥95th percentile [CDC]) | HopSCOTCH | 2.5 (6) | Usual care | | | X | X | X
Van Grieken, 2013^166, 208, 209^ Fair | Cluster RCT | Netherlands Primary Care | 637 | 24 (79.6) | 5 year olds who are overweight but do not have obesity (IOTF) | Be Active Eat Right | 2 (4) | Usual care | | | | X
Taveras, 2015^164, 204, 205^ Good | Cluster RCT | United States Primary Care | 549 | 12 (94.4) | 6 to 12 years olds with obesity (≥ 95th percentile [CDC]) | CDS + coaching | 1.25 (5) | Usual care | | | | X
McCallum, 2007^142, 192, 212^ Good | RCT | Australia Primary Care | 163 | 9.1; 15.0 (89.6) | 5 to 9 year olds who are overweight or have mild obesity (IOTF [but zBMI <3.0]) | LEAP | 1 (4) | Usual care | | | X | X | X
Wake, 2009^168, 189, 192^ Good | RCT | Australia Primary Care | 258 | 6; 12 (95.0) | 5 to 10 year olds who are overweight or have obesity but zBMI <3.0 (IOTF and UK norms) | LEAP-2 | 1 (4) | Usual care | | | X | X | X
Lifestyle-based maintenance after weight loss interventions
Davis, 2012^125^ Fair | RCT | United States Other | 61 | 8 (86.9) | Adolescent African Americans or Latinos in grades 9 to 12 who had completed initial 4-month weight loss intervention and are overweight or have obesity (≥85th percentile [CDC]) | Maintenance (Group classes) | 16 (14) | Newsletters | | | | X
Non-lifestyle behavior-based interventions
Boutelle, 2014^118^ Fair | RCT | United States Other | 44 | 8 (88.6) | 8 to 12 year olds meeting criteria for eating in the absence of hunger who are overweight or had obesity (≥ 85th percentile [CDC]) | Regulation of Cues (ROC) program | 28 (14) | Waitlist | | | | X
Tanofsky-Kraff, 2010 ^162, 179, 183^ Fair | RCT | United States Other | 38 | 6; 12 (92.1) | Adolescent girls who are overweight or have obesity (BMI 75–97th percentile [norms NR]) | IPT-Weight Gain Prevention | 17.9 (13) | Attention control (health education) | | | | X | X
Pharmacotherapy
Clarson, 2014^123^ Fair | RCT | Canada Health Care | 69 | 6; 12; 24 (68.1) | 10 to 16 year olds with obesity (BMI >95th percentile for age and sex [CDC]) | Metformin + comprehensive lifestyle | 86 (106) | Placebo + comprehensive lifestyle | | | | X | X
Wiegand, 2010^171^ Fair | RCT | Germany and Switzerland Health Care | 70 | 6 (90) | 10 to 17 year olds with obesity (>97th percentile [German norms]) at risk of developing type 2 diabetes with previous unsuccessful lifestyle intervention | Metformin + family-based lifestyle intervention | 40.8 (58) | Placebo + lifestyle intervention | | | | X | X
Wilson, 2010^172^ Fair | RCT | United States Health Care | 77 | 12 (70.1) | 13 to 18 year olds with obesity (BMI ≥95th percentile [CDC]) but weight <136 kg | Metformin + lifestyle intervention | 9.5 (19) | Placebo + lifestyle intervention | | | | X | X
Yanovski, 2011^173, 174^ Good | RCT | United States Health Care | 100 | 6 (85) | 6 to 12 year olds with insulin resistance and obesity (BMI ≥95th percentile [CDC]) | Metformin + lifestyle intervention | 3 (6) | Placebo + lifestyle intervention | | | | X | X
Love-Osborne, 2008^140^ Fair | RCT | United States Other | 85 | 6 (75.3) | 12 to 19 year olds with insulin resistance or presence of acanthosis nigricans and obesity (BMI >95 percentile [norms NR]) | Metformin + goal setting | 2.25 (6) | Placebo + goal setting | | | | X | X
Kay, 2001^134^ Fair | RCT | United States NR | 24 | 2 (NR) | Adolescents with obesity (BMI >30 [NR]) | Metformin + calorie-controlled diet | 0.5 (1) | Placebo + calorie-controlled diet | | | | | X
Evia-Viscarra, 2012^127^ Fair | RCT | Mexico Health Care | 31 | 3 (83.9) | 9 to 18 year olds with insulin resistance and obesity (BMI >95th percentile for age and sex [CDC]) | Metformin + lifestyle recommendations | 0.25 (1) | Placebo + lifestyle recommendations | | | | | X
Kendall, 2013^135^ Fair | RCT | United Kingdom Health Care | 155 | 6 (71.0) | 8 to 18 year olds with IGT or hyperinsulinemia and obesity (BMI >98th percentile [UK norms]) | Metformin + 1 individual session | 0.25 (1) | Placebo + 1 individual session | | | | X | X
Srinivasan, 2006^158^ Fair | RCT | Australia Health Care | 28 | 6 (78.6) | 9 to 18 year olds with clinical suspicion of insulin resistance or presence of acanthosis nigricans and obesity (IOTF) | Metformin + 1 individual session | 0.25 (1) | Placebo | | | | X | X
Burgert, 2008^121^ Fair | RCT | United States Health Care | 34 | 4 (82.4) | 13 to 18 years old with insulin resistance and obesity [NR] | Metformin + lifestyle recommendations | 0.25 (1) | Placebo + lifestyle recommendations | | | | | X
Freemark, 2001^128, 181^ Fair | RCT | United States Health Care | 32 | 6 (90.6) | 12 to 19 year olds with fasting hyperinsulnemia and family history of type II DM and obesity (BMI >30) | Metformin | 0 (0) | Placebo | | | | X | X
Yanovski, 2012^108, 177^ Fair | RCT | United States Health Care | 200 | 6 (85.5) | 12 to 17 year old African Americans and Caucasians with severe obesity (BMI and triceps skinfold >95th percentile [NHANES]) and ≥1 obesity-related comorbidity | Orlistat + behavioral weight loss | 15 (15) | Placebo + behavioral weight loss | | | | X | X
Chanoine, 2005^122, 175^ Fair | RCT | United States and Canada Health Care | 539 | 12 (64.7) | 12 to 16 year olds with obesity (≥2 BMI units above US mean for 95th percentile, and BMI<44) | Orlistat + Diet, PA, and Behavior Therapy | 9 (18) | Placebo + Diet, PA, and Behavior Therapy | | | | X | X
Maahs, 2006^141^ Fair | RCT | United States Other | 40 | 6 (85) | 14 to 18 year olds who are overweight or have obesity (BMI >85th percentile [norms NR]) | Orlistat + dietitian counseling | 3.5 (7) | Placebo + dietitian counseling | | | X | X | X

* Taylor, 2016 intervention involved 5 hours of contact in the first 12 months, so is included in the lowest-contact group for the meta-analysis, which included 12 months outcomes.

Abbreviations: BMI=body mass index; CCT=controlled clinical trial; CDC=Centers for Disease Control and Prevention; CDS=clinical decision support; EMR=electronic medical record; est=estimated; IGT=impaired glucose tolerance; IOTF=International Obesity Task Force; IPT=interpersonal therapy; KQ=Key Question; MI=motivational interviewing; NHANES=National Health and Nutrition Examination Survey; NR=not reported; PA=physical activity; PCP=primary care physician; RCT=randomized, controlled trial; RD=registered dietitian; SG-CRCT=single group cluster randomized controlled trial; UK=United Kingdom; zBMI=body mass index z score.

Table 7 Population Characteristics of Treatment Studies, Grouped by Intervention Type, Sorted by Descending Estimated Intervention Contact Hours (KQs 3–5)

Author, Year and Quality | Recruitment | Age range (mean) | Mean Baseline BMI and zBMI | % Female | % Race/Ethnicity
Behavior-based interventions
Lison, 2012^137^ Fair | NR | 6–16 (11.9) | 29.1 2.13 | 49.1 | Black: NR Latino: NR Native Amer: NR White: 100
Weigel, 2008^170^ Fair | Mixed | 7–15 (11.2) | 28.6 2.36 | 54.8 | Black: NR Latino: NR Native Amer: NR White: NR
Savoye, 2007^156^ Fair | NR | 8–16 (12.1) | 36.0 NR | 60.9 | Black: 38.5 Latino: 24.7 Native Amer: NR White: 36.8
Savoye, 2014^155^ Fair | Clinician referral | 10–16 (12.9) | 33.3 2.2 | 65.3 | Black: 28 Latino: 36 Native Amer: NR White: 20
Reinehr, 2006^149^ Fair | Other | 6–14 (10.4) | 26.9 2.4 | 46.7 | Black: NR Latino: NR Native Amer: NR White: NR
Reinehr, 2009^150^ Fair | Not reported | 10–16 (12.6) | NR 2.46 | 56.1 | Black: NR Latino: NR Native Amer: NR White: NR
Reinehr, 2010^151^ Fair | Mixed | 8–16 (11.5) | 23.8 1.66 | 60.6 | Black: NR Latino: NR Native Amer: NR White: NR
Vos, 2011^167^ Fair | Clinician referral | 8–17 (13.2) | 32.5 4.3 | 53.2 | Black: NR Latino: NR Native Amer: NR White: NR
Kalarchian, 2009^132^ Fair | NR | 8–12 (10.19) | 32.12 NR | 56.8 | Black: 26 Latino: 1 Native Amer: 0 White: 73.4
Kalavainen, 2007^133^ Fair | Mixed | 6–9 (8.1) | 23.2 2.6 | 60 | Black: NR Latino: NR Native Amer: NR White: NR
Stark, 2011^160^ Fair | Screening (population-based) | 2–5 (4.1) | NR NR | 33.3 | Black: NR Latino: 16.7 Native Amer: NR White: 83.3
Croker, 2012^124^ Fair | Clinician referral | 8–12 (10.3) | 30.6 3.2 | 69.4 | Black: 19.4 Latino: NR Native Amer: NR White: 56.9
DeBar, 2012^126^ Good | Clinician referral | 12–17 (14.1) | 31.9 2.00 | 100 | Black: NR Latino: NR Native Amer: NR White: 72.1
Sacher, 2010^153^ Fair | Mixed | 8–12 (10.3) | 27.2 2.77 | 54.3 | Black: NR Latino: NR Native Amer: NR White: 50
Nemet, 2005^144^ Fair | Volunteer | 6–16 (11.1) | 28.2 NR | 43.5 | Black: NR Latino: NR Native Amer: NR White: NR
Stark, 2014^159^ Fair | Screening (population-based) | 2–5 (4.5) | NR 2.4 | 65.2 | Black: NR Latino: NR Native Amer: NR White: 82.6
Bryant, 2011^120^ Fair | Mixed | 8–16 (11.4) | NR 2.99 | 64.3 | Black: 4.3 Latino: NR Native Amer: NR White: 87.1
Mellin, 1987^143^ Fair | Mixed | 12–18 (15.6) | NR NR | 78.8 | Black: 3 Latino: 7.6 Native Amer: NR White: 88
Golley, 2007^130^ Fair | Other | 6–9 (8.2) | 24.3 2.75 | 63.1 | Black: NR Latino: NR Native Amer: NR White: 98
Hofsteenge, 2014^131^ Fair | Clinician referral | 11–18 (14.5) | 33.4 2.93 | 55.7 | Black: NR Latino: NR Native Amer: NR White: NR
Gerards, 2015^129^ Fair | Mixed | 4–8 (7.21) | 20.5 1.84 | 55.8 | Black: NR Latino: NR Native Amer: NR White: NR
Nowicka, 2008^146^ Fair | Clinician referral | 12–19 (14.7) | 34.5 3.25 | 50 | Black: NR Latino: NR Native Amer: NR White: NR
Boudreau, 2013^117^ Fair | Clinician referral | 9–12 (10.3) | NR 2.1 | 61.5 | Black: NR Latino: 100 Native Amer: NR White: NR
Norman, 2015^145^ Fair | Mixed | 11–13 (11.9) | 29.3 2.1 | 50.9 | Black: 3.8 Latino: 82.1 Native Amer: NR White: 7.5
Taylor, 2015^165^ Good | Screening (population-based) | 4–8 (6.5) | 19.4 1.63 | 55.3 | Black: NR Latino: NR Native Amer: NR White: NR
Raynor, 2012a^148^ Fair | Mixed | 4–9 (7.2) | NR 2.32 | 61.4 | Black: NR Latino: 18.8 Native Amer: NR White: 86.1
Raynor, 2012b^148^ Fair | Mixed | 4–9 (7.1) | NR 2.27 | 60.5 | Black: NR Latino: 11.1 Native Amer: NR White: 90.1
Kong, 2013^136^ Fair | Volunteer | NR (14.8) | NR NR | 58.8 | Black: NR Latino: 68.6 Native Amer: 5.9 White: NR
Stettler, 2014^161^ Fair | Screening (population-based) | 8–12 (10.8) | 21.6 1.24 | 52.3 | Black: 42.4 Latino: 6.4 Native Amer: NR White: 52.9
Saelens, 2002^154^ Fair | Mixed | 12–16 (14.2) | 30.7 2.07 | 40.9 | Black: 4.5 Latino: 15.9 Native Amer: NR White: 70.5
Broccoli, 2016^119^ Good | Screening (population-based) | 4–7 (6.6) | 18.25 1.35 | 61.6 | Black: NR Latino: NR Native Amer: NR White: NR
O’Connor, 2013^147^ Fair | Mixed | 5–8 (6.8) | NR NR | 80 | Black: 12.5 Latino: 82.5 Native Amer: NR White: 5
Sherwood, 2015^157^ Fair | Clinician referral | 2–4 (2.75) | NR 0.94 | 45 | Black: NR Latino: 7 Native Amer: NR White: 80
Taveras, 2011^163^ Good | Screening (population-based) | 2–6 (4.9) | 19.2 1.85 | 48.3 | Black: 18.9 Latino: 16.6 Native Amer: NR White: 56.6
Love-Osborne, 2014^139^ Fair | NR | 12–18 (15.9) | 31.7 1.90 | 52.1 | Black: NR Latino: 88.5 Native Amer: NR White: NR
Looney, 2014^138^ Fair | Mixed | 4–10 (8.0) | NR 2.34 | 68.2 | Black: 4.5 Latino: 9.1 Native Amer: NR White: 72.7
Resnicow, 2015^152^ Fair | Clinician referral | 2–8 (5.1) | NR NR | 57.1 | Black: 6.6 Latino: 21.6 Native Amer: NR White: 60.0
Wake, 2013^169^ Good | Screening (population-based) | 3–10 (7.3) | 22.5 2.2 | 54.2 | Black: NR Latino: NR Native Amer: NR White: NR
Van Grieken, 2013^166^ Fair | Screening (population-based) | 5 (5.8) | 18.13 NR | 61.9 | Black: NR Latino: NR Native Amer: NR White: NR
Taveras, 2015^164^ Good | Screening (population-based) | 6–12 (9.8) | 25.8 2.06 | 46.8 | Black: 21.1 Latino: 14 Native Amer: NR White: 51.2
McCallum, 2007^142^ Good | Screening (population-based) | 5–9 (7.4) | 20.3 1.9 | 51.5 | Black: NR Latino: NR Native Amer: NR White: NR
Wake, 2009^168^ Good | Screening (population-based) | 5–10 (7.5) | 20.2 1.9 | 60.5 | Black: NR Latino: NR Native Amer: NR White: NR
Davis, 2012^125^ Fair | Volunteer | NR (15.7) | 34.9 2.2 | 54.7 | Black: NR Latino: NR Native Amer: NR White: NR
Boutelle, 2014^118^ Fair | Volunteer | 8–12 (10.2) | 27.3 2.10 | 50 | Black: NR Latino: NR Native Amer: NR White: 69.1
Tanofsky-Kraff, 2010^162^ Fair | Mixed | NR (15.1) | 25.4 1.3 | 100 | Black: 47.4 Latino: 5.3 Native Amer: NR White: 36.8
Pharmacotherapy
Clarson, 2014^123^ Fair | Mixed | 10–16 (13.7) | 32.5 2.17 | 58 | Black: 2.9 Latino: NR Native Amer: 4.3 White: 76.8
Wiegand, 2010^171^ Fair | Screening (population-based) | 10–17 (15.0) | 34.88 NR | 67.1 | Black: NR Latino: NR Native Amer: NR White: 88.6
Wilson, 2010^172^ Fair | NR | 13–18 (14.9) | 35.9 2.29 | 66.2 | Black: 18.2 Latino: 23.4 Native Amer: NR White: 63.6
Yanovski, 2011^173^ Good | Mixed | 6–12 (10.2) | 34.4 2.57 | 60 | Black: 40 Latino: 11 Native Amer: NR White: 45
Love-Osborne, 2008^140^ Fair | Mixed | 12–19 (15.7) | 39.7 NR | 71 | Black: 34 Latino: 58 Native Amer: NR White: NR
Kay, 2001^134^ Fair | NR | NR (15.6) | 41.0 NR | 62.5 | Black: NR Latino: NR Native Amer: NR White: 100
Evia-Viscarra, 2012^127^ Fair | NR | 10.1–16.6 (13.4) | 33.1 NR | 65.4 | Black: NR Latino: NR Native Amer: NR White: NR
Kendall, 2013^135^ Fair | Screening (population-based) | 8–18 (13.7) | 36.5 3.4 | 67.5 | Black: 1.3 Latino: NR Native Amer: NR White: 76.2
Srinivasan, 2006^158^ Fair | Screening (population-based) | 9–18 (12.5) | 35.2 2.43 | 53.6 | Black: NR Latino: NR Native Amer: NR White: 25
Burgert, 2008^121^ Fair | Other | 13–18 (15) | 40.5 NR | 67.9 | Black: 25 Latino: 17.9 Native Amer: NR White: 57.1
Freemark, 2001^128^ Fair | Volunteer | 12–19 (14.9) | 40.0 NR | 62.1 | Black: 44.8 Latino: NR Native Amer: NR White: 55.2
Yanovski, 2012^108^ Fair | NR | 12–17 (14.59) | 41.7 NR | 65.5 | Black: 61.5 Latino: 0 Native Amer: 0 White: 38.5
Chanoine, 2005^122^ Fair | Mixed | 12–16 (13.6) | 35.6 NR | 67 | Black: 16.9 Latino: NR Native Amer: NR White: 76
Maahs, 2006^141^ Fair | Mixed | 14–18 (15.8) | 40.4 NR | 67.5 | Black: NR Latino: 62.5 Native Amer: NR White: NR

Abbreviations: Amer=American; BMI=body mass index; NR=not reported; zBMI=body mass index z score.

Of the 45 trials (n=7,099) of behavior-based interventions (Table 8), 42 (n=6,956) used counseling on diet, physical activity, and behavior change management with the aim of reducing excess weight in young persons, either through weight loss or limiting further weight gain as the child grows, and all reported weight outcomes.^117, 119, 120, 124, 126, 129–133, 136–139, 142–157, 159–161, 163–170^ We refer to these as “lifestyle-based weight loss trials.” An additional trial assessed the benefits of a weight maintenance program for high schoolers who had completed a 4-month weight loss intervention.^125^ Two additional trials provided interventions with minimal focus on general diet and physical activity, and instead focused on limiting overeating by using a “regulation of cues” intervention (based on appetite awareness and cue exposure treatment)^118^ and on interpersonal issues as a source of excess weight gain.^162^ These last three trials will be discussed separately from the lifestyle-based weight loss trials.

Table 8 Intervention Characteristics of Behavior-Based Trials Included for Treatment Benefit (KQs 3-5)

Author, Year Quality Age Group | Intervention | Description | Delivery | Format | Target | # Sessions and Session Length (min) | Duration (months) | Est hours | Provider | Role of PCP
Lison, 2012^137^ Fair Wide range | Hospital-based group exercise (IG1) | 2 1-hr parent/child lifestyle education sessions with behavior change strategies; 120 1-hr group PA sessions (offered 5 times/week, families encouraged to attend at least 3 sessions/week) | In Person | Group PA sessions | Child, Family | 122 | 6 | 122 | Pediatrician (education sessions), PE instructor (exercise sessions) | No role
Lison, 2012^137^ Fair Wide range | Home-based exercise (IG2) | 2 1-hr parent/child lifestyle education sessions with behavior change strategies and Mediterranean diet focus; detailed home-based PA plan with demonstration, written instructions, and log | In Person, Print | Individual PA sessions | Child, Family | 2 60 | 6 | 2 | Pediatrician (education sessions), PE instructor (assumed, exercise demonstration) | No role
Weigel, 2008^170^ Fair Wide range | Sea Lion Club | Twice weekly 45- to 60-min child group sessions for 12 months, including PA, dietary education, and coping strategies; 12 separate monthly 2-hour parent support meetings that included some parent-child activities | In Person | Group PA sessions | Parent, Child, Family | 104 45–60 (child), 120 (parent) | 12 | 114.1 | Dietitians, psychologists, sports coaches | No role
Savoye, 2007^156^ Fair Wide range | Bright Bodies | 26 weekly nutrition education and behavioral management sessions using Smart Moves Workbook, twice-weekly physical activity sessions tapering to twice-monthly after 6 months | In Person, Print | Group PA sessions | Parent, Child, Family | 64 40 (diet + behavioral), 50 (PA, 1st 6m), 100 (PA, 2nd 6m) | 12 | 82.33 | Dietitian or social worker; exercise physiologists | No role
Savoye, 2014^155^ Fair Wide range | Bright Bodies | 26 weekly nutrition education and behavioral management sessions using Smart Moves Workbook; twice-weekly physical activity sessions tapering to twice-monthly after 6 months; 26 parent support sessions | In Person | Group PA sessions | Parent, Child, Family | 52 50 (exercise), 40 (therapy) | 6 | 78 | Dietitian, physical therapist | No role
Reinehr, 2006^149^ Fair Wide range | Obeldicks | Intensive year-long comprehensive program; 9-session parent group course, 6-session behavior therapy and nutrition education groups for children, weekly PA sessions, 6 individual family therapy sessions (more as needed) | In Person | Group, Individual PA sessions | Parent, Child, Family | 52 90 (group sessions), 30 (individual family), 60 (PA) | 12 | 77.5 | Pediatrician, dietitian, psychologist, exercise physiologist | No role
Reinehr, 2009^150^ Fair Wide range | Obeldicks | Intensive year-long comprehensive program; 9-session parent group course, 6-session behavior therapy and nutrition education groups for children, weekly PA sessions, 3 individual family therapy sessions (more as needed) | In Person | Group, Individual PA sessions | Parent, Child, Family | 52 90 (group sessions), 30 (family), 60 (PA) | 12 | 77.5 | Pediatricians, diet assistants, psychologists, and exercise physiologists | No role
Reinehr, 2010^151^ Fair Wide range | Obeldicks light | 37 child sessions, 6 parent sessions, 5 child+parent sessions; PA training, nutrition education, and behavior counseling performed in group sessions with individual counseling for child and family | In Person | Group, Individual PA sessions | Parent, Child, Family | 37 PA: 90; parent: 90; individual child/parent counseling: 30 | 6 | 67 | Pediatricians, diet assistants, psychologists, exercise physiologists | No role
Vos, 2011^167^ Fair Wide range | Family-based multi-disciplinary lifestyle intervention | 2 individual family assessment and advice visits followed by 7 2.5-hr group comprehensive behavioral lifestyle meetings, parents and children usually separate, plus 2 to 3 booster group sessions yearly | In Person | Group, Individual PA sessions | Parent, Child, Family | 19 150 (group) 180–270 (individual) | 24 | 46.25 | Dietician, child physiotherapist, child psychologist, social worker | No role
Kalarchian, 2009^132^ Fair Elementary | Family-based lifestyle intervention | 20 60-min separate adult and child group sessions including weekly family meeting with lifestyle coach; adult also set goals, modeled behavior change; 6 booster sessions (3 group, 3 phone) | In Person, Phone | Group, Individual | Parent, Child, Family | 26 60 | 12 | 43.75 | Lifestyle coach | No role
Kalavainen, 2007^133^ Fair Elementary | Health-promoting lifestyle | 15 90-min group sessions, parents and children mostly separate; parents targeted as main agents of change; interactive activities and PA for children; manuals for parents, workbooks for children and homework assigned | In Person, Print | Group PA sessions | Parent, Child, Family | 15 90 | 6 | 43.5 | Dietitian (parent sessions); advanced clinical nutrition students (child sessions) | No role
Stark, 2011^160^ Fair Preschool | LAUNCH | 9 clinic-based 90-min comprehensive behavioral lifestyle group sessions for parents and children separately plus 9 home visits; vegetable taste tests, pedometers, parents received 2 weeks worth of vegetables, child sessions included 15-min PA | In Person | Group, Individual | Parent, Child, Family | 18 90 (clinic), 60–90 (in-home) | 6 | 38.25 | Licensed clinical psychologist, post doc and research coordinator | No role
Croker, 2012^124^ Fair Elementary | Family-based behavioral therapy | 15 90-min comprehensive multicomponent family-based behavioral therapy group sessions, parents and children meeting separately for 10 sessions and together for 5 sessions | In Person | Group | Parent, Child, Family | 15 90 | 6 | 37.5 | Psychologist, family therapist, dietitian | No role
DeBar, 2012^126^ Good Adolescent | Multi-component behavioral intervention | 16 90-min group developmentally-tailored multicomponent behavioral intervention sessions for adolescent girls; 12 with concurrent parent sessions; trained PCP to support behavioral weight management goals; 2 PCP meetings | In Person, Phone | Group, Individual PA sessions | Parent, Child | 18 90 (group), NR, est 15 min (PCP) | 5 | 36.5 | Nutritionists, health educators and clinical psychologists; primary care physicians | Participated in intervention
Sacher, 2010^153^ Fair Elementary | MEND | 18 2-hr family-based multicomponent behavioral healthy lifestyle group sessions targeting education, skills training, and motivational enhancement; included 1-hr PA sessions in 16 of the sessions; free access to community pool | In Person, Print | Group PA sessions | Child, Family | 18 120 | 2.25 | 36 | MEND leaders, assistant | No role
Nemet, 2005^144^ Fair Wide range | Dietitian + PA sessions | 4 evening lectures for parents, 6 dietician meetings, and twice-weekly PA sessions for 3 months | In Person, Print | Group, Individual PA sessions | Parent, Child, Family | 34 45 (dietician), 60 (exercise + lectures) | 3 | 32.5 | Physicians, dieticians, youth coaches | Participated in intervention
Stark, 2014^159^ Fair Preschool | LAUNCH-clinic | 10 90-min comprehensive behavioral lifestyle group sessions for parents and children separately; vegetable taste tests, pedometers, parents received 2 weeks worth of vegetables, child sessions included 15-min of moderate-to-vigorous PA | In Person | Group, Individual | Parent, Child | 10 90 | 6 | 30 | Clinical psychologist, pediatric psychologist, research coordinator | No role
Bryant, 2011^120^ Fair Wide range | WATCH IT | 16 weekly 30-min individual sessions for support and encouragement and 1-hr PA group sessions; motivational enhancement and solution-focused approach to lifestyle change | In Person | Group, Individual PA sessions | Child, Family | 16 30 (individual, parent), 60 (group PA) | 12 | 24 | Nonprofessional health trainers, support and supervision by nurse, dietician, psychologist, + pediatrician | No role
Mellin, 1987^143^ Fair Adolescent | SHAPEDOWN | 14 90-minute weekly group adolescent sessions and 2 90-minute parent sessions plus separate workbooks for parent and adolescent; focus on successive, sustainable, small lifestyle modifications | In Person, Print | Group PA sessions | Parent, Child | 16 90 | 3 | 24 | Nutritionists | No role
Golley, 2007^130^ Fair Elementary | Triple P + healthy lifestyle group (IG1) | 4 2-hr group sessions and 7 individual phone calls aimed at changing parenting practices and general parenting styles, and 7- session behavioral healthy lifestyle group for parents and concurrent child PA sessions | In Person, Phone, Print | Group, Individual PA sessions | Parent, Child | 18 2 hours (group parenting), 15–20 minutes (calls) | 5 | 23.75 | Dietitian | No role
Golley, 2007^130^ Fair Elementary | Triple P (IG2) | 4 2-hr group sessions and 7 individual phone followup sessions aimed at changing parenting practices and general parenting styles (no behavioral lifestyle component); workbook, and healthy lifestyle pamphlet | In Person, Phone, Print | Group, Individual | Parent | 11 2 hours (group), 15–20 minutes (phone) | 5 | 9.75 | Dietitian | No role
Hofsteenge, 2014^131^ Fair Wide range | Go4it | 7 90-min group sessions plus 2 booster sessions covering diet, PA, and cognitive behavior therapy for adolescents; 2 separate parent sessions | In Person, Print | Group | Parent, Child | 11 90 | 6 | 16.5 | Dietician, pediatrician/endocrinologist, psychologist | No role
Gerards, 2015^129^ Fair Elementary | Lifestyle Triple P | 10 90-minute group sessions and 4 individual 15–30 minute phone sessions aimed at changing parenting practices and styles with specific strategies around lifestyle change; workbook, recipes and active games booklet | In Person, Phone, Print | Group, Individual | Parent | 14 90 (group), 15–30 (telephone) | 3.5 | 16.5 | Health professionals (not further specified) | No role
Nowicka, 2008^146^ Fair Adolescent | Family Weight School | 4 4-hr family group comprehensive behavioral lifestyle meetings, emphasizing communication skills, mutual support, consistency, establishing appropriate limits; 10-min individual meeting with pediatrician each session | In Person | Group, Individual | Parent, Child, Family | 4 240 (including 10-min individual PCP session) | 12 | 16 | Pediatrician, dietician/sports trainer, pediatric nurse, family therapist | Participated in intervention
Boudreau, 2013^117^ Fair Elementary | PowerUp + coaching | 6 90-minute PowerUp classes (separate, interactive group sessions for children and caregivers) covering nutrition, PA, and stress management, plus 6 monthly individual culturally-sensitive health coaching sessions | In Person, Phone | Group, Individual PA sessions | Parent, Child, Family | 12 90 | 6 | 10.5 | Health educator, physical therapist, nutritionist, and primary care pediatrician | Participated in intervention
Norman, 2015^145^ Fair Wide range | Stepped-down Care | Stepped-down care: tailored to progress of individual participants in achieving weight loss goals | In Person, Phone, Print | Individual | Parent, Child | 27 NR | 13 | 8.25 | Physician, health education counselor | Participated in intervention
Taylor, 2015^165^ Good Elementary | Tailored lifestyle support | 1 individual 1- to 2-hour multidisciplinary session with parents followed by 16 brief contacts for tailored behavioral lifestyle change support | In Person, Phone | Individual | Parent | 14 60–120 (multi-disciplinary consult), 30–40 (in-person visits), 5–10 (phone calls) | 24 | 7.2 | Mentor, nutritionist/dietician, exercise specialist/trainer, clinical psychologist | No role
Raynor, 2012a^148^ Fair Elementary | DECREASE + Growth Monitoring (IG1) | 8 45-min parent group sessions covering behavioral strategies to decrease high-calorie non-nutrient dense foods; growth assessed at 0, 3, and 6 months with accompanying letter providing anthropometric information and interpretation | In Person | Group | Parent | 8 45 | 6 | 6 | Research-staff therapist (master or doctoral-level with expertise in nutrition or exercise and behavior modification) | No role
Raynor, 2012a^148^ Fair Elementary | INCREASE + Growth Monitoring (IG2) | 8 45-min parent group sessions covering behavioral strategies to increase healthy food intake; growth assessed at 0, 3, and 6 months with accompanying letter providing anthropometric information and interpretation | In Person | Group | Parent | 8 45 | 6 | 6 | Research-staff therapist (master or doctoral-level with expertise in nutrition or exercise and behavior modification) | No role
Raynor, 2012b^148^ Fair Elementary | TRADITIONAL + Growth Monitoring (IG1) | 8 45-minute parent group sessions covering behavioral strategies to increase PA and reduce sugar-sweetened beverage consumption; growth assessed at 0, 3, and 6 months with accompanying letter providing anthropometric information and interpretation | In Person | Group | Parent | 8 45 | 6 | 6 | Research-staff therapist (master or doctoral-level with expertise in nutrition or exercise and behavior modification) | No role
Raynor, 2012b^148^ Fair Elementary | SUBSTITUTES + Growth Monitoring (IG2) | 8 45-minute parent group sessions covering behavioral strategies to increase low-fat milk and decrease TV as substitute behaviors; growth assessed at 0, 3, and 6 months with accompanying letter providing anthropometric information and interpretation | In Person | Group | Parent | 8 45 | 6 | 6 | Research-staff therapist (master or doctoral-level with expertise in nutrition or exercise and behavior modification) | No role
Kong, 2013^136^ Fair Adolescent | ACTION | Initial MI visit with PCP and student to review medical history/lab results, assess diet and PA, receive DVD; 7 followup MI visits with PCP to discuss DVD and work toward healthy lifestyle goals; newsletter and 8 post-visit MI calls to parents/caregivers | In Person, Phone, Electronic, Print | Individual | Parent, Child | 16 47 (mean, 1st session), 24 (mean, subsequent sessions) | 9 | 4.25 | School-based health center clinician (family medicine nurse practitioner) | Participated in intervention
Stettler, 2014^161^ Fair Elementary | Multiple-behavior change (IG1) | 12 15- to 25-min sessions targeting healthy beverages, increased PA, and reduced sedentary activity, incorporating behavior change techniques | In Person | Individual | Family | 12 15–25 | 12 | 4 | Trained primary care clinician | Participated in intervention
Stettler, 2014^161^ Fair Elementary | Combined (IG2) | 12 15–25 min sessions incorporating behavior change techniques targeting healthy beverages, increased PA, and reduced sedentary activity (IG2), or targeting health beverage consumption only (IG3) | In Person | Individual | Family | 12 15–25 | 12 | 4 | Trained primary care physician | Participated in intervention
Stettler, 2014^161^ Fair Elementary | Beverage-only intervention (IG3) | 12 15–25 min sessions to reduce intake of sugary drinks and increase intake of water and milk, incorporating behavior change techniques | In Person | Individual | Family | 12 15–25 | 12 | 4 | Trained primary care clinician | Participated in intervention
Saelens, 2002^154^ Fair Adolescent | Healthy Habits Intervention | Computer assessment with 1 pediatrician session to discuss results with family; 11 phone counseling calls, 3 mailings | In Person, Phone, Electronic, Print | Individual | Child, Family | 13 Computer + pediatrician sessions NR; phone sessions 10–20 mins (average length 16.4 mins) | 4 | 3.75 | Pediatrician; phone counselors | Participated in intervention
Broccoli, 2016^119^ Good Elementary | Motivational Interviewing | 5 individual motivational interviewing sessions with parent and child and pediatrician; families decided on goals, progress discussed at subsequent meetings | In Person | Individual | Parent, Child, Family | 5 30–60 | 3 | 3.75 | Family pediatrician | Participated in intervention
O’Connor, 2013^147^ Fair Elementary | Helping HAND | 6 monthly individual family sessions with health advisors with follow-up phone call after each session; set monthly child-behavior goals with implementation plan and behavior-specific parenting practice goals | In Person, Phone | Individual | Family | 12 NR | 7 | 3.5 | Trained allied health staff “health advisors” | No role
Sherwood, 2015^157^ Fair Preschool | Busy Bodies / Better Bites | 1 brief primary care session followed by 8 15- to 30-min phone coaching sessions for goal setting and MI | In Person, Phone, Print | Individual | Parent, Child, Family | 9 NR (in-person), 15–30, average 23 (phone) | 6 | 3.32 | Pediatric primary care provider; experienced interventionists | 1-time brief message/Endorse-ment
Taveras, 2011^163^ Good Preschool | MI + enhanced EMR and training | 4 25-min in-person + 3 15-min phone motivational interviewing sessions with nurse practitioner. Pediatricians endorsed messages during well-child visits. Tailored materials, behavior monitoring tools, enhanced electronic medical record. | In Person, Phone, Electronic, Print | Individual | Family | 8 15–25 | 12 | 2.67 | Nurse practitioner (primary interventionist), pediatrician | Participated in intervention
Love-Osborne, 2014^139^ Fair Adolescent | Health educator visits | Average of 5 visits with health educator using motivational interviewing, goal-setting, self-monitoring, with or without supporting text messages; participants linked to existing resources and facilitated applications for free recreation memberships | In Person, Electronic | Individual | Child | 5 NR | 8 | 2.5 | Health educator | No role
Looney, 2014^138^ Fair Elementary | Newsletters + Growth Monitoring + Family-based Bx Counseling (IG1) | 6 20- to 30-min in-person or phone sessions for growth monitoring/feedback and caretaker behavioral counseling; 6 monthly educational newsletters on nutrition and activity; usual care from the pediatrician | In Person, Phone, Print | Individual | Parent, Child, Family | 6 30 (in-person), 20 (telephone) | 6 | 2.5 | Trained interventionist + pediatrician | No role
Looney, 2014^138^ Fair Elementary | Newsletters + Growth Monitoring (IG2) | 6 10- to 15-min in-person or phone growth monitoring sessions with standardized feedback; 6 monthly educational newsletters on nutrition and leisure-lime activity; usual care from the pediatrician | In Person, Phone, Print | Individual | Child, Family | 6 15 (in-person), 10 (telephone) | 6 | 1.25 | Trained interventionist + pediatrician | No role
Resnicow, 2015^152^ Fair Elementary | PCP + RD MI (IG1) | 4 brief MI counseling sessions by PCP + 6 MI counseling sessions from RD conducted over 2 years, targeting diet and activity behaviors | In Person, Phone, Print | Individual | Parent | 10 NR | 24 | 2.5 | PCP (pediatrician and NPs) and RD | Participated in intervention
Resnicow, 2015^152^ Fair Elementary | PCP MI (IG2) | 4 brief MI counseling sessions over 2 years conducted by PCP, targeting diet and activity behaviors | In Person, Print | Individual | Parent | 4 NR | 24 | 1 | PCP (pediatrician and NPs) | Participated in intervention
Wake, 2013^169^ Good Elementary | HopSCOTCH | 1 hour-long family visit with obesity specialist team to develop plan and goals, followed by GP visits every 4 to 8 weeks using brief solution-focused techniques; web-based software (HopSCOTCH) used to track progress and link specialist team with GP | In Person | Individual | Family | 6 60 (specialist), 20–40 (long GP), 6–20 (standard GP) | 12 | 2.5 | General practitioner, obesity specialist team (pediatrician and dietician) | Participated in intervention
Van Grieken, 2013^166^ Fair Preschool | Be Active Eat Right | Prevention protocol involving motivational interviewing during a well-child visit. 3 additional structured healthy lifestyle counseling sessions matched to parents’ stage of change could be offered. | In Person, Print | Individual | Family | 4 NR, average duration of 1st additional session, 24.76 (range, 0–60) | 12 | 2 | Youth Health Care Team (pediatrician, nurse, assistant) | Participated in intervention
Taveras, 2015^164^ Good Elementary | CDS+coaching (IG1) | Computerized clinical decision support system with point of care prompts at well-child visit, motivational interview, patient materials + 4 phone MI sessions by health coach and optional text message program | In Person, Phone, Electronic, Print | Individual | Parent, Family | 5 75 | 12 | 1.25 | Pediatrician, health coach | Participated in intervention
Taveras, 2015^164^ Good Elementary | CDS (IG2) | Computerized clinical decision support system with point of care prompts at well-child visit, motivational interview, patient materials | In Person, Electronic, Print | Individual | Family | 1 15 | 12 | 0.25 | Pediatrician | Participated in intervention
McCallum, 2007^142^ Good Elementary | LEAP | 4 GP consultations using brief solution-focused family therapy for healthy lifestyle goals; 16-page folder of materials including topic sheets, wall chart, reward stickers, and shopping tips | In Person, Print | Individual | Family | 4 “Brief” | 3 | 1 | General practitioner | Participated in intervention
Wake, 2009^168^ Good Elementary | LEAP-2 | 4 GP consultations using brief solution-focused family therapy for healthy lifestyle goals; 16-page folder of materials including topic sheets, wall chart, reward stickers, and shopping tips | In Person, Print | Individual | Family | 4 “Brief” | 3 | 1 | General practitioner | Participated in intervention
Davis, 2012^125^ Fair Adolescent | Maintenance (Group classes) | 8 90-min group classes for adolescents after completion of weight loss program, reinforcing the content previously covered; 4 additional motivational telephone calls to explore and resolve ambivalence; separate parent classes, asked to attend 2 | In Person, Phone | Group, Individual PA sessions | Parent, Child | 14 15 (phone), 90 (group) | 8 | 16 | Trained research staff | No role
Boutelle, 2014^118^ Fair Elementary | Regulation of Cues (ROC) program | 14 group session behavioral counseling based on appetite awareness and cue exposure treatment; core components included psychoeducation, parenting skills, coping skills, self-monitoring of hunger and cravings, and experiential learning | In Person, Print | Group | Parent, Child, Family | 14 45 (separate child and parent groups); 30 (joint child and parent) | 4 | 28 | Doctoral-level psychologists assisted by masters-level cotherapists and undergraduate volunteers | No role
Tanofsky-Kraff, 2010^162^ Fair Adolescent | IPT-Weight Gain Prevention | 12 75- to 90-min interpersonal psychotherapy (IPT) group meetings + individual 1.5-hr pre-group meeting; overeating and loss-of-control eating linked to interpersonal functioning | In Person | Group, Individual | Child | 13 1.5 hours (individual), 75–90 (group) | 3 | 17.9 | Psychologist, graduate student | No role

Abbreviations: CDS=clinical decision support; DVD=digital video disc; est=estimated; GP=general practitioner; HD=healthful diet; hr=hour(s); IG=intervention group; indiv=individual; IPT=interpersonal therapy; m=month(s); MI=motivational interviewing; min=minute(s); msg=message; NP=nurse practitioner; NR=not reported; PA=physical activity; PCP=primary care physician; PE=physical education; pt=participant; RD=registered dietitian; TV=television.

Of the included behavior-based intervention trials, only seven were included in the previous review.^130, 142–144, 149, 154, 156^ Six trials that had been included in the previous review were excluded from the current review, four because they were not conducted in or recruited from a health care setting^218–221^ and two due to quality concerns.^222, 223^ Both of the included orlistat trials were included in the previous review,^122, 141^ and we found no new trials of orlistat in adolescents. We carried forward all three of the metformin trials that were included in the previous review^128, 140, 158^ and identified seven newly published trials, including three used only for the KQ related to harms.^121, 127, 134, 135, 171–173^

### KQ 1 Do Screening Programs for Obesity in Children and Adolescents Reduce Excess Weight or Age-Associated Excess Weight Gain, Improve Health Outcomes During Childhood, or Reduce Obesity in Adulthood? a) Are There Effects of Screening on Cardiometabolic Measures? b) Are There Common Components of Efficacious Screening Programs? c) Does Efficacy Differ by Key Patient Subgroups?

We found no studies meeting our inclusion criteria that addressed the benefits of screening for obesity.

### KQ 2 Does Screening for Obesity in Children and Adolescents Have Adverse Effects?

We found no studies meeting our inclusion criteria that addressed the harms of screening for obesity.

### KQ 3 Do Weight Management Interventions for Children and Adolescents That Are Primary Care–Feasible or Referable From Primary Care Improve Health Outcomes During Childhood or Reduce Incidence of Obesity in Adulthood? a) Does Efficacy Differ by Key Patient Subgroups? b) Are There Common Components of Efficacious Interventions?

#### Behavior-Based Interventions

Eleven trials reported results of behavior-based interventions on a health outcome, specifically measures of quality of life or functioning, self-esteem or body self-esteem, and depression (Appendix D Table 1).^117, 126, 131, 132, 142, 153, 160, 165, 167–169^ All of these were lifestyle-based weight loss trials. No trials reported other health outcomes, such as orthopedic pain, sleep apnea, or morbidity associated with type 2 diabetes or hypertension. None of the trials offering 52 or more hours of estimated intervention contact reported health outcomes. Across all health outcomes, few trials reported group differences, but where differences were found, interventions involved 26 or more contact hours in all cases.

Ten of these trials reported measures of health-related quality of life and/or functioning using the Pediatric Quality of Life Inventory,^117, 126, 131, 142, 160, 165, 168, 169^ the Child Health Questionnaire,^131, 132^ and DISABKIDS.^167^ Results at the followup closest to 12 months are shown in Figure 4 for the seven studies with sufficient data to show in a forest plot. All of these trials involved 1 to 45 hours of intervention contact, and most trials did not find greater improvement in intervention versus control group participants, including the three trials that are not shown in the figure due to insufficient data.^117, 168, 169^ Only two trials found greater improvement in the intervention group at any followup. One very small (n=18) U.S. primary care-based trial in 2- to 5-year-olds with 38 hours of intervention contact reported greater improvements in parent-reported physical functioning at 6 and 12 months (10- and 14-point improvements at 6 and 12 months, respectively, in the intervention group vs. 2- and 3-point declines, respectively, in the control group, on a 100-point scale).^160^ Another U.S. trial, which targeted 8- to 12-year olds and involved an estimated 44 hours of intervention contact, reported greater improvements in parent-reported global health score at 6 but not 12 months of followup.^132^

Figure 4 Forest Plot of Change in Quality of Life and Functioning in Behavior-Based Intervention Trials (KQ 3)

Abbreviations: BL=baseline; CG=control group; CHQ=Child Health Questionnaire; CI=confidence interval; diff=difference; est=estimated; hrs=hours; IG=intervention group; PEDsQL=Pediatric Quality of Life; tx=treatment.

This figure is a forest plot of change in quality of life and functioning in behavior-based intervention trials, stratified by quality of life instrument

Measures of self-esteem or self-perception were assessed in five trials using variants of the Harter Scale^142, 153, 168, 169^ or the Rosenburg Self-Esteem Scale.^126^ Statistically significant differences between groups were reported for only one trial, which reported improvements of 0.4 and 0.1 points for the intervention and control group, respectively, on a 4-point scale.^153^ Contact hours were estimated at 36 hours for this trial. Similarly, five trials reported an outcome related specifically to body satisfaction or esteem,^126, 131, 142, 168, 169^ and only one reported greater improvement in the intervention group, in a trial of adolescent females who received an estimated 37-hour intervention.^126^

Finally, one trial reported on depression but found no difference between groups in the proportion screening positive on the Patient Health Questionnaire for Adolescents (7.3% vs. 5.3% in the intervention vs. control group).^126^

Given the sparse reporting, wide range of specific outcomes reported, and low variability in effect sizes, data were insufficient to examine the association between effect size and treatment components (KQ 3a) or patient characteristics (KQ 3b).

#### Pharmacotherapy Interventions

Only one of 11 pharmacotherapy trials reported quality of life measures.^141^ This was an orlistat study that reported no quality of life differences between orlistat and placebo groups at 6 months. No other health outcomes were reported.

### KQ 4 Do Weight Management Interventions for Children and Adolescents That Are Primary Care–Feasible or Referable From Primary Care Reduce Excess Weight or Age-Associated Excess Weight Gain? a) Do Weight Management Interventions Affect Cardiometabolic Measures? b) Are There Common Components of Efficacious Interventions? c) Does Efficacy Differ by Key Patient Subgroups?

#### Lifestyle-Based Weight Loss Programs

##### Study Characteristics

Of the 42 lifestyle-based weight loss trials, 50 percent were conducted in the United States and the remaining trials in Europe, Australia, or Israel. Most trials were conducted in primary care (43%) or another health care setting (43%); the others involved health care–based recruitment but the intervention took place outside of a health care setting. Twenty-six percent of the studies used screening to identify patients for recruitment, and an additional 21 percent recruited exclusively through clinician referral, in which the clinician identified children in need of weight management through any means without necessarily using a systematic screening approach. Most of the remaining studies used multiple recruitment strategies, usually including at least clinician referral and solicitation of community volunteers through media advertising.

##### Populations

Most trials included children with obesity or both children with obesity and those who were overweight according to published CDC, IOTF, or country-specific norms. Five of the trials specifically targeted youth who were overweight but did not have obesity.^119, 151, 157, 161, 166^ In addition, five trials targeted children who had more severe obesity (≥97th or 98th percentile for their age and sex),^120, 132, 149, 153, 170^ although only one trial was based on CDC norms.^132^ Across all 33 lifestyle-based weight loss trials that reported baseline zBMI, the mean value ranged from 0.94 to 4.3 and the weighted average zBMI was 2.3. The 85th percentile for age and sex corresponds to a zBMI of 1.036 and the 95th percentile to a zBMI of 1.645, according to CDC norms (Table 1). Average weighted baseline BMIs were 18.7 kg/m^2^ in trials of preschool-aged children, 23.5 kg/m^2^ in trials of elementary-aged children, and 32.2 kg/m^2^ in trials of adolescents.

The included lifestyle-based weight loss trials covered the full age range, including children as young as 2 years^159, 160, 163^ up to age 18^131, 139, 143^ or 19 years.^146^ Almost half of the trials were limited to elementary-aged children, generally from age 6 to 8 years up to age 12 years, and an additional 28 percent included a range covering both prepubescent children and adolescents. Six studies targeted adolescents only^126, 136, 139, 143, 146, 154^ and five targeted preschool- to kindergarten-aged children.^157, 159, 160, 163, 166^ One trial was limited to girls only^126^ and the remaining trials included both boys and girls (median percent female, 56.1%). Most trials either failed to report the race/ethnicity breakdown of their sample or had a predominantly white sample. One study, however, targeted Latino 9- to 12-year-olds,^117^ and four others included samples that were majority Latino.^136, 139, 145, 147^ Black children were not widely represented; however, in four studies, 26 to 42 percent of participants were black.^132, 155, 156, 161^

##### Interventions

All of the lifestyle-based weight loss trials specifically reported providing at least dietary counseling and some information about behavior change principles, and most also explicitly stated that they also provided information or counseling regarding physical activity or sedentary behavior. The number of sessions ranged from one to 122 and contact hours ranged from an estimated 0.25 to 122 hours over 2.25 to 24 months. Many of the most intensive interventions included supervised physical activity sessions and usually included group meetings, with or without individual parent or family meetings as well. These more intensive group interventions frequently involved separate groups for parents and children, as well as joint activities. In addition to providing practical information on topics such as healthy eating, safe exercising, and reading food labels, these interventions typically incorporated behavior change techniques such as goal setting, monitoring diet and activity behaviors, and problem-solving. The lowest-intensity interventions (<6 contact hours) did not include group sessions. These interventions were frequently conducted in primary care settings with the involvement of the primary care provider and, in several cases, included motivational interviewing by the primary care provider or another healthy lifestyle counselor.^119, 136, 139, 152, 157, 163, 164, 166^

For studies with multiple active intervention arms, we selected the most intensive or comprehensive intervention arm for analysis. Additional intervention arms are shown in Appendix D Table 2 but are not shown in the forest plots or tables.

Most trials reported some measure of adherence. When reported, the average percent of sessions completed generally ranged from the mid-60s to low-80s,^124, 126, 132, 138, 143, 146, 148, 152, 154, 157, 161, 165^ and the percentage of participants who attended each session ranged from 79 to 87 percent in four trials reporting this outcome.^117, 133, 153, 170^ The percentage completing all sessions varied considerably; in two trials offering four visits with participants’ primary care providers, only 37 percent^168^ and 41 percent^142^ completed all four consultations. In other trials outside of primary care settings, 68 to 95 percent of participants completed all of the offered group^119, 136, 157, 159, 167^ or phone^164^ sessions (range, 5 to 14 sessions in trials reporting this outcome).

##### Quality Assessment

We gave eight studies a good rating,^119, 126, 142, 163–165, 168, 169^ excluded 15 studies for poor quality, and the remaining studies were assigned a fair rating. Among the fair-quality trials, several reported generally good methods but attrition greater than 20 percent.^129, 130, 155, 172^ More typically, there was more than one concern if studies received a fair rating. Aside from attrition, common concerns included failing to report allocation concealment, randomization methods, outcomes assessment blinding, information about intervention fidelity, or patient adherence or attendance. Many trials had small sample sizes; approximately half of the studies had fewer than 40 participants in each treatment arm. Among the studies excluded for poor quality, the most common issues were high attrition (>40%) or differential attrition (>20 percentage-point difference between groups). The next most common problem was noncomparability of groups at baseline, such as recruitment through completely different and noncomparable mechanisms (e.g., requiring intervention group participants to have had two failed weight loss attempts), but this restriction was not in place for control group participants.

We included both RCTs and nonrandomized, clinical trials. Of the lifestyle-based weight loss interventions, 90 percent were individual or cluster RCTs. We also included three nonrandomized trials^146, 149, 150^ and one cluster RCT with only one group per cluster, which we refer to as a single-group cluster randomized trial.^136^ None of the nonrandomized trials were rated as good quality.

##### Findings

Summary. Weight management interventions with more than 26 estimated contact hours were generally effective in reducing excess weight in children and adolescents after 6 to 12 months, typically with absolute zBMI reductions of 0.20 or more compared with little or no reduction in control groups (Figures 5 and 6). Effects were generally larger and more likely to be statistically significant in programs with more hours of contact. Although several interventions with fewer than 26 contact hours were effective,^119, 152, 154, 161^ most did not show statistically significant group differences, and standardized effect sizes were usually small (generally reflecting absolute reductions in zBMI of ≤0.10 in intervention groups), especially as the number of contact hours diminished. Two of the three lower-intensity interventions that showed a benefit of treatment targeted children who were overweight but did not have obesity.^119, 161^ Even when results were not statistically significant, on average the intervention group almost always showed greater reductions than the control group, although both groups showed a wide range of effects, as demonstrated by large SDs relative to the average change. In other words, some children in both groups showed fairly large reductions in excess weight, some showed no or modest changes, and some continued to gain excess weight.

Figure 5 Forest Plot of zBMI in Behavior-Based Weight Loss Intervention Trials (KQ 4)

* Study-reported repeated measures or adjusted analysis demonstrated a statistically significant benefit.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; diff=difference; est=estimated; hrs=hours; IG=intervention group; m=month(s); SD=standard deviation; tx=treatment; zBMI=body mass index z-score.

This figure is a forest plot of change in zBMI in behavior-based intervention trials, stratified by intervention intensity

Figure 6 Forest Plot of Change in Weight (zBMI, BMI, Weight in Kilograms, or BMI Percentile) in Lifestyle-Based Weight Loss Intervention Trials, by Estimated Contact Hours, Showing DerSimonian and Laird Pooled Estimates (KQ 4)

* Study-reported repeated measures or adjusted analysis demonstrated a statistically significant benefit.

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; CI=confidence interval; est=estimated; hrs=hours; IG=intervention group; m=month(s); SD=standard deviation; SMD=standardized mean difference; tx=treatment; zBMI=body mass index z-score.

This figure is a forest plot of change in any weight outcome in behavior-based intervention trials, stratified by intervention intensity with pooled estimates

Interventions offering 52 or more contact hours showed fairly consistent improvements in blood pressure (pooled mean difference in change between groups for systolic blood pressure [SBP], −6.4 mm Hg [95% CI, −8.6 to −4.2]; k=6; I^2^=51%; pooled mean difference in change between groups for diastolic blood pressure [DBP], −4.0 mm Hg [95% CI, −5.6 to −2.5]; k=6; I^2^=17%) and some improvements in insulin/glucose parameters other than fasting plasma glucose (homeostatic model assessment, 2-hour oral glucose test, insulin levels). However, even the interventions with the highest number of contact hours did not improve fasting plasma glucose or lipid levels compared with control groups. Less intensive interventions were generally not associated with improvements in blood pressure, insulin/glucose, or lipid levels.

Weight. Twenty-eight of the lifestyle-based weight loss trials reported sufficient data to calculate change in zBMI at followup for each group and include in the meta-analysis (Figure 5). Eight additional studies that did not report zBMI could be included in the meta-analysis, using BMI,^132, 144, 156, 163, 166, 168^ weight in kilograms,^136^ or BMI percentile^152^ (Figure 6). Because statistical heterogeneity was very high when all trials were included together (I^2^=81.5%) and estimated hours of contact was clearly related to effect size, we divided the body of evidence into four categories based on of hours of contact. All weight outcomes for all time points are shown in Appendix D Table 3. In addition, a forest plot showing native units, rather than standardized mean differences, without pooling, is included for ease of interpretation of effect sizes (Figure 7).

Figure 7 Forest Plot of Change in Weight (zBMI, BMI, Weight in Kilograms, or BMI Percentile) in Lifestyle-Based Weight Loss Intervention Trials, Showing Native Units, Without Pooling (KQ 4)

* Study-reported repeated measures or adjusted analysis demonstrated a statistically significant benefit.

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; CI=confidence interval; est=estimated; hrs=hours; IG=intervention group; m=month(s); SD=standard deviation; SMD=standardized mean difference; tx=treatment; zBMI=body mass index z-score.

This figure is a forest plot of change in any weight outcome in behavior-based intervention trials, stratified by intervention intensity

The seven trials with 52 or more contact hours all showed clear benefits of treatment,^137, 149–151, 155, 156, 170^ with a pooled standardized mean difference of −1.10 (95% CI, −1.30 to −0.89; k=6, I^2^=43.4%).^149–151, 155, 156, 170^ Results were very similar using the REML method with the Knapp-Hartung adjustment for all analyses (Table 9). One trial with an estimated 122 contact hours is not shown in the figure due to insufficient data, but it reported a greater reduction in zBMI in the intervention group than in the control group (−0.16 vs. −0.01; p=0.002) (Table 10).^137^ Five of these seven trials with the highest number of contact hours reported zBMI, the most valid measure to compare across the range of ages. Absolute zBMI reductions of 0.16 to 0.34 were seen in all studies except one, while control groups generally reported small- to moderate-sized zBMI increases (Appendix D Table 4). Appendix D Table 5 shows how these changes in zBMI translate to change in weight in pounds, estimated based on BMI or zBMI if weight was not reported. In terms of absolute change in weight in pounds, on average, children in intervention groups showed very little weight change over the course of the intervention period, while those in the control groups typically gained 8 to 17 lb. Only a few trials reported dichotomous outcomes, such as the percent with obesity at followup (Figure 8). Although the 2010 trial by Reinehr et al^151^ targeted children who were overweight (but not with obesity), the vast majority of children in the other trials in this group met criteria for obesity. These trials covered a wide age range, and both of the U.S. trials by Savoye et al included a substantial proportion of nonwhite children.

Table 9 Summary of Meta-Analyses of Weight Change in Lifestyle-Based Weight Loss Interventions Compared to Control Groups (Key Question 4)

Estimated Hours of Contact | Outcome | Analysis | SMD | 95% CI | k | I^2^ (%)
52+ | Best weight outcome | Primary^*^ | −1.10 | −1.30 to −0.89 | 6 | 43.4
52+ | Best weight outcome | REML model with Knapp-Hartung | −1.10 | −1.37 to −0.83 | 6 | 43.4
52+ | Best weight outcome | Including poor-quality studies | −0.97 | −1.31 to −0.64 | 7 | 86.0
52+ | Best weight outcome | Higher correlation between baseline and followup (0.80) | −1.24 | −1.46 to −1.02 | 6 | 48.2
52+ | zBMI only | Primary^*^ | −1.10 | −1.37 to −0.84 | 5 | 52.8
52+ | zBMI only | REML model with Knapp-Hartung | −1.10 | −1.48 to −0.73 | 5 | 52.8
52+ | zBMI only | Including poor-quality studies | −0.96 | −1.36 to −0.56 | 6 | 88.1
52+ | zBMI only | Higher correlation between baseline and followup (0.80) | −1.30 | −1.56 to −1.04 | 5 | 50.0
26–51 | Best weight outcome | Primary^*^ | −0.34 | −0.52 to −0.16 | 9 | 24.0
26–51 | Best weight outcome | REML model with Knapp-Hartung | −0.31 | −0.51 to −0.11 | 9 | 24.0
26–51 | Best weight outcome | Including poor-quality studies | −0.31 | −0.47 to −0.14 | 10 | 19.5
26–51 | Best weight outcome | Higher correlation between baseline and followup (0.80) | −0.43 | −0.64 to −0.22 | 9 | 41.9
26–51 | zBMI only | Primary^*^ | −0.38 | −0.64 to −0.13 | 7 | 40.0
26–51 | zBMI only | REML model with Knapp-Hartung | −0.34 | −0.63 to −0.41 | 7 | 40.0
26–51 | zBMI only | Including poor-quality studies | −0.38 | −0.64 to −0.13 | 7 | 40.0
26–51 | zBMI only | Higher correlation between baseline and followup (0.80) | −0.47 | −0.74 to −0.19 | 7 | 48.8
6–25 | Best weight outcome | Primary^*^ | −0.02 | −0.25 to 0.21 | 7 | 37.4
6–25 | Best weight outcome | REML model with Knapp-Hartung | −0.02 | −0.31 to 0.27 | 7 | 37.4
6–25 | Best weight outcome | Including poor-quality studies | −0.16 | −0.33 to 0.01 | 14 | 34.5
6–25 | Best weight outcome | Higher correlation between baseline and followup (0.80) | −0.06 | −0.34 to 0.21 | 7 | 56.0
6–25 | zBMI only | Primary^*^ | −0.02 | −0.25 to 0.21 | 7 | 37.4
6–25 | zBMI only | REML model with Knapp-Hartung | −0.02 | −0.31 to 0.27 | 7 | 37.4
6–25 | zBMI only | Including poor-quality studies | −0.13 | −0.33 to 0.06 | 12 | 42.1
6–25 | zBMI only | Higher correlation between baseline and followup (0.80) | −0.06 | −0.34 to 0.21 | 7 | 56.0
0–5 | Best weight outcome | Primary^*^ | −0.16 | −0.25 to −0.08 | 14 | 0.0
0–5 | Best weight outcome | REML model with Knapp-Hartung | −0.17 | −0.26 to −0.07 | 14 | 0.0
0–5 | Best weight outcome | Including poor-quality studies | −0.15 | −0.22 to −0.07 | 14 | 0.0
0–5 | Best weight outcome | Higher correlation between baseline and followup (0.80) | −0.20 | −0.28 to −0.11 | 14 | 0.0
0–5 | zBMI only | Primary^*^ | −0.22 | −0.34 to −0.10 | 9 | 0.0
0–5 | zBMI only | REML model with Knapp-Hartung | −0.22 | −0.37 to −0.08 | 9 | 0.0
0–5 | zBMI only | Including poor-quality studies | −0.21 | −0.33 to −0.09 | 9 | 0.0
0–5 | zBMI only | Higher correlation between baseline and followup (0.80) | −0.27 | −0.39 to −0.15 | 9 | 0.0

* Primary analysis included all fair- and good-quality trials with sufficient data for meta-analysis, assuming a correlation of 0.50 between baseline and followup measures for calculating standard deviation of the change score when not reported, using the Dersimonian & Laird method for pooling.

Abbreviations: CI=confidence interval; k=number of studies; REML=restricted maximum likelihood; SMD=standardized mean difference; zBMI=body mass index z score.

Table 10 Weight Outcomes of Included Lifestyle-Based Weight Loss Intervention Trials Not Included in the Meta-Analysis (KQ 4)

Author, Year Quality | Population | # of Sessions | Months Followup | Outcome | IG Mean Change (SD) | CG Mean Change (SD) | Between-Group P-Value
Lison, 2012^137^ Fair | Wide age range | 122 | 6 | zBMI | −0.16 (NR) | −0.01 (NR) | 0.002
Mellin, 1987^143^ Fair | Adolescents | 24 | 6 | Weight (kg) | −1.40 (NR) | −1.05 (NR) | NSD
Raynor, 2012a^148^ Fair | Elementary age | 6 | 6 | zBMI | −0.08 (NR) | −0.11 (NR) | NSD
Raynor, 2012a^148^ Fair | Elementary age | 6 | 12 | zBMI | −0.10 (NR) | −0.13 (NR) | NSD
Raynor, 2012b^148^ Fair | Elementary age | 6 | 6 | zBMI | −0.16 (NR) | −0.07 (NR) | NSD
Raynor, 2012b^148^ Fair | Elementary age | 6 | 12 | zBMI | −0.22 (NR) | −0.22 (NR) | NSD
O’Connor, 2013^147^ Fair | Elementary age | 3.5 | 7 | zBMI | 1.77 (0.05)^*^ | 1.75 (0.06)^*^ | 0.86
Love-Osborne, 2014^139^ Fair | Adolescents | 2.5 | 8 | zBMI | NR (NR) | NR (NR) | NSD

* O’Connor, 2013^147^ reported mean (SE) zBMI at followup but BMI percentile at baseline.

Abbreviations: CG=control group; IG=intervention group; NR=not reported; NSD=no significant difference; SD=standard deviation; zBMI=body mass index z score.

Figure 8 Forest Plot of Dichotomous Weight Status Outcomes of Lifestyle-Based Weight Loss Intervention Trials (KQ 4)

Abbreviations: CG=control group; CI=confidence interval; est=estimated; hrs=hours; IG=intervention group; RR=relative risk.

This figure is a forest plot of dichotomous weight status outcomes in behavior-based intervention trials

Six of these seven studies reported results immediately after the last treatment session, so we could not determine the degree to which effects were maintained without ongoing contact. One trial reported results 1 year after the 12-month intervention had ended and found that beneficial effects were maintained (Figure 9).^149^ None of these highest-intensity trials were rated good quality, and two were nonrandomized trials that used as controls children who had undergone the intake process but lived too far away to participate in the program, which is an inferior design to a true RCT.^149, 150^ These factors may exaggerate the true effects of high-intensity interventions. The best-quality study, which reported 23 percent attrition and only 6 months of followup but otherwise generally good methods (including multiple imputation to analyze results in all randomized participants), showed the smallest treatment effect.^155^ In this U.S.-based study of 10- to 16-year-olds with an average baseline BMI of 33 kg/m^2^, the intervention group showed an average BMI decrease of 0.37 kg/m^2^ and weight gain of less than 1 kg on average (1.3 lb), while the control group showed an average BMI increase of 0.67 kg/m^2^ and weight gain of 3.7 kg (8.1 lb).

Figure 9 Forest Plot of Change in Weight (zBMI, BMI, Weight in Kilograms, or BMI Percentile) in Lifestyle-Based Weight Loss Intervention Trials With Multiple Posttreatment Followup, by Estimated Contact Hours, Showing DerSimonian and Laird Pooled Estimates (KQ 4)

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; diff=difference; est=estimated; hrs=hours; IG=intervention group; m=month(s); SD=standard deviation; tx=treatment; zBMI=body mass index z-score.

This figure is a forest plot of change in any weight outcome in behavior-based intervention trials with multiple posttreatment followups

The nine trials with an estimated 26 to 51 contact hours generally showed smaller effects than trials with 52 or more contact hours. Seven of the nine trials demonstrated statistically significant group differences based on study-reported analyses or our calculations based on reported means and SDs.^124, 126, 132, 133, 144, 153, 159, 160, 167^ These trials had a pooled standardized mean difference of −0.34 (95% CI, −0.52 to −0.16; k=9; I^2^=24%). Five of these trials reported results from 3.75 to 9 months after the last treatment session, and all five demonstrated a statistically significant benefit of treatment, suggesting some degree of postcontact maintenance of weight loss,^126, 144, 153, 159, 160^ which is supported by generally maintained effects at longer posttreatment followup (Figure 9). Change in zBMI in the seven studies reporting zBMI ranged from −0.11 (SD, 0.16)^124^ to −0.59 (SD, 0.75)^160^ in the intervention groups, whereas the values were 0.10 or less in the control groups. Absolute weight changes were highly variable, but typically intervention groups averaged around 1- to 5-lb weight gains compared with average 5- to 10-lb gains in control groups.

Studies with an estimated fewer than 26 contact hours were unlikely to show statistically significant group differences. Moreover, the effect sizes were generally small, usually with standardized effect sizes less than 0.30, and in three trials the control group paradoxically showed greater improvement than the intervention group.^117, 120, 129^ However, none of these were statistically significant. The pooled estimate for trials with interventions of 6 to 25 contact hours was −0.02 (95% CI, −0.25 to 0.21; k=7; I^2^=37%), and none of these trials showed a statistically significant group difference,^117, 120, 129–131, 145, 146^ nor did the three trials in this group not included in the meta-analysis. ^143, 148^ Trials with up to 5 contact hours^119, 136, 138, 139, 142, 147, 152, 154, 157, 161, 163–166, 168, 169^ had a pooled effect of −0.17 (95% CI, −0.25 to −0.08; k=14; I^2^=0%).^119, 136, 138, 142, 152, 154, 161, 163–166, 168, 169^ While this difference was statistically significant, it was small, and only four^119, 152, 154, 161^ of the 16 trials, including the two trials that were not included in the meta-analysis,^139, 147^ showed statistically significant benefits. Of the three very brief interventions that showed a benefit, two were limited to overweight populations (who did not have obesity),^119, 161^ which suggested that if brief interventions are ever called for, they may be best reserved for children who are overweight only.

Appendix D Tables 4 and 5 include columns showing 1 SD around the mean change in each direction for zBMI (Appendix D Table 4) and weight change in pounds (Appendix D Table 5), to highlight the wide range of effects within each study. For example, in the best-quality trial by Savoye et al with an intervention of 52 or more contact hours reported,^155^ two thirds of the intervention participants ranged from losing 9 lb to gaining 12 lb over the course of 6 months, based on the reported SDs. In the control group, two thirds of participants ranged from losing 2 lb to gaining 19 lb. In another U.S.-based trial by the same author, two thirds of the intervention group participants ranged from a 19-lb weight loss to a 20-lb weight gain over 1 year, versus a 5-lb weight loss to a 39-lb weight gain in the control group.^156^ While wide difference in weight change would be expected in trials with a wide range of ages, such as these two trials, zBMI values also had a surprisingly large degree of variability. For example, in the 6-month trial by Savoye et al, two thirds of participants ranged from a zBMI reduction of 0.18 to an increase of 0.08, and variability was substantially higher in most other trials, regardless of intensity or duration.^155^ In general, among trials with an estimated 26 or more contact hours, two thirds of children ranged from zBMI reductions of approximately 0.50 and higher to almost no change in zBMI or, in the low end of this intensity range, increases of up to 0.26. Among the interventions with fewer contact hours, change in zBMI in the middle two thirds of children generally ranged from reductions of 0.20 to 0.70 to increases of 0.20 or more. Across all of the included lifestyle-based weight loss trials, control groups exhibited wide-ranging changes in zBMI scores but shifted to less favorable results than the intervention groups.

Other intermediate outcomes (KQ 4a). Fifteen of the lifestyle-based weight loss trials, including nine of the 10 trials with the highest number of contact hours, reported cardiometabolic outcomes.^117, 130–133, 136, 139, 149–151, 153, 155, 156, 167, 170^ While these outcomes were rather sparsely reported overall, most of the trials with 52 or more contact hours reported cardiometabolic outcomes. Therefore, we pooled these outcomes only for the highest-contact group for blood pressure,^149–151, 155, 156, 170^ lipid,^149, 150, 155, 156^ and fasting plasma glucose levels.^149, 150, 155, 156^ SBP was reduced in five of the six trials with 52 or more contact hours reporting this outcome (Figure 10; Appendix D Table 6),^149–151, 155, 170^ and the pooled estimate was −6.4 mm Hg (95% CI, −8.6 to −4.2; k=6; I^2^=51.3%) (Table 11). In those trials in which a reduction occurred, SBP was reduced by 2 to 7 mm Hg in the intervention groups and ranged from a reduction of 1 mm Hg to an increase of 5 mm Hg in the control groups. DBP showed smaller effects that were statistically significant in only the two trials with the weakest design, resulting in relative improvements of 2 to 5 mm Hg,^149, 150^ with a pooled estimate of −4.0 mm Hg (95% CI, −5.6 to −2.5; k=6; I^2^=17.3%) (Table 11). Most of the trials with fewer contact hours did not show group differences for either SBP or DBP.

Figure 10 Forest Plot of Blood Pressure in Lifestyle-Based Weight Loss Intervention Trials (KQ 4)

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; DBP=diastolic blood pressure; est=estimated; hrs=hours; IG=intervention group; m=month(s); SBP=systolic blood pressure; tx=treatment; WMD=weighted mean difference.

This figure is a forest plot of change in blood pressure in behavior-based intervention trials, stratified by intervention intensity

Table 11 Pooled Results for Continuous Intermediate Cardiometabolic Outcomes of Included Lifestyle-Based Weight Loss Intervention Trials With 52 or More Estimated Contact Hours (KQ 4)

Outcome | Unit | Pooled mean difference in change between groups (95% CI) | # trials | I ^ 2 ^ | Model | Report Figure
SBP | mm Hg | −6.4 (−8.6 to −4.2)^*^ | 6 | 51.3 | DL | 10
DBP | mm Hg | −4.0 (−5.6 to −2.5)^†^ | 6 | 17.3 | DL | 10
FPG | mg/dL | −0.8 (−3.0 to 1.2) | 4 | 0 | REML | 11
LDL | mg/dL | −10.0 (−21.1 to 1.1) | 4 | 56.6 | REML | 12
HDL | mg/dL | 0.4 (−2.2 to 3.0) | 4 | 0 | REML | 12
Triglycerides | mg/dL | −9.1 (−27.8 to 9.6) | 4 | 36.9 | REML | 12

* REML estimate, −6.4 (95% CI, −9.3 to −3.5).

† REML estimate, −4.1 (95% CI, −6.1 to −2.0).

Abbreviations: DBP=diastolic blood pressure; DL=Dersimonian & Laird; FPG=fasting plasma glucose; HDL=high-density lipoprotein; LDL=low-density lipoprotein; PL=profile likelihood; REML=restricted maximum likelihood with Knapp-Hartung modification; SBP=systolic blood pressure.

A variety of glucose and insulin parameters were reported (Figure 11; Appendix D Table 7). Again, improvements were seen primarily in the four studies with 52 or more contact hours reporting these outcomes. Although none of these trials with the highest number of contact hours reported statistically significant greater improvements in fasting plasma glucose levels, between-group differences were reported for the 2-hour oral glucose tolerance test,^150, 155^ homeostatic model assessment,^150, 155, 156^ and insulin levels.^150, 155, 156^ The pooled estimate for fasting plasma glucose level was −0.7 mg/dL, which was not statistically significant (95% CI, −2.6 to 0.4; k=4; I^2^=0%) (Table 11). In addition, one nonrandomized, controlled trial showed reductions in metabolic syndrome in the intervention group but not in the control group.^150^ In this study, 19 percent of the intervention group and 20 percent of the control group met International Diabetes Federation criteria for metabolic syndrome at baseline, but at the 1-year followup, 8 percent of the intervention group and 21 percent of the control group met the criteria. Results generally showed no between-group differences for the remaining trials that reported one or more of these outcomes.^130, 131, 133, 136, 167^ One trial reported no cases of diabetes onset in either group^155^ and another trial reported onset in two of 83 control group participants (2.4%) but none in the intervention group.^139^

Figure 11 Forest Plot of Glucose Outcomes in Lifestyle-Based Weight Loss Intervention Trials (KQ 4)

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; est=estimated; FPG=fasting plasma glucose; HOMA=homeostatic model assessment; hrs=hours; IG=intervention group; IU=international unit(s); m=month(s); OGTT=oral glucose tolerance test; pmol=picomole(s); SD=standard deviation; tx=treatment; WMD=weighted mean difference.

This figure is a forest plot of change in glucose outcomes in behavior-based intervention trials, stratified by intervention intensity

The only trials to show improvements in lipid levels were those with 52 or more contact hours, but these differences did not show a clear pattern of benefit (Figure 12; Appendix D Table 8), and none of the pooled effects were statistically significant (Table 11). One trial showed greater improvement in the amount of low-density lipoprotein cholesterol (−7.7 vs. +7.7 mg/dL in the intervention vs. control group, respectively),^150^ a second trial showed greater improvement in total cholesterol level (−9.2 vs. +3.7 mg/dL),^156^ and a third showed greater improvement in triglyceride levels (−28.4 vs. −4.6 mg/dL).^155^ For all of these lipid outcomes, other high-intensity trials did not show a benefit, and none of the interventions with 52 or more contact hours showed between-group differences in high-density lipoprotein levels.

Figure 12 Forest Plot of Lipids in Lifestyle-Based Weight Loss Intervention Trials (KQ 4)

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; DBP=diastolic blood pressure; est=estimated; HDL-C=high-density lipoprotein cholesterol; hrs=hours; IG=intervention group; LDL-C=low-density lipoprotein cholesterol; m=month(s); SBP=systolic blood pressure; TC=total cholesterol; tx=treatment.

This figure is a forest plot of change in lipid outcomes in behavior-based intervention trials, stratified by intervention intensity

Effect modifiers, including intervention components (KQ 4b). Applying meta-regression, we examined a number of potential effect modifiers, including several quality-related variables (overall quality rating, RCT/cluster RCT vs. other designs, year of publication, percent followup), intervention components (estimated contact hours, number of sessions, duration of the intervention, whether group or individual sessions were offered, whether supervised physical activity sessions were offered, whether sessions were offered to children without parents in the room or included both parents and children together), and other study characteristics (type of control group, use of population-based screening for recruitment). Of all these factors, only the estimated contact hours and number of sessions were clearly associated with effect size (meta-regression p<0.001 for both). However, of five trials that included multiple intervention groups with differing contact hours, none reported statistically significant larger effects in the more intensive arm.^130, 137, 138, 152, 164^ In most cases there was a nonstatistically significant difference in favor of the more intensive treatment arm, with differences that were larger and more consistent across outcomes in studies with greater differences in contact hours between the groups.^130, 137^ Trials with a higher percentage of followup also tended to have larger effect sizes, even after controlling for estimated contact hours, allaying fears that effect sizes are artificially inflated due to study limitations.

We found no evidence for or against the importance of any specific intervention component or approach. All of the interventions that showed a benefit included parents and provided basic didactic information about healthy diet and physical activity. Most successful interventions took place outside of the primary care setting, targeted both the parent and child (separately, together, or both), helped parents and children engage in stimulus control (e.g., limiting access to tempting foods, limiting screen time), identified or helped participants identify specific goals, and encouraged self-monitoring and problem-solving to help achieve the goals. These trials typically included some supervised physical activity sessions. Other common components included contingent use of rewards or reinforcement, motivational interviewing, teaching of coping skills, addressing body image, and the option of individual family counseling to address family-specific issues. The dietary approach of some successful studies specifically described using a nondiet approach, instead emphasizing healthy foods and moderate portions,^133, 155, 156^ and several used a “Stoplight” metaphor, categorizing food as red (stop), yellow (consider the amount) and green (okay when hungry or thirsty) to steer children to healthier choices.^132, 150, 151, 167, 224^ Parents were frequently asked to modify their behavior and were sometimes actively engaged in weight loss interventions themselves. Three studies had multiple comparison groups designed to contrast specific approaches: two encouraged participants to primarily reduce unhealthy behaviors versus increase healthy behaviors^148^ and one compared targeting unhealthy beverage reduction only versus targeting multiple diet and physical activity behaviors.^161^ No notable differences between approaches were found in any of these trials.

We conducted several sensitivity analyses to explore the impact of our analysis methods on effect sizes and found our results to be highly robust (Table 9). First, when we used the REML method of pooling with the Knapp-Hartung adjustment, which is an appropriate and more conservative approach to pooling than that of DerSimonian and Laird when the number of trials to be pooled is relatively small (<10), the point estimates were identical to two decimal places or very slightly attenuated and CIs slightly wider, but the statistical significance never changed. Next, poor-quality trials were included in the analysis, and again point estimates were slightly attenuated or minimally changed, although the CIs narrowed due to the larger number of observations and the pooled estimates for all four categories of contact hours were statistically significant. Finally, to calculate the SD of change scores for trials that reported only baseline and followup means and SDs, we estimated the correlation between baseline and followup weight measures to be 0.50, which we judged to be a fairly conservative (i.e., low) estimate. We also ran sensitivity analyses assuming a higher correlation of 0.80, as would likely be seen in an adult population, and predictably found that this approach resulted in larger effect sizes.

Important subpopulations (KQ 4c). Subgroup analysis of our prespecified subpopulations of interest (i.e., age, race/ethnicity, sex, degree of excess weight, socioeconomic status) was sparse in the included trials, leading us to draw no conclusion about differential effectiveness on weight outcomes. Analyses of the effect of behavior-based treatments in subpopulations were generally limited by small study sizes and the absence of statistical interaction testing in several trials.

Five trials reported results separately for boys and girls, but no clear pattern emerged to suggest that weight management interventions are differentially effective.^119, 130, 139, 155, 163^ Only a few trials reported subgroup analysis by severity of obesity,^139, 146^ age (among young children, ages 4 to 5 years vs. 6 to 7 years^119^ and ages 2 to 4 years vs. 5 to 7 years^163^), parental education,^119, 163^ race/ethnicity,^163^ and income.^163^ Subgroup analyses showed no differential effectiveness based on age or race/ethnicity.

One of the trials, which examined whether the effects were similar across two levels of obesity severity in Swedish adolescents with an average baseline BMI of 34.5 kg/m^2^ and an estimated 16 contact hours, found that the subgroup below the median zBMI for the study showed a statistically significant reduction in excess weight, while those above the median had minimal change.^146^ The other trial with a subgroup analysis by baseline obesity severity found no beneficial effect in any of the subgroups of adolescents they examined (BMI percentiles of 85th to 95th, 95th to 99th, and above 99th).^139^ However, this trial of adolescents conducted in a school-based health center with an estimated 2.5 contact hours had an imbalance between intervention and control participants in that control participants had substantially higher athletic participation, which may have attenuated the effects of the intervention.

Two trials examining socioeconomic factors had contradictory findings.^119, 163^ The U.S. primary care–based study in 2- to 6-year-olds reported that lower-income families showed a greater benefit than higher-income families but found no subgroup differences by age, parental education, or race/ethnicity.^163^ An Italian trial found greater benefit in families with higher versus lower maternal education (p=0.008 for interaction).^119^

Among studies that were limited to important subgroups, contact hours still appeared to be the primary factor that predicted success. We saw no evidence that age group of participants was an important driver of effect size (Appendix D Figure 1). In four trials of young children, two trials with 30 to 36 contact hours showed large beneficial effects^159, 160^ and two brief (2 to 3 hours) primary care–based studies revealed very small and statistically nonsignificant effects.^163, 166^ Both trials with the largest effects among those providing 26 to 51 estimated contact hours targeted young children.^159, 160^ Small absolute weight changes can have a large effect on excess adiposity for very young children (Table 1), which suggests that slightly less intensive programs may be beneficial in young children. Both of these trials were very small studies, however, and need to be replicated. These interventions involved individual and group activities as well as home visits, instruction in behavior change principles, and general parenting instruction.

In the six studies targeting adolescents, the only one that showed a statistically significant benefit had the highest number of estimated contact hours (37 hours). This trial was limited to girls (average BMI, 32 kg/m^2^) recruited through a primary care setting for a 5-month intervention that included visits with the primary care provider as well as separate group sessions for the girls and their parents.^126^ This study had a fairly small effect, with zBMI decreasing from 2.00 to 1.88 in the intervention group and from 2.00 to 1.94 in the control group at 6 months, but the benefits were fully retained at the 12-month followup. In terms of weight change in pounds, at 12 months the intervention group gained an average of 4.9 lb (1 SD range, −31.2 to +41 lb) compared with an average gain of 7.1 lb in the control group (1 SD range, −28.9 to +43.1 lb).

Four trials were limited to or primarily comprised of Latino youth.^117, 136, 139, 147^ All involved relatively brief interventions (2.5 to 11 estimated contact hours), and none demonstrated a benefit of treatment. However, two of the highest-intensity trials included samples in which more than 60 percent of participants were black or Latino^155, 156^ and both showed relatively large benefit with 78 to 82 contact hours.

Five trials were limited to youths with severe obesity (≥97th or 98th percentile for the norms used by the study).^120, 132, 149, 153, 170^ Interventions with more than 52 contact hours showed beneficial effects,^149, 170^ whereas the intervention with fewer than 26 contact hours did not.^120^ The two interventions with mid-range contact hours had mixed results.^132, 153^ At the other end of the spectrum, four additional trials were limited to children and adolescents who were overweight and did not have obesity.^119, 157, 161, 166^ All of these trials were brief interventions (1 to 4 contact hours), but two had a beneficial effect, despite the short contact time.^119, 161^

#### Other Behavior-Based Interventions

We also included one small trial (n=61) of weight maintenance in adolescents who had participated in a 4-month weight loss intervention.^125^ The maintenance portion of the intervention included eight group sessions, involving four motivational calls to the adolescents and up to four parent sessions over the course of 8 months. Compared with a newsletter-only control group, the active maintenance group did not show improved weight, body composition, glucose/insulin indices, or lipid levels immediately after the intervention finished. Detailed results were not provided for most outcomes, but group differences were not statistically significant (Appendix D Table 9).

We also included two small pilot trials (n<50) that used fundamentally different approaches to weight management. Rather than provide information and structure regarding change in diet and physical activity, one trial tested a “Regulation of Cues” intervention that involved appetite awareness and cue exposure training.^118^ This 14-session intervention for 8- to 12-year-olds focused on increasing awareness of overeating in relation to the environment and used behavioral approaches to reduce overeating. The other trial used both individual- and group-based interpersonal therapy for adolescent girls, assuming that overeating was related to poor social functioning and the consequent negative mood.^162^ This trial focused on improving interpersonal skills as a way to reduce overeating. Neither of these trials showed group differences in mean BMI or zBMI with the intervention (no zBMI reductions >0.10 in either group).

#### Pharmacotherapy Interventions

##### Study Characteristics

Eleven trials compared pharmacotherapy for weight loss with a placebo. Eight of these trials used metformin^123, 128, 135, 140, 158, 171–173^ and three used orlistat^108, 122, 141^ (Table 6). These trials were generally small, ranging from 28 to 155 participants in metformin trials and from 40 to 539 participants in orlistat trials. Overall, 616 participants were randomized for metformin trials and 779 for orlistat trials. Most (64%) were conducted in the United States,^108, 128, 140, 172, 173^ and others were conducted in the United Kingdom,^135^ Canada,^123^ Australia,^158^ and Germany and Switzerland.^171^ No trials were conducted in primary care; 18 percent were conducted in pediatric obesity centers,^122, 171^ another 18 percent in pediatric endocrine clinics,^135, 158^ and the remainder in other types of clinical research centers. Participants in 27 percent of trials were selected from populations referred to pediatric obesity centers^171^ or pediatric endocrine centers.^135, 158^ One study recruited volunteers only,^128^ and others used heath care based–recruitment, often by using several strategies such as clinician referral in combination with advertisement. Four studies were partially or wholly funded by industry.^108, 122, 128, 171^

Two studies included placebo run-in periods to enrich population compliance^172^ or confirm eligibility.^122^ One study of metformin had a cross-over design with a 2-week washout in between periods.^158^ Eight trials were 6 months long and three trials were 1 year long. One trial continued participant monitoring for 48 weeks after drug discontinuation following a 1-year randomized phase.^172^

##### Populations

Fifty-four percent of trials were conducted exclusively in adolescents,^108, 122, 128, 140, 141, 172^ and the remaining trials included younger children as well. The mean age of participants in metformin and orlistat trials was 13.7 and 14.0 years, respectively. All three orlistat trials were limited to adolescents.^108, 122, 141^ One metformin trial enrolled children as young as age 6 years.^173^ Participants in pharmacotherapy trials had a higher BMI than those in behavior-based interventions (36.0 and 37.4 kg/m^2^ for metformin and orlistat trials, respectively). Among trials reporting weight, mean baseline values ranged from 172 to 241 lb in the metformin trials and 213 to 248 lb in the orlistat trials. All trials included both boys and girls. About two thirds of the participants were female. Among trials reporting percentage of white participants, the range was 25 to 89 percent. Two trials were conducted in a majority Hispanic population^140, 141^ and four trials included at least 33 percent of children who were black.^108, 128, 140, 173^

For inclusion, six of eight (75%)^128, 135, 140, 158, 171, 173^ metformin trials required abnormalities of insulin or glucose metabolism, such as hyperinsulinemia, insulin resistance, or impaired glucose tolerance; one trial explicitly excluded participants with elevated fasting or 2-hour glucose levels or HbA1c.^123^ Three metformin trials also had selection criteria regarding a family history of diabetes or the presence of acanthosis nigricans.^128, 140, 158^ One metformin trial restricted inclusion to participants with a previous unsuccessful lifestyle intervention, defined as BMI change less than 2 kg/m^2^ over 6 months and persistent insulin resistance.^171^

With the exception of one orlistat study that required the presence of one or more obesity-related comorbid conditions (including type 2 diabetes, among others),^108^ studies typically excluded persons with diabetes. Metformin trials screened out patients with contraindications to the drug (mainly renal or hepatic dysfunction, which can increase the risk of lactic acidosis, a rare but serious potential side effect).^225^

##### Interventions

To examine the incremental effect of the drug, trials were selected to have the same background lifestyle intervention in each group plus the pharmacotherapy or placebo. Interventions from pharmacotherapy trials are described in Table 12. All but one drug trial provided a background lifestyle intervention, and this was a study of metformin.^128^ Two trials provided minimal standardized diet and exercise advice with an estimated contact time of 15 minutes,^135, 158^ and five trials provided advice on behavioral management in addition to advice on diet and exercise, with estimated contact time ranging from 2.25 to 9.5 hours.^122, 140, 141, 172, 173^ Three studies also offered group exercise sessions in addition to diet and exercise advice and behavioral management; these studies had estimated contact time of 15 to 86 hours.^108, 123, 171^

Table 12 Intervention Characteristics of Pharmacotherapy Trials Included for Treatment Benefit (KQs 3 and 4)

Author, Year Quality Age group | Intervention | Description | Components | Delivery | Format | Target | # Sessions (session length) | Duration (months) | Est hours | Provider | Role of PCP
Metformin
Clarson, 2014^123*^ Fair Wide range | Metformin + comprehensive lifestyle | Metformin 2000 mg QD + lifestyle intervention consisting of the following sessions over 12 months: 66 group exercise, 12 dietitian, 12 social worker, 4 group family and 12 group child behavior change sessions, for a total of 86 hours of direct contact | HD advice PA advice PA sessions Behavioral Drug | In Person | Group, Individual | Child, Family | 106 (Social worker 30 mins, dietitian 30 mins, group family 120 mins, group behavior 20 mins, exercise 60 mins) | 12 | 86 | Exercise specialist, social worker, dietitian | No role
Wiegand, 2010^171*^ Fair Wide range | Metformin + family-based lifestyle intervention | Metformin 500 mg bid + multi-professional family-based lifestyle program consisting of individual goal setting, reinforcement sessions and structured interview with basic education and 2 45-min PA classes per week | HD advice PA advice PA sessions Behavioral Drug | In Person | Group, Individual | Family | 58 (sport sessions 45 minutes; other NR) | 6 | 40.8 | Multi-professional (not further described) | No role
Wilson, 2010^172*^ Fair Adolescent | Metformin + lifestyle intervention | Metformin 500 mg qid + 19 session lifestyle cognitive-behavioral therapy program | HD advice PA advice Behavioral Drug | In Person | Individual | Family | 19 (NR) | 12 | 9.5 | Trained health specialist | No role
Yanovski, 2011^173*^ Good Wide range | Metformin + lifestyle intervention | Metformin 1 g bid + lifestyle intervention consisting of 6 monthly family meetings with dietitian and self-monitoring of food and activity using pedometer | HD advice PA advice Behavioral Drug | In Person | Individual | Family | 6 (NR) | 6 | 3 | Dietitian | No role
Love-Osborne, 2008^140^ Fair Adolescent | Metformin + goal setting | Metformin 850 mg bid + 6 monthly individual goal-setting sessions; initial session included written material and video | HD advice PA advice Behavioral Drug | In Person, Electronic, Print | Individual | Child | 6 (NR) | 6 | 2.25 | Dietitian or study investigator and research assistant | No role
Kendall, 2013^135*^ Fair Wide range | Metformin + 1 individual session | Metformin 1.5 g/day and 1 standardized individual healthy lifestyle advice session | HD advice PA advice Drug | In Person, Print | Individual | Child | 1 (NR) | 6 | 0.25 | NR | No role
Srinivasan, 2006^158^ Fair Wide range | Metformin + 1 individual session | Metformin 1 g bid + standardized information on healthy eating and exercise | HD advice PA advice Drug | In Person | Individual | Child | 1 (NR) | 6 | 0.25 | NR | No role
Freemark, 2001^128^ Fair Adolescent | Metformin | Metformin 500 mg bid; no dietary change attempted | Drug | NA | NA | Child | 0 (NR) | NA | 0 | NA | No role
Orlistat
Yanovski, 2012^108*^ Fair Adolescent | Orlistat + behavioral weight loss | Orlistat 120 mg TID for 6 months plus 12-week behavioral weight loss program | HD advice PA advice PA sessions Behavioral Drug | In Person | Group | Child | 15 (NR) | 6 | 15 | Registered dietitian | NR
Chanoine, 2005^122^ Fair Adolescent | Orlistat + Diet, PA, and Behavior Therapy | Orlistat 120 mg 3 times/day + hypocaloric diet, exercise and behavioral therapy; 18 individual meetings with dietitian and behavioral psychologist | HD advice PA advice Behavioral Drug | In Person | Individual | Child | 18 (NR) | 12 | 9 | Dietitian, behavioral psychologist | No role
Maahs, 2006^141^ Fair Adolescent | Orlistat + dietitian counseling | Orlistat 120 mg 3 times/day + 7 monthly diet and exercise counseling sessions with dietitian | HD advice PA advice Behavioral Drug | In Person, Print | Individual | Child | 7 (NR) | 6 | 3.5 | Dietitian | No role

* New studies since previous review.

Abbreviations: bid=twice daily; HD=healthy diet; est=estimated; NA=not applicable; NR=not reported; qid=four times daily; PA=physical activity.

Interventions were delivered individually for most included trials. Sessions were attended by both parents and children in four of the trials,^123, 171–173^ and apparently by only the child in the remaining studies; no trial included a parent-only component. Primary care providers were not involved in delivering interventions for any of these included trials.

Adherence to pharmacotherapy was typically assessed through use of pill counts^122, 123, 141, 158, 171, 173^ but also through prescription dispensing^140^ and asking participants about missed doses.^172^ Adherence metrics were inconsistent across studies. The lowest adherence level occurred in a trial reporting that 60 and 75 percent of the metformin and control groups, respectively, filled four prescriptions over 6 months, equating to a maximum dose for 2 months.^140^ Adherence was greatest in a trial in which 93.2 and 92.2 percent of pills were taken in the metformin and placebo groups, respectively.^173^ Adherence in orlistat trials was 72 to 73 percent in one trial,^122^ greater than 80 percent for the overall population in one trial,^141^ and not reported in the other.^108^

Adherence to lifestyle intervention components in these pharmacotherapy trials was less commonly reported. When reported, it was variable. The lowest rate of attendance occurred in a 1-year trial, in which participants attended an average of 6.3 and 6.7 out of a possible 19 sessions in the intervention and placebo groups, respectively.^172^ The highest rate occurred in a 6-month trial in which 88 and 92 percent of the intervention and placebo groups, respectively, attended clinical visits and education sessions but only 61 and 70 percent, respectively, attended at least one group exercise session per week.^171^ The trial with the most intensive lifestyle intervention—86 estimated contact hours—reported adherence to sessions over time and showed that attendance decreased as the intervention progressed.^123^ At 3 to 6 months, attendance at fitness and nutrition/social work sessions was 57 to 76 percent and 64 to 71 percent, respectively, and at 7 to 12 months, 40 to 63 percent and 53 to 79 percent, respectively.

The total daily metformin dose ranged from 1,000 to 2,000 mg.^172^ Doses were typically up-titrated over several weeks to reduce side effects; participants were generally allowed to reduce the dose if side effects occurred. All orlistat trials administered a total daily dose of 360 mg. Participants in all orlistat trials^108, 122, 141^ were instructed to take a multivitamin, consistent with FDA label information that this agent can reduce the absorption of some fat-soluble vitamins and beta-carotene.^226^ Similarly, participants in two metformin trials^172, 173^ were advised to take a multivitamin due to possible metformin interference with B_12_ absorption.^225^

##### Quality Assessment

We gave one study a good rating,^173^ excluded one for poor quality,^227^ and rated the remaining 10 trials as fair.^108, 122, 123, 128, 135, 140, 141, 158, 171, 172^ Among the fair-quality trials, several reported generally good methods but attrition greater than 25 percent.^122, 123, 135, 140, 171, 172^ Concerns in other fair-quality studies also included missing information on the randomization procedure, allocation concealment, or weight measurement methods; lack of reporting regarding adherence to behavioral intervention components; unclear analysis methods; and differential attrition of approximately 10 percent. Results of one fair-quality trial were published only on ClinicalTrials.gov^108^ and as a conference abstract;^177^ quality rating was performed based on information available only through these sources. Methods in the poor-quality trial were sparsely described and information about several quality domains, including the number of participants followed up, was not reported.^227^

##### Metformin

Summary. Metformin was associated with a small but statistically significant weight reduction with minimal statistical heterogeneity in trials of 6 to 12 months’ duration. In pooled analyses, metformin reduced zBMI by −0.10 (95% CI, −0.17 to −0.03; k=6; I^2^=13.1%) and BMI by −0.86 kg/m^2^ (95% CI, −1.44 to −0.29; k=6; I^2^=0%) (Figures 13 and 14). Results of trials that could not be pooled for any or select outcomes were generally consistent with pooled results.^128, 140, 158^ When individual trials adjusted for characteristics such as baseline weight, age, sex, or race/ethnicity, several trials became statistically significant, which were not in our unadjusted analyses.^135, 172, 173^ Dose did not appear to modify the weight effect of metformin, but our analysis was limited by confounding across the studies. Limited data are available about the persistence of metformin effect after discontinuation. Metformin was associated with no statistically significant benefit for fasting glucose, lipid, or blood pressure outcomes; where outcomes could be pooled, CIs were wide and statistical heterogeneity was high for some outcomes (Table 13).

Figure 13 Forest Plot of Change in zBMI in Metformin Trials (KQ 4)

* Study-reported repeated measures or adjusted analysis demonstrated a statistically significant benefit.

Note: dose in mg/day.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; IG=intervention group; SD=standard deviation; WMD=weighted mean difference; Tx=treatment.

This figure is a forest plot of change in zBMI in metformin trials

Figure 14 Forest Plot of Change in BMI in Metformin Trials (KQ 4)

* Study-reported repeated measures or adjusted analysis demonstrated a statistically significant benefit.

Note: dose in mg/day.

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; IG=intervention group; SD=standard deviation; WMD=weighted mean difference; Tx=treatment.

This figure is a forest plot of change in BMI in metformin trials

Table 13 Pooled Results for Continuous Intermediate Cardiometabolic Outcomes of Included Metformin Trials (KQ 4)

Outcome | Unit | Pooled mean difference in change between groups (95% CI) | # trials | I ^ 2 ^ | Model | Report Figure
FPG | mg/dL | −3.7 (−9.9 to 2.5) | 5 | 64.0 | REML | 15
TC | mg/dL | −2.5 (−13.7 to 8.7) | 4 | 0.0 | REML | 16
LDL | mg/dL | −0.3 (−8.4 to 7.8) | 6 | 21.4 | REML | 16
HDL | mg/dL | 0.2 (−2.4 to 2.8) | 6 | 11.9 | REML | 16
Triglycerides | mg/dL | 3.1 (−17.6 to 23.8) | 5 | 0.0 | REML | 16

Abbreviations: CI=confidence interval; DBP=diastolic blood pressure; DL=Dersimonian & Laird; FPG=fasting plasma glucose; HDL=high-density lipoprotein; LDL=low-density lipoprotein; PL=profile likelihood; REML=restricted maximum likelihood with Knapp-Hartung modification; SBP=systolic blood pressure.

Table 14 Discontinuation Rates in Pharmacotherapy Trials Included for Harms of Treatment (KQ 5)

Study, Year Quality | Timepoint, months | Drug: N Discontinuing due to AE | Drug: N Analyzed | Drug: % Discontinuing due to AE | Placebo: N Discontinuing due to AE | Placebo: N Analyzed | Placebo: % Discontinuing due to AE
Metformin
Kay, 2001^134^ Fair | 2 | 0 | 12 | 0 | NR^*^ | 12 | NR^*^
Evia-Viscarra, 2012^127^ Fair | 3 | 2 | 15 | 13.3 | 2 | 16 | 12.5
Burgert, 2008^121^ Fair | 4 | 0 | 15 | 0 | NR^*^ | 13 | NR^*^
Love-Osborne, 2008^140^ Fair | 6 | 2 | 60 | 3.3 | 1 | 25 | 4
Wiegand, 2010^171^ Fair | 6 | 1 | 36 | 2.8 | 3 | 34 | 8.8
Yanovski, 2011^173^ Good | 6 | 1 | 53 | 1.9 | 0 | 47 | 0
Clarson, 2014^123^ Fair | 12 | 1 | 33 | 3.0 | NR^*^ | 36 | NR^*^
Wilson, 2010^172^ Fair | 12 | 3 | 39 | 7.7 | 1 | 38 | 2.6
Metformin Total | | 10 | 263 | 3.8% | 7 | 221 | 3.2%
Orlistat
Maahs, 2006^141^ Fair | 6 | 2 | 20 | 10 | 0 | 20 | 0
Yanovski, 2012^108^ Fair | 6 | 1 | 100 | 1 | 2 | 100 | 2
Chanoine, 2005^122^ Fair | 12 | 12 | 352 | 3.4 | 3 | 181 | 1.7
Orlistat Total | | 15 | 472 | 3.2% | 5 | 301 | 1.7%

* NR counted as 0 in totals.

Abbreviations: AE=adverse effect; NR=not reported.

Weight. Six of eight metformin trials reported sufficient data for a meta-analysis of zBMI change (Appendix D Table 10). These pooled results showed a zBMI net reduction of −0.10 (95% CI, −0.17 to −0.03; k=6; I^2^=13.1%) among those taking metformin compared with placebo (Figure 13), with almost identical results using the more conservative profile likelihood pooling method to account for the very small number of trials being pooled (−0.10 [95% CI, −0.19 to −0.03; k=5; I^2^=0%). Despite differences in metformin dose and background therapy between trials, statistical heterogeneity was very low. As with the behavioral trials, the relatively large SDs suggested a wide range of effects within trials (Appendix D Tables 11 and 12).

The largest between-group difference in zBMI change occurred in a small fair-quality trial of 6 months that offered no adjunct diet or activity advice or behavioral component (this trial was also the only one with exclusively volunteer recruitment). Participants in the metformin group had a statistically significantly higher BMI at baseline than those in the placebo group, without adjustment of results.^128^ Intervention group participants achieved the second greatest mean zBMI reduction across trials at −0.12 (SD, 0.30), but placebo group participants had the largest zBMI increase at 0.23 (SD, 0.39). The trial with the most intensive lifestyle background therapy, with an estimated 86 contact hours, showed a sizeable net difference in zBMI between the intervention and placebo groups that neared statistical significance at 12 months (−0.22 [95% CI, −0.46 to 0.02]);^123^ despite the intensive lifestyle intervention in both groups, mean zBMI increased by 0.05 (SD, 0.40) in the placebo group. Six-month outcomes in this trial showed a smaller and nonsignificant zBMI net difference of −0.10 (95% CI, −0.31 to 0.11), where the metformin group had a zBMI reduction that was similar at 12 months (−0.14 [SD, 0.44]), but the placebo group had a 6-month zBMI reduction of −0.04 (SD, 0.38) that turned into a zBMI increase at 12 months. The one trial that restricted inclusion to participants with a previous unsuccessful lifestyle intervention, defined as BMI change less than 2 kg/m^2^ and persistent insulin resistance, showed no difference in zBMI between the metformin and placebo groups.^171^ The remaining trials had similar very small and statistically nonsignificant unadjusted between-group zBMI reductions, which ranged from −0.06 to −0.08.^135, 172, 173^ However, study-reported results adjusted for baseline zBMI^135^ or age, sex, and race/ethnicity^173^ were statistically significant in two trials. For the latter (the one good-quality trial of metformin), this equated to a 1.5-kg weight gain in participants taking metformin and a 4.8-kg gain in those taking placebo.^173^ An additional trial reporting zBMI could not be included in the meta-analysis because no measure of dispersion was reported; instead, it reported a metformin treatment effect that was generally consistent with other trials (−0.12; p<0.005).^158^

Of the of eight metformin trials, six could be pooled to evaluate BMI change. These six trials showed a reduction of −0.86 kg/m^2^ with very low statistical heterogeneity (95% CI, −1.44 to −0.29; k=6; I^2^=0%) (Figure 14), again with almost identical results in the profile likelihood analysis (−0.86 [95% CI, −1.45 to −0.28]; k=6; I^2^=0%). In unadjusted analyses, the difference in BMI between intervention and control groups ranged from −1.86 to 0.38 kg/m^2^. In adjusted analyses, three trials rendered statistically significant results.^135, 172, 173^ Two small, fair-quality trials could not be pooled owing to no reported measures of dispersion. Both trials reported somewhat larger metformin treatment effects on BMI than were shown in other pooled trials (−1.4 kg/m^2^ [p<0.02]^128^ and −1.26 kg/m^2^ [p=0.002]).^158^ Five of the metformin trials were conducted among participants with a wide age range,^123, 135, 158, 171, 173^ so analyses of zBMI may be preferred to analyses of BMI since many participants were still growing.

Very limited evidence is available regarding the persistence of metformin effects on weight after drug discontinuation. One study had a randomized phase of 52 weeks and then followed participants for an additional 48 weeks after drug discontinuation.^172^ This study showed a significant BMI improvement after 52 weeks of metformin treatment in adjusted analyses. The improvement persisted for 12 to 24 weeks after cessation of drug treatment, but retention was only 49 percent at the end of the monitoring period.

In qualitative analyses, we found no evidence that dose modified the effect of metformin. However, study-level analyses are confounded by differences in recruitment, quality, and level of medication adherence.

Fasting plasma glucose level. Most studies reported small or no reductions in fasting glucose level with the use of metformin (ranging from −1.62 to 0.6 mg/dL), and small increases with placebo (ranging from 0.18 to 3.47 mg/dL) (Figure 15). Pooled analyses showed a between-group difference in fasting glucose of −3.7 mg/dL with wide CIs (95% CI, −9.9 to 2.5; k=5; I^2^=64.0%) (Table 13). One outlier study showed a statistically significant difference of −17.90 mg/dL (95% CI, −27.91 to −7.89) between the metformin and placebo groups.^128^ A small fair-quality study without lifestyle modification components, this trial also exhibited the largest metformin effect on zBMI. However, this trial had a statistically significant BMI imbalance between groups at baseline and a questionable fasting glucose balance between groups that was not adjusted for. Between-group change in fasting glucose level in other studies was small and generally nonsignificant in unadjusted analyses (range, −0.90 to −4.35 mg/dL).^123, 135, 158, 171, 173^ Change in one of these trials was statistically significant upon adjustment but retained the same magnitude of change.^173^ This pattern of results was generally similar for other glucose and insulin-related outcomes (Figure 15; Appendix D Table 13).

Figure 15 Forest Plot of Change in Insulin and Glucose Outcomes in Metformin Trials (KQ 4)

Abbreviations: BL=baseline; CI=confidence interval; FPG=fasting plasma glucose; HOMA=homeostasis model assessment; hr=hour; IU=international unit; OGTT=oral glucose tolerance test; SD=standard deviation; SMD=standardized mean difference.

This figure is a forest plot of change in insulin and glucose outcomes in metformin trials

Lipid and blood pressure levels. Six of eight metformin trials reported measures of various lipids (total, low-density lipoprotein, and high-density lipoprotein cholesterol; triglycerides). None of the trials reported statistically significant differences in any lipid outcome, and pooled estimates were similarly nonsignificant with low statistical heterogeneity (Figure 16; Table 13; Appendix D Table 14).^123, 128, 135, 171–173^ Similarly, none of three reporting trials showed differences in blood pressure.^123, 135, 171^

Figure 16 Forest Plot of Change in Lipid Outcomes (mg/dL^*^ * Except for LDL:HDL, which is a ratio. ) in Metformin Trials (KQ 4)

Abbreviations: BL=baseline; CG=control group; CI=confidence interval; HDL=high-density lipoprotein cholesterol; IG=intervention group; LDL-C=low-density lipoprotein cholesterol; SD=standard deviation; TC=total cholesterol.

This figure is a forest plot of change in lipid outcomes in metformin trials

Important subpopulations. Four of eight metformin trials commented on results for sex or race/ethnicity subpopulations.^128, 140, 172, 173^ Analyses of the effect of metformin in subpopulations were limited by small study sizes, lack of prespecified subgroup analyses in individual trials, and the absence of statistical interaction testing in several trials. In the one trial with explicitly prespecified subgroup analyses and interaction testing, neither sex nor race/ethnicity modified the effect of metformin on BMI (p>0.20).^172^ Another study found that BMI decreased less in non-Hispanic blacks than in non-Hispanic or Hispanic whites; however, the p-value for the interaction test was 0.064.^173^ A study of 85 adolescents showed that females were twice as likely as males to decrease BMI by at least 5 percent, which was not explained by metformin adherence; however, interaction testing was not performed and prespecification of the analysis was not reported.^140^

##### Orlistat

Summary. In a small body of evidence (3 trials), orlistat was associated with small between-group reductions in BMI ranging from −0.94 (95% CI, −1.58 to −0.30) to −0.50 kg/m^2^ (95% CI, −7.62 to 6.62) and weight ranging from −3.90 (−25.54 to 17.74) to −2.61 kg (95% CI not reported; p<0.001). Results were significant in the two larger trials. Two of three trials reported changes in cardiometabolic risk factors and results were generally statistically nonsignificant, except for DBP reduction in a large trial (mean between-group difference, −1.81 mm Hg [95% CI not reported]; p=0.04). None of the studies followed weight change after medication use ended.

Weight. Orlistat trials reported small between-group BMI differences ranging from −0.94 (95% CI, −1.58 to −0.30) to −0.50 kg/m^2^ (95% CI, −7.62 to 6.62) (Appendix D Table 10).^108, 122, 141^ Intervention groups reduced BMI between −1.44 (95% CI, −1.96 to −0.9) and −0.55 kg/m^2^ (95% CI not reported), whereas control groups had BMI changes ranging from −0.8 (95% CI, −7.47 to 5.87) to 0.31 kg/m^2^ (95% CI not reported). BMI reduction was statistically significant in the two larger trials (n=539 and n=200)^108, 122^ but was not in the smaller trial (n=40).^141^ Baseline BMI in orlistat trials ranged from 35.6 to 41.7 kg/m^2^. In the largest trial, 19.0 percent of participants who had been given orlistat but 11.7 percent who had been given placebo achieved weight loss of 5 percent or more (p=0.03).^122^ Weight reduction in both groups peaked at about 12 weeks. Weight change ranged from −5.5 (95% CI, −18.24 to 7.2) to 0.53 kg (95% CI not reported) among orlistat participants and from −1.6 (95% CI, −21.19 to 17.99) to 3.14 kg (95% CI not reported) among participants given a placebo. Between-group differences in weight were similar among trials and ranged from −3.90 (95% CI, −25.54 to 17.74) to −2.61 kg (95% CI not reported; p<0.001); again, results were statistically significant in only the two larger trials. The one trial reporting zBMI showed a between-group difference of −0.06 (95% CI, −0.12 to 0.00) favoring orlistat.^108^

Cardiometabolic outcomes. Two of three orlistat trials reported cardiometabolic outcomes.^122, 141^ Changes in glucose, insulin, and lipid levels were statistically nonsignificant in both reporting trials. In the one trial that reported blood pressure, the orlistat group achieved a greater DBP reduction (mean between-group difference, −1.81 mm Hg [95% CI not reported]; p=0.04); changes in SBP were not statistically significant (mean between-group difference, −0.22 mm Hg [95% CI not reported]; p=0.84).^122^

Important subpopulations. Two of three orlistat trials commented on potential effect modification by sex and noted that there appeared to be no effect modification by this characteristic.^122, 141^ Two of three trials commented on race/ethnicity.^108, 122^ In the larger trial (n=539), in which 16.9 percent of the population was black, authors reported no effect modification by race/ethnicity; analyses were not explicitly prespecified and did not include interaction testing.^122^ In the smaller trial (n=200), in which 62 percent of the population was black, non-Hispanic whites in the orlistat group lost more weight than non-Hispanic blacks, but CIs overlapped (−3.7 [95% CI, −5.8 to −1.7] and −2.1 kg [95% CI, −3.7 to −0.5], respectively).^108^ Non-Hispanic white children in the placebo group did better than non-Hispanic black children, but CIs again overlapped (−1.6 [95% CI, −3.6 to 0.4] and 0.4 kg [95% CI, −1.2 to 2.0], respectively). No interaction testing was performed; specification of the analysis was unclear, but recruitment was limited to non-Hispanic whites and non-Hispanic blacks. In trials reporting power, power was not calculated for analyses of subpopulations.^122, 141^

### KQ 5 Do Weight Management Interventions for Children and Adolescents Have Adverse Effects?

#### Lifestyle-Based Weight Loss Interventions

Three of the lifestyle-based weight loss intervention trials reported no adverse events of the intervention,^124, 151, 153^ and two additional trials (published in the same article) reported no serious adverse events.^148^ Five trials similarly found no group differences on measures of disordered eating or body dissatisfaction, measures that could potentially show a benefit or harm of the interventions.^126, 142, 154, 168, 169^ For example, the good-quality trial in adolescent girls reported the proportion in the intervention and control groups with disordered eating.^126^ The proportion of girls who reported disordered eating declined in both the intervention and control groups; at baseline, 13 girls in each group reported disordered eating, and at 12-month followup, one girl in the control group and none in the intervention group reported such pathology.

#### Pharmacotherapy Interventions

Fourteen trials were included for the evaluation of adverse effects associated with pharmacotherapy. In addition to the 11 trials included for efficacy analyses,^108, 122, 123, 128, 135, 140, 141, 158, 171–173^ an additional three metformin trials with duration of less than 6 months were eligible for consideration of harm.^121, 127, 134^ These three additional trials were small fair-quality trials of 2 to 4 months’ duration and 24 to 34 participants.

##### Metformin

Summary. Gastrointestinal side effects were common but not serious in participants taking metformin. Side effects were frequently reported by those taking placebo. Discontinuation due to adverse effects, however, was relatively rare (<5%) and occurred in relatively similar proportions between groups. Reporting trials generally showed no differences in liver or kidney function, and there were no reported cases of lactic acidosis.^121, 127, 128, 135, 158, 172, 173^

Side effects. Side effects were reported inconsistently across studies but were generally common and gastrointestinal in nature. Two studies of metformin reported overall gastrointestinal symptoms and showed high prevalence in both metformin and placebo groups. In one trial, the prevalence of symptoms in the metformin and placebo groups was 29 and 19 percent, respectively,^140^ and in the other trial, the prevalence was 14 and 26 percent, respectively.^171^ Nausea was common in the two studies reporting this outcome (23% and 42% among those taking metformin);^134, 172^ just one of these trials reported nausea among placebo participants (8%). Liquid or loose stools was reported by 17 to 42 percent of metformin participants in two reporting trials;^134, 173^ in the trial reporting this outcome for placebo participants, it occurred in 17 percent (p=0.01 compared with 42% in metformin participants). Vomiting was reported by 15 to 42 percent of those taking metformin in two trials and by 3 and 21 percent of control group participants, respectively.^172, 173^ In one of the 12-month trials, one participant in the metformin group discontinued the drug for 2 weeks due to persistent diarrhea; this was unchanged and metformin was resumed.^123^

Trial protocols generally allowed for a reduction in dose when participants presented with side effects. Five trials reported the proportion of participants reducing dose. Among trials using a dose of 2,000 mg/day, between 7 and 17 percent of intervention group participants reduced dose to alleviate side effects, whereas dose reductions in placebo participants ranged from 2 to 8 percent.^123, 158, 172, 173^ A 3-month trial using a dose of 1,500 mg/day reported that no participants required a reduction in dose.^121^ Seven percent of metformin participants in a 6-month trial using a dose of 1,000 mg/day required dose reduction, but the proportion in the control group was not reported.^128^ In a trial that reported side effects by month, symptoms were most prevalent at 1 month and decreased over time such that there were no differences between the metformin and placebo groups by the end of the 6-month trial.^173^

Discontinuation due to adverse effects. Five of the 11 metformin trials reported the number of participants (for both intervention and control groups) discontinuing the trial due to adverse effects.^127, 140, 171–173^ Two trials of short duration reported no discontinuations due to adverse effects among participants receiving metformin and did not report discontinuations in placebo groups.^121, 134^ A 12-month trial reported one discontinuation in the metformin group but did not report discontinuations in the placebo group.^123^ Summed across trials, the proportion of participants discontinuing due to adverse effects was 3.8 percent (10/263) for metformin participants and 3.2 percent (7/221) for placebo participants (Table 12).

Liver and kidney function and lactic acidosis. Eight of 11 metformin trials reported measures of liver function (alanine aminotransferase, aspartate aminotransferase), kidney function (serum creatinine), or lactate levels.^121, 123, 127, 128, 135, 158, 172, 173^ In five of these trials, authors reported either no difference between groups in these measures^121, 135, 158^ or that no participants achieved abnormal levels.^128, 173^ In one trial, two participants in the metformin group and one in the placebo group had elevated alanine aminotransferase levels and discontinued therapy.^172^ In another trial, one participant in the placebo group withdrew due to an increased liver transaminase level at 1 month; this participant had fatty liver secondary to obesity which was detected by ultrasonography.^127^ In one of the 12-month trials, one participant in the metformin group experienced transient elevation of transaminases, which resolved 1 month after discontinuation.^123^ Cumulatively, there were 3 cases of elevated liver enzymes among metformin participants and 2 cases among placebo participants. There were no reported cases of lactic acidosis in the included trials.

Vitamin and hemoglobin levels. The two trials reporting B_12_ levels showed no adverse effects related to this vitamin.^121, 173^ The two trials reporting hemoglobin levels exhibited no metformin-associated differences in this outcome.^128, 173^

##### Orlistat

Summary. Gastrointestinal side effects were very common among patients taking orlistat. Discontinuation due to adverse effects was relatively rare (<5%) and was about twice as common in orlistat participants than in those taking placebo.

Side effects. Side effects were reported inconsistently across the three included trials but were primarily gastrointestinal and were very common among patients taking orlistat. Fatty or oily stools were reported by 50 to 70 percent of orlistat participants and 0 to 8 percent of those taking placebo.^108, 122, 141^ Abdominal pain or cramping were reported by 16 to 65 percent and 11 to 26 percent of those taking orlistat and placebo, respectively. Flatus with discharge was reported by 20 to 43 percent of those taking orlistat and 3 to 11 percent of those taking placebo. In two trials, fecal incontinence was reported in 9 to 10 percent of orlistat participants and 0 to 1 percent of placebo participants.^122, 141^ In the other trial, 60 versus 11 percent of orlistat and placebo participants, respectively, reported uncontrolled passage of stool or oil.^108^ One trial reported adverse effects over time.^141^ The prevalence of some but not all adverse effects decreased over time among those taking orlistat. Cramping, for example, decreased from 65 percent reporting at 1 month to 13 percent at 6 months. Fatty or oily stools, cramping, flatus with discharge, and fecal incontinence improved more over time among those taking orlistat than those taking placebo.

Discontinuation due to adverse effects. All three orlistat groups reported discontinuation due to adverse effects. Cumulatively, 3.2 percent (15/472) of orlistat participants and 1.7 percent (5/301) of placebo participants withdrew due to adverse effects. In the largest orlistat trial, there were 11 serious adverse events in the orlistat group and five in the placebo group.^122^ In the orlistat group, only one serious adverse event was thought to be possibly study-related—asymptomatic cholelithiasis leading to cholecystectomy in a 15-year-old female who had lost 15.8 kg by the time of the event. In the smaller trial, one suicide occurred in the orlistat group in a patient who was under a psychiatrist’s care.^141^ No deaths occurred in the placebo group. In the other orlistat trial, no serious adverse events occurred in the intervention group, but two occurred in the placebo group—one episode of hypoglycemia due to a pharmacy error in preparing insulin and an overnight hospital admission for lower left quadrant pain and vomiting.^108^

Vitamin levels, growth, and hormones. Two of three orlistat trials measured vitamin A, D, and E levels and reported no differences between groups.^122, 141^ All orlistat trials, however, provided multivitamin supplementation for all participants. No between-group differences in growth, bone mineral density, or sexual maturation were reported in the one trial reporting these outcomes.^8^ This trial reported a decrease from baseline in estradiol among girls taking orlistat and a slight increase among those taking placebo (p=0.05).