# 2 Methods

## Scope and Purpose

This systematic review examined the evidence for screening for obesity in children and adolescents and addressed the benefits and harms of weight management interventions in primary care or primary care–relevant settings for children and adolescents. The USPSTF will use this review to update its 2010 recommendation on screening for obesity in children and adolescents.^104^

## Key Questions and Analytic Framework

In consultation with the Agency for Healthcare Research and Quality (AHRQ) and members of the USPSTF, we developed an analytic framework (Figure 3) and five Key Questions (KQs) to guide our review. These KQs were adapted from questions addressed in the 2010 review.^105^

1. Do screening programs for obesity in children and adolescents lead to reductions in excess weight or age-associated excess weight gain, improve health outcomes during childhood, or reduce incidence of obesity in adulthood?
  a. Are there effects of screening on cardiometabolic measures (i.e., blood pressure, lipid levels, and insulin resistance)?
  b. Are there common components of efficacious screening programs?
  c. Does efficacy differ by key patient subgroups (i.e., age, race/ethnicity, sex, degree of excess weight, and socioeconomic status)?
2. Does screening for obesity in children and adolescents have adverse effects?
3. Do weight management interventions for children and adolescents that are embedded in primary care, or referable from primary care, improve health outcomes during childhood or reduce incidence of obesity in adulthood?
  a. Are there common components of efficacious interventions?
  b. Does efficacy differ by key patient subgroups (i.e., age, race/ethnicity, sex, degree of excess weight, and socioeconomic status)?
4. Do weight management interventions for children and adolescents that are embedded in primary care, or referable from primary care, reduce excess weight or age-associated excess weight gain?
  a. Are there effects of interventions on cardiometabolic measures (i.e., blood pressure, lipid levels, and insulin resistance)?
  b. Are there common components of efficacious interventions?
  c. Does efficacy differ by key patient subgroups (i.e., age, race/ethnicity, sex, degree of excess weight, and socioeconomic status)?
5. Do weight management interventions for children and adolescents have adverse effects?

Figure 3 Analytic Framework

* Blood pressure, lipid levels, and insulin resistance are secondary outcomes when reported with weight.

Abbreviations: BMI=body mass index; CV=cardiovascular; KQ=key question; QOL=quality of life.

This figure is the analytic framework that depicts the five Key Questions (KQs) addressed by the systematic review. The figure illustrates how screening children and adolescents may improve health outcomes (KQ1) and result in the identification of individuals who are overweight or have obesity who may receive interventions. Interventions may result in changes in intermediate (KQ4) and final health outcomes (KQ3). The analytic framework also depicts the possible adverse events occurring after screening (KQ2) or treatment (KQ5).

Weight management interventions are behavioral counseling, pharmacotherapy, and health care system–level approaches.

## Data Sources and Searches

In addition to evaluating all previously included studies for inclusion in the current review, we conducted an initial search for existing synthesized literature and guidelines related to screening for obesity in children and adolescents in MEDLINE/PubMed, the Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews, the Institute of Medicine, the National Institute for Health and Care Excellence, PsycINFO, the Education Resources Information Center, AHRQ, the American Academy of Child and Adolescent Psychiatry, the American Psychological Association, the Campbell Collaboration, DynaMed, the Canadian Agency for Drugs and Technologies in Health, the Institute for Clinical Systems Improvement, the National Health Services Health Technology Assessment Programme, and the Centre for Reviews and Dissemination from January 2009 through March 31, 2014. The search strategies are listed in Appendix B.

We searched for newly published literature in the following databases: MEDLINE/PubMed, PsycINFO, the Cochrane Central Register of Controlled Trials, and the Education Resources Information Center through January 22, 2016, and starting from January 2005 for screening studies (bridging from the 2005 USPSTF review^19^) and from January 2010 for treatment studies (bridging from the 2010 USPSTF review,^106^ which only covered the treatment literature) (Appendix B). We also reviewed reference lists of reviews and other studies to identify additional potentially relevant studies published in or after 1985 that were not identified by our literature searches. We managed literature search results using EndNote version 7.3.1 (Thomson Reuters, New York, NY).

To reduce the risk of reporting bias for the pharmacotherapy interventions included in our review (metformin and orlistat), we used both the Drugs@FDA and clinicaltrials.gov Web sites. For Drugs@FDA, we searched for the drug approval package for orlistat using the method described by Turner.^107^ We did not search for the metformin drug approval package as metformin is a generic name and FDA reviews for generic drugs are focused on bioequivalence rather than efficacy and safety.^107^ We examined the package inserts for both drugs to note known harms and side effects. We searched clinicaltrials.gov using the terms “orlistat” and “metformin,” restricting results to studies conducted in children (n=13 for orlistat and n=129 for metformin). For study titles that appeared to be relevant, the full records were reviewed by two investigators; studies meeting eligibility criteria were matched with published articles where possible (one study published results in clinicaltrials.gov without a subsequent journal publication^108^).

## Study Selection

Two investigators independently reviewed titles and abstracts and then full-text articles against prespecified inclusion and exclusion criteria (Appendix B Table 1). Disagreements were resolved through discussion and consensus or consultation with the other investigators. A list of excluded studies after full-text review, including the reasons for exclusion, is available in Appendix C.

We included fair- and good-quality studies published in the English language that were conducted among children and adolescents ages 2 to 18 years in “economically developed” countries, according to membership in the Organisation for Economic Co-Operation and Development,^109^ including:

- Randomized, controlled trials (RCTs) and nonrandomized, controlled clinical trials that examined the benefits or harms of screening or weight management interventions (behavioral counseling, pharmacotherapy, and health care system–level approaches) in children and adolescents.
- Large comparative cohort or case-control studies with appropriate comparison groups, large case series, or large event monitoring studies that examined harms of weight loss medications in children or adolescents.

Included trials had to have a primary aim of reducing excess weight (through weight loss or limited weight gain with growth in height) or maintaining previous reductions in excess weight and be either conducted in or recruited from health care settings or systems. We limited our examination of pharmacotherapy interventions to orlistat or metformin. We excluded studies with components that could not be implemented in primary care settings, such as surgical interventions, changes to the built environment, and interventions providing most or all of the participants’ food.

We required that studies assessing the benefits and harms of screening be conducted in a primary care setting. Studies of weight management interventions could also take place in phone, mobile, or virtual (i.e., online or computer-based) settings or in community or research settings as long as there was some connection to a health setting (e.g., recruitment exclusively from a health care setting). We excluded studies in community or university research laboratories or other nonmedical centers, college settings, and mental health clinics unless they recruited participants through a health care setting. In addition, we excluded studies conducted in correctional facilities, school classrooms, worksites, inpatient or residential treatment facilities, and emergency departments.

We required that weight management intervention studies be comprised of individuals with either an age- and sex-specific BMI in the 85th percentile or higher or those who met other similar criteria for overweight or obesity. These study populations could have had excess weight previously and currently be engaged in maintenance of weight loss. We also included studies if most (≥50%) of the sample met the criteria for overweight or obesity and the study targeted a population at high risk (≥80% had risk factors for overweight [e.g., overweight parents; Hispanic, black, or American Indian/Alaska Native ethnicity] or obesity-related medical problems [e.g., type 2 diabetes, metabolic syndrome, hypertension, lipid abnormalities, or other cardiovascular-related disorders]). For example, we would have included a trial with up to 49 percent normal-weight children in a Native American community with a very high obesity prevalence. We excluded studies limited to youth who had an eating disorder, were pregnant or postpartum, were overweight or had obesity secondary to a medical condition (i.e., polycystic ovarian syndrome, hypothyroidism, Cushing’s syndrome, growth hormone deficiency, insulinoma, hypothalamic disorder, cancer, or medication use), had an intellectual or developmental disability, or were in college.

Control groups in weight management intervention studies could include usual care, no intervention, waitlist, attention control, or a minimal intervention (e.g., pamphlets, one to two annual sessions presenting information similar to what intervention groups receive through usual care in a primary care setting, no more than 60 minutes total of estimated direct contact), and we required a placebo control for drug studies. We excluded comparative effectiveness studies.

We required that all included studies report at least one weight outcome (e.g., weight, BMI, zBMI, BMI percentile, percent overweight, total adiposity, body composition, waist circumference). Other outcomes of interest included child health outcomes (e.g., reduced orthopedic pain, sleep apnea, and asthma; decreased morbidity from diabetes mellitus or hypertension; improved depression or quality of life), adult health outcomes (obesity), intermediate outcomes (e.g., reduction or appropriate maintenance of weight or adiposity, cardiometabolic measures when weight-related measures are also reported, liver dysfunction), or adverse effects of screening or treatment (e.g., labeling, stigma or increased body image concerns, eating disorder, exercise-induced injury). We required at least 6 months postbaseline followup for all outcomes except harms, and used 12 months as the preferred outcome if it was available. We refer to “followup” to characterize months since baseline, without regard for whether the measure was taken immediately posttreatment or after some time had elapsed since treatment ended.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of included studies using criteria defined by the USPSTF^110^ and assigned each a final quality rating of “good,” “fair,” or “poor” (Appendix B Table 2). Investigators resolved disagreements through discussion.

Studies with a single “fatal flaw” (e.g., attrition >40%, differential attrition >20%) or multiple important limitations that could invalidate the results were rated as poor quality and excluded. Good-quality studies included all or most of the following: adequate randomization procedures, allocation concealment, blinding of outcome assessors, reliable outcome measures, comparable groups at baseline (with specified eligibility criteria), low attrition, statistical methods that revealed no important concerns, and adequate and faithful adherence to the intervention. We rated studies as fair quality if they did not meet most of the good-quality criteria but had no significant flaws that could invalidate the results.

One investigator abstracted data from all included studies into a Microsoft Access database (Microsoft Corporation, Redmond, WA) and a second investigator checked the data for accuracy. We abstracted study design characteristics, population demographics, baseline history of obesity and other related conditions, screening and intervention details (if applicable), health outcomes (e.g., quality of life), child weight outcomes, other intermediate outcomes (e.g., blood pressure, lipid and glucose levels), and adverse events.

## Data Synthesis and Analysis

For pharmacotherapy trials and behavior-based trials (examined separately), we used summary tables of study, population, and intervention characteristics and outcomes for each KQ. These tables and forest plots of the results were used to examine the consistency, precision, and relationship of effect size with key potential modifiers. Weight-related measures at 12 months of followup from baseline were the primary outcome for this review. Specifically, zBMI score or BMI-SDS was selected as the primary outcome if it was available, since that was the only widely available measure that could be used to compare relative degree of excess weight across ages (we refer to either of these measures as zBMI). If zBMI was not reported, BMI, weight (in kilograms), waist circumference (in centimeters), and BMI percentile were used, in order of decreasing preference. BMI percentile was chosen last because it was not frequently reported, the CDC does not recommend using above the 97th percentile, and because of the ceiling effect at the 99th percentile. Because we included different measures in this analysis, we pooled standardized mean differences in change between groups. We also conducted analyses limited to only studies reporting zBMI and found that the standardized pooled effects were very similar to analyses that included trials reporting other measures, indicating that confounding by measure is minimal or absent, so we further present a zBMI-specific forest plot showing nonstandardized mean differences in change, to ease interpretation.

Twelve months was selected as the primary outcome, even though trials could be included if they only reported a 6-month followup. However, given the questionable value of short-term weight loss that is not maintained, we selected 12 months as the primary outcome because we considered it to be long enough to have demonstrated some level of weight maintenance. In addition, it was the most commonly reported time to followup among the included trials. If outcomes were not available at 12 months, the closest followup to 12 months was used instead (range, 6 to 24 months). Because hours of contact appeared to be a strong effect modifier in the behavioral weight loss trials, these trials were grouped by estimated hours of contact and separate pooled estimates were generated for each subgroup.

If reported, change from baseline was used for analysis. Where change scores were not available, they were calculated from baseline and followup measures if possible, assuming a 0.50 correlation between baseline and followup measures of weight. We also ran sensitivity analyses assuming a higher correlation (0.80) and found that the pooled results were very similar but slightly less conservative using the higher correlation, so we report the results using the lower value (0.50). We adjusted six trials for clustering^111^ and calculated a design effect based on average cluster size and estimated intraclass correlation (0.05).

We used the DerSimonian and Laird estimation method for pooling weight outcomes,^112^ with sensitivity analyses using a restricted maximum likelihood model (REML) with the Knapp-Hartung adjustment for small samples, which is a more conservative approach when there is substantial statistical heterogeneity or the number of studies is small for behavioral trials.^113, 114^ Because there were even fewer pharmacotherapy trials for pooling, we used the profile likelihood method for sensitivity analysis.^115^ The I^2^ statistic was used to assess statistical heterogeneity^116^ and the Cochrane guidelines for interpretation were applied: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent moderate heterogeneity, 50 to 90 percent substantial heterogeneity, and greater than 75 percent considerable heterogeneity.^111^ We had insufficient data to pool other outcomes (such as cardiometabolic outcomes) but present results in forest plots without pooling.

Funnel plots and the Egger’s test were used to examine the risk of small study effects for the behavior-based weight loss trials, combining trials of all levels of estimated contact hours. We did not have sufficient data to perform these analyses for pharmacotherapy trials.

Meta-regressions were used to examine potential a priori–specified effect modifiers for the behavior-based weight loss interventions. These potential modifiers included intervention duration (in months), year of publication, study quality, whether the trial was randomized, percent followup at 12 months (or closest time), estimated hours of contact in the control group, whether supervised physical activity sessions were included in the intervention, and, among interventions offering group sessions, whether individual sessions were also offered.

Analyses were conducted in Stata version 13.1 (StataCorp LP, College Station, TX). All significance testing was two-sided and results were considered statistically significant if the p-value was 0.05 or less.

Hours of contact were estimated based on number of planned treatment sessions and the length of each session. When information on session length was not provided, we used a priori–developed assumptions to estimate contact hours; for example, assigning phone sessions described as “brief” to be 5 minutes in length, phone sessions not described as “brief” as 15 minutes, individual sessions as 30 minutes, and group sessions as 60 minutes. We estimated contact time as the total time the family spent at the clinic, so a 2-hour session that involved 1 hour of parents and children in a group together followed by 1 hour where parents and children participated in separate groups would be counted as 2 hours of contact. Interventions were grouped by hours of contact (0 to 5 hours, 6 to 25 hours, 26 to 51 hours, ≥52 hours). Cutpoints were decided first based on the cutpoint used in the previous USPSTF review (26 hours),^105^ and then subdivided those two groups post hoc based on logic and where there were discontinuities in the frequency distribution of estimated contact hours. For example, there were several interventions estimated to involved 44 to 45 hours of contact, then the next higher intervention involved 67 hours. In that case, we assigned 52 hours to be the cutoff between these groups, extending the logic from the previous review of using a cutoff of 1 hour per week for 6 months to a cutoff of 1 hour per week for 1 year. Rather than using number of sessions as our primary measure of dose, we used contact hours because it more fully captured the total time and had better distributional properties for analysis (i.e., less skewness and kurtosis). Estimated hours of contact in the first 12 months only are shown on the forest plots because the primary outcome was weight change at 12 months (or closest followup available).

## Expert Review and Public Comment

A draft research plan for this review was available for public comment from October 23 to November 19, 2014. We made no substantive changes to our review methods based on comments received. The draft version of this report was reviewed by experts and USPSTF federal partners. Comments received were reviewed, considered, and addressed as appropriate, and were primarily focused on clarifying the text, providing additional requested detail, and considerations for background and discussion text. Additionally, a draft of the full evidence report was posted on the USPSTF Web site from November 2 through November 28, 2016. Comments were reviewed, considered, and addressed as appropriate. Some suggestions for clarification of background and methods, additional discussion items, and suggestions for future research were adopted, but we made no changes to the results or conclusions.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the USPSTF. We consulted with USPSTF liaisons at key points in the review, including the development of the research plan (i.e., KQs, analytic framework, and inclusion/exclusion criteria) and the finalization of the systematic review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the report, and assisted with public comment on the research plan and draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review or the final report.