# 1 Introduction

## Condition Definition and Measures of Excess Weight

An excess of body fat is associated with a variety of health risks in children and adolescents.^1^ Because direct measurement of their body fat is difficult, is expensive due to specialized equipment requirements,^2^ and exposes youth to radiation, excess fat is usually estimated using height and weight and compared with age- and sex-based norms from reference populations to determine the percentile ranking associated with the patient’s body mass index (BMI) (calculated in kilograms divided by height in meters squared). In the United States, obesity in children and adolescents is defined as a BMI in or above the 95th percentile for the child’s age and sex or, among older adolescents, a BMI of more than 30.0 kg/m^2^ (the definition of adult obesity). Children and adolescents with a BMI in the 85th to 94th percentile, respectively, are categorized as overweight. Health care providers in the United States usually use U.S.-specific norms developed by the Centers for Disease Control and Prevention (CDC) for children age 2 years and older,^3^ the ages covered by this review, but other norms are also available.^4–7^

Definitions of severe obesity have also been proposed, including using the 99th percentile (approximately equivalent to BMI ≥34 kg/m^2^ among 14- to 16-year-olds)^1^ and 120 percent of the 95th percentile or BMI greater than 35 kg/m^2^ (the definition of adult level II obesity).^8^ The latter definition is generally preferred because percentile scores above the 97th percentile are based on small numbers of children and so are not robust.

Norms also differ slightly in how they categorize the adiposity of children; the CDC reference norms are more likely to categorize children as having obesity than the International Obesity Task Force (IOTF) curves.^9^ Other common measures of excess weight are the BMI z-score (zBMI) or BMI standard deviation score (BMI-SDS). Although zBMI and BMI-SDS are derived differently, they are effectively the same measure, and refer to the number of standard deviations (SDs) the child’s BMI falls from the median according to CDC or IOTF norms. For reference, Table 1 shows BMI and weight in the 85th and 95th percentiles, along with corresponding zBMI values, assuming a 50th percentile height.

Table 1 Illustrative Weight at Selected Percentile Cutoffs (and Corresponding zBMI According to CDC Norms) for Girls and Boys at Ages 4, 8, 12, and 16 Years

Sex | Age (y) | 85th Percentile for age and sex (zBMI=1.036) | | 95th Percentile for age and sex (zBMI=1.645) | | Difference between 95th and 85th percentiles
Sex | Age (y) | BMI | Weight (lb)^*^ | BMI | Weight (lb)^*^ | Weight (lb)
Girl | 4 | 16.8 | 37.8 | 18.0 | 40.5 | 2.8
Girl | 8 | 18.3 | 65.9 | 20.7 | 74.5 | 8.6
Girl | 12 | 21.7 | 109.9 | 25.3 | 127.6 | 17.8
Girl | 16 | 24.7 | 143.5 | 28.9 | 168.2 | 24.7
Boy | 4 | 16.9 | 38.0 | 17.8 | 40.1 | 2.0
Boy | 8 | 18.0 | 64.6 | 20.1 | 72.2 | 7.6
Boy | 12 | 21.0 | 106.2 | 24.2 | 122.4 | 16.2
Boy | 16 | 24.2 | 140.9 | 27.6 | 160.4 | 19.5

Abbreviations: BMI=body mass index; zBMI=body mass index z score; y=year(s).

Weight calculations assume 50th percentile height for age and sex.

Note: Height and 85th and 95th BMI percentiles from the Centers for Disease Control and Prevention growth charts (http://www.cdc.gov/growthcharts/html_charts/statage.htm and http://www.cdc.gov/growthcharts/html_charts/bmiagerev.htm).

Other anthropometric measures have been developed in adults that consider waist circumference in addition to height and weight, such as a body shape index^10^ and the anthropometric risk index, which also incorporates hip measurements.^11^ Compared with BMI and simpler measures of central adiposity, these newer measures show a more linear and, in some instances, stronger relationship with mortality.^12, 13^ In adolescents, the body shape index has shown a stronger relationship than BMI with prediabetes,^14^ although evidence is mixed on its association with blood pressure.^14, 15^ These measures may be useful complements to BMI in predicting future health risk.

## Prevalence

Almost 17 percent of 2- to 19-year-olds in the United States have obesity, according to the 2011–2012 National Health and Nutrition Evaluation Survey (NHANES), and 31.8 percent are either overweight or have obesity.^16^ Younger children (ages 2 to 5 years) are less likely to have obesity than older children, and there is substantial variability across racial/ethnic groups. Obesity prevalence is generally 21 to 25 percent among Hispanic and black children age 6 years or older, whereas prevalence ranges from a low of 3.7 percent for Asian 6- to 11-year-old girls to a high of 20.9 percent for non-Hispanic white adolescent girls.^16^ These prevalence figures represent substantial increases over the past three decades, although overall the rate of obesity may be stabilizing in recent years; the prevalence of obesity in children and adolescents in 2011–2012 does not differ statistically from 2003–2004 figures (Figure 1). However, the proportion of children meeting criteria for severe (class II and III) obesity has increased since 2003.^17^ Other data support the NHANES evidence that childhood obesity rates have stopped increasing, including state-level data showing similar trends and surveys of declines in calories from sweetened drinks and fast food restaurants.^18^ However, obesity rates continue to increase in some subpopulations, such as Hispanic males and African American girls, exacerbating racial/ethnic disparities in obesity.^18^

Figure 1 Prevalence of Obesity Among Children and Adolescents Ages 2 to 19 Years, United States^10,287,288^

This figure displays the increased prevalence of obesity among children and adolescents ages 2 to 19 years in the United States over time (1971–2014)

## Burden

Excess adiposity can have a direct harmful effect on physical health prior to adulthood; however, the primary concern in most cases of excess weight in childhood and adolescence is the associated continued obesity into adulthood (Appendix A). Estimates of adult obesity for children who meet criteria for obesity are wide ranging and, not surprisingly, increase with age and degree of excess weight in childhood.^19^ A 2015 systematic review of 23 large, prospective longitudinal studies found that close to 80 percent of adolescents with obesity go on to have obesity as adults; this figure is slightly lower (approximately 70%) when adult BMI is measured at age 30 years or older. Approximately 64 percent of preadolescents with obesity also have obesity in adulthood. Meta-analyses of 20 of the 23 studies showed a strong association between childhood obesity and adult obesity, as children with obesity were about 5 times more likely to have obesity as adults than children without obesity (pooled relative risk [RR], 5.21 [95% confidence interval (CI), 4.50 to 6.02]).^20^ In addition, the risk is higher among children who are overweight throughout their childhood; 62 percent of youth in a prospective cohort in the United Kingdom who were overweight or had obesity at age 7 years as well as in adolescence had obesity as an adult, but only 49 percent who were overweight or had obesity during adolescence but not at age 7 years had obesity as an adult (Table 2).^21^

Table 2 Proportion of Adults Who Have Obesity Among Persons With or Without Overweight or Obesity in Childhood or Adolescence, in Three British Cohorts^15^

Overweight or obesity in childhood (age 7 years) | Overweight or obesity in adolescence (ages 15–16 years) | Proportion with obesity in adulthood (ages 34–43 years)
Yes | Yes | 62.3%
Yes | No | 25.8%
No | Yes | 49.4%
No | No | 11.8%

Although cardiovascular disease takes many years to develop, obesity is associated with poor cardiovascular and metabolic parameters during childhood, including high blood pressure, abnormal lipid levels, and insulin resistance.^22–28^ Childhood obesity appears to detrimentally alter cardiovascular structure and function prior to adulthood.^29^ Childhood obesity has also been associated with other near-term health effects, such as increased risk of asthma, obstructive sleep apnea, orthopedic difficulties, early maturation, polycystic ovarian syndrome, and hepatic steatosis.^30^ Nonalcoholic steatohepatitis is a serious condition that can lead to cirrhosis and the need for liver transplant. The proportion of children experiencing these health effects increases with increasing zBMI.^31^

In addition, children and adolescents who are overweight or have obesity report lower self-esteem and health-related quality of life (particularly related to physical function and mobility) than normal-weight youth.^32–34^ Weight-based victimization (e.g., teasing and bullying) has been cited as the primary reason for victimization in school settings among adolescents and elementary-aged children.^35–37^ However, many of the studies of psychosocial issues compared youth identified through clinic settings with healthy controls (with overweight or obesity) from the community or schools. Youth seeking care for their weight may not be broadly representative of children and adolescents who are overweight or have obesity. Surveys of representative community samples of children and adolescents who currently have or previously had obesity have not reported poorer psychosocial outcomes (self-esteem, depression, school/social functioning) despite respondents’ awareness of their (past or present) excess weight.^38, 39^

Obesity maintained into adulthood can significantly affect health. Long-term prospective studies show that childhood BMI is associated with an increased risk of all-cause mortality, cardiovascular- and metabolic-related conditions/risk factors, and several types of cancer.^40–47^ For example, one study found an increased risk of future heart disease of approximately 5 percent for every additional BMI unit in adolescence, not controlling for adult BMI,^42^ and BMI during late adolescence has been associated with increased risk of cardiovascular death over 40 years of followup.^48^ However, studies that control for adult BMI have generally found no such associations, suggesting that childhood obesity alone has minimal direct effect on adult morbidity and mortality.^40, 41^ Indeed, prospective data show that risks of adult cardiovascular disease–related factors in adults without obesity are similar among those who had obesity as children and those who did not, which suggests that harmful cardiovascular effects in childhood may be reversible with weight loss.^49^

Future physical health risks in children categorized as overweight (but not having obesity) are assumed to vary depending on body composition, BMI trajectory, family history, and other factors.^1^ However, they likely primarily function through increasing the risk of adult obesity.

## Etiology and Natural History

Genetics play a substantial role in the development of obesity; based on studies of twins and adoptees, heritability is estimated to be 0.6 or higher.^50, 51^ However, genetic susceptibility is a continuous trait, thought to be multidetermined, and involves interaction between genetics and environment in most cases.^50^ In recent decades, numerous changes in the social, cultural, food, and built environments in the United States have made it increasingly easy to eat more calorie-dense food and exercise less,^52^ in stark contrast to conditions of periodic energy stress under which adipose tissue and its function evolved.^53^ Some of the more obvious changes include increased availability of inexpensive fast food, sugar-sweetened beverages, and processed convenience foods high in sugars, fats, and salt; widespread use of cars or other automated transport; labor-saving machines in the home and workplace; and dramatic increases in screen time. More subtle changes, such as lack of sleep, widespread use of indoor heating and air conditioning, and pharmaceutical iatrogenesis, may also be contributing to the high rates of obesity.^54^

Young persons can develop obesity at any point during their childhood or adolescence. Conversion from overweight to obesity is quite high among young children; in a large longitudinal cohort study in the United States, 20 percent of children who were overweight (but did not have obesity) in kindergarten met criteria for obesity in the next year, and the annual incidence of obesity was 10 percent or higher through third grade among those who had been overweight.^55^ In contrast, the annual incidence of obesity among children who were not overweight ranged from 1.2 to 2.4 percent.

BMI is somewhat stable across the lifespan. Correlations between childhood BMI and BMI 10 years later range from 0.67 to 0.78, and remain at about 0.40 after 30 years for children age 10 years and older.^56^ Once a person develops obesity, the body’s biochemical feedback mechanisms conspire to maintain the excess weight and to regain lost weight.^57, 58^ For example, one study found that adults who previously had obesity require 15 percent fewer calories to maintain a normal weight than someone who never had obesity.^50^ This mechanism is compounded by the fact that among persons who previously had obesity, changes in neuronal signaling in response to food decrease satiation and perceptions of the amount of food eaten, among other effects.^58^ Thus, once excess weight is established, weight loss can be very difficult. Another example of the tenacity of excess weight is that in clinical trials, control groups generally show very little improvement in excess weight, whereas in studies of other conditions, control groups frequently improve simply as a function of participating in a trial.^59^

## Risk Factors

The strength of the association of some risk factors for childhood obesity appears to change with age, although some are more consistent across the age span. Parental obesity is a strong risk factor for all ages.^51, 60–62^ A recent large study of the transmission of excess weight in biological and adoptive families concluded that while overweight (without obesity) in children is largely related to environmental factors, obesity exhibits a highly genetic component.^63^ For children of all ages, poor diet (e.g., consumption of sugar-sweetened beverages and calorie-dense foods), low levels of physical activity, short sleep duration, and sedentary behaviors (e.g., high amounts of screen time) are risk factors for childhood obesity.^64–68^ Dieting to lose weight and loss of control of eating are both associated with greater weight gain in later childhood and adolescence among children who are already overweight or have obesity or who have a parent who is overweight or has obesity.^69^

Similarly, a low family income in childhood increases the risk for obesity and overweight throughout childhood.^70, 71^ Environmental factors specific to the neighborhood in which an adolescent lives, such as food and retail scale and physical disorder, have been associated with increased odds of having obesity among adolescent girls.^72^ Among younger children, factors associated with obesity include maternal diabetes, maternal smoking, gestational weight gain, rapid infant growth, and short sleep duration.^60, 61, 73–75^ In addition, a decrease in physical activity participation in the preteen years is a risk factor for excess weight in adolescence.^64^

The prevalence of obesity by race/ethnicity is clearly variable (Figure 2).^16^ Racial/ethnic differences in both nongenetic and genetic risk factors likely contribute to disparities in obesity prevalence, with socioeconomic status being one of the strongest factors.^76, 77^ Other factors may also play a role. For example, black and Latino children are more likely to have a television in the bedroom and higher intake of sugar-sweetened beverages and fast food (controlling for child sex and socioeconomic factors) compared with white children.^78^ Genetic variability might be due to adaptation to longer-term stresses in the geographic region in which different groups evolved, perhaps related to climate and local disease load.^53^ In addition, body composition differs across race; non-Hispanic black children have lower levels of body fat at a given BMI level than Mexican American and non-Hispanic white children. For example, among children meeting the definition of obesity based on their BMI, 92 to 95 percent of non-Hispanic white and Mexican American children but 86 percent of non-Hispanic black children were in or above the 70th percentile for adiposity based on direct measures of body fat with dual-energy X-ray absorptiometry. Differences were even more striking among children meeting the BMI-based definition of overweight; 66 to 67 percent of Mexican American children but 58 percent of non-Hispanic white children and only 30 percent of non-Hispanic black children were in or above the 70th percentile for adiposity.^79^ On the other hand, cardiometabolic risk is increased at a given BMI in persons of south Asian ancestry compared with persons of European ancestry, at least among adults.^80^

Figure 2 Prevalence of Obesity Among Youth Ages 2 to 19 Years Based on BMI Percentile for Age and Sex, by Sex and Race/Hispanic Origin, United States, 2011–2014^288^

This figure displays the prevalence of obesity among children and adolescents ages 2 to 19 years, based on BMI percentile for age and sex, by sex and race/Hispanic origin in the United States (2011–2014)

## Rationale for Screening in Children

Screening enables clinicians to identify children needing a more thorough assessment of obesity risk and to provide an appropriate level of counseling. Counseling may range from simple healthy lifestyle messages for those with a BMI below the 85th percentile, to in-office weight management counseling, to tertiary care referral. Because many parents do not recognize that their children are overweight or have obesity,^81^ providers could play an important role in initiating early intervention when weight management efforts (stabilizing weight with growth in height or actual weight reduction) might be more likely to be successful. As the Expert Committee recommendation notes,^1^ health care visits provide a good opportunity to identify excess weight because of the private setting and because the setting frames excess weight as a health issue.

For children with severe obesity for whom weight reduction is the goal, losing a substantial amount of weight can be very difficult, at least in part because of the body’s inclination to maintain body weight.^82^ In adulthood, approximately 0.8 percent of women and 0.4 percent of men with a BMI between 30 and 35 kg/m^2^ will attain a nonoverweight body weight in a given year; the rates are much lower in adults with severe obesity.^83^ For children who are still growing, it may be easier to lose a small amount of weight or slow the increase in weight as they grow in order to bring weight and height in line. For example, a 4-year-old girl with a BMI in the 95th percentile for age and sex (and 50th percentile for height) is only approximately 3 lb above the cutoff for normal weight, but a 16-year-old girl with the same BMI is almost 25 lb above normal weight (Table 1).^84^ Similarly, it might be difficult for a child to change long-entrenched eating and activity habits, but helping parents and families adopt healthy habits early in the child’s life could make this task easier.

## Screening Strategies

Both the 2007 Expert Committee and the 2011 National Heart, Lung, and Blood Institute Expert Panel recommend using BMI to screen for obesity risk^85^ starting at age 2 years. BMI is recommended due to its feasibility of measurement, acceptable accuracy in identifying young persons with excess weight (particularly at higher BMI levels), and evidence linking BMI to cardiovascular risk factors.^82^ The Expert Committee further describes the health care setting as a good place to identify children with excess weight “because the setting frames the condition as a health problem and because the visit is private.”^1^ Both groups advocate using BMI as a screening measure and not as a definitive measure of risk; instead, they recommend that elevated BMI should lead to further evaluation rather than directly to intervention, since this index is not a perfect measure of adiposity or future health risk (as seen, for example, by the variability in association between BMI and body fat across racial/ethnic groups), particularly in the 85th to 95th percentile range.

A systematic review of studies comparing BMI with direct measures of body fat (e.g., dual-energy X-ray absorptiometry, air-displacement plethysmography, hydrostatic weighing, bioelectrical impedance analysis, or equivalent) found that specificity was generally 95 percent or higher for youth with BMI-for-age in the 95th percentile or greater. In other words, the vast majority of young persons without excess adiposity had a BMI that also indicated they did not have obesity (usually defined as <20% to 30% body fat, or <95th percentile for body fat). Sensitivity was wide ranging (depending on the reference standard used, among other factors) and uniformly lower than specificity. Across all studies, about 73 percent of young persons with excess adiposity were identified as having obesity by their BMI. Thus, in the 95th percentile BMI-for-age cutoff, 27 percent are misclassified as not having excess adiposity when they really do.^86^ As percentile scores rise higher than the 95th percentile, the likelihood of excess adiposity also grows higher.

Waist circumference is another potential useful measure that correlates with central adiposity. There is growing interest that waist circumference may provide additional, unique information. Some research shows that waist circumference is a better predictor than BMI of physiologic risk factors (e.g., insulin resistance, high blood pressure, high serum cholesterol, metabolic syndrome), but the norms and cutoffs are not well established and the Expert Committee does not recommend its routine use.^82^

Once a child is identified as being overweight or having obesity, the discussion with parents must be handled sensitively. The Expert Committee provides some sample language for such a conversation and notes that use of the terms “fatness,” “excess fat,” and “obesity” are perceived as derogatory, and suggests using terms such as “overweight,” “weight,” “excess weight,” and “BMI” instead.^1^

## Treatment Approaches

Although not all have been rigorously evaluated, interventions have been designed across the full spectrum of obesity prevention and management, from interventions to promote healthy lifestyle habits in children without excess weight to help them avoid future obesity, to intensive multidisciplinary approaches to help adolescents with severe obesity lose weight to avoid or reverse deleterious health effects of obesity. In fact, in some cases, the same intervention could be viewed as preventive for a child who has a normal BMI but as a treatment intervention for a child who is overweight or has obesity. Some adolescents who have obesity may be prescribed adjunctive medication to facilitate weight loss, and adolescents with extreme obesity experiencing ill health effects may be candidates for weight loss surgery.

At minimum, all patients and their parents can be counseled on the importance of physical activity, what constitutes a healthy diet, and other actions that promote healthy weight (e.g., eating breakfast daily, encouraging family meals, limiting eating out). For children and adolescents meeting the BMI criterion for obesity or overweight along with other risk factors, the Expert Panel recommends a systematic series of increasingly intensive interventions based on degree of obesity, associated health effects, motivation for weight management, clinic resources, and other factors.^1^ Brief descriptions of the intervention stages are provided in Table 3, although this stage approach has not been specifically tested.

Table 3 Expert Committee Stages of Obesity Treatment

Stage | Brief description
Stage 1: Prevention Plus | Prevention counseling message, but with weight management goal Include motivational interviewing techniques Primary care office setting Counseling provided by physician, advanced practice nurse, physician assistant, or office nurses, with appropriate training Family and provider work together to identify appropriate behavioral target. Followup frequency tailored to individual family Increase to Stage 2 if lack appropriate improvement after 3–6 months
Stage 2: Structured Weight Management | More support and structure provided than Stage 1, with specific eating and activity goals, monitoring, and planned reinforcement Office staff with training in motivational interviewing, monitoring, and reinforcement techniques establish goals, see families for followup care, and may provide group sessions Counseling by dietitian or clinician with training in creating eating plan Other specialty providers involved as needed (e.g., family therapist, physical/exercise therapist) Usually monthly followup Increase to Stage 3 if have not met goals after 3–6 months
Stage 3: Comprehensive Multidisciplinary Intervention | Structured program with behavior modification (at least food monitoring, goal-setting, contingency management) Multidisciplinary team with expertise in childhood obesity, including behavior specialist, registered dietitian, exercise specialist, primary care provider Usually weekly visits for 8–12 weeks, then monthly Generally not possible in primary care setting Only increase to Stage 4 after considering patient’s maturity and ability to understand risks, willingness to maintain physical activity and appropriate diet and behavioral monitoring
Stage 4: Tertiary Care Intervention | For youth with severe obesity Include medications, very low-calorie diet, or weight control surgery Should occur in pediatric weight management centers Multidisciplinary team with standard clinical assessment protocols

For patients who have severe obesity and for whom behavioral approaches alone have not been successful, medications may be used in conjunction with behavioral approaches. Orlistat is the only approved drug for children and adolescents age 12 years or older. Orlistat is available by prescription only in adolescents but is available over the counter for adults age 18 years and older. The U.S. Food and Drug Administration (FDA) has approved four new medications for weight management in adults since 2012: Belviq (lorcaserin), Qsymia (phentermine-topiramate), Saxenda (liraglutide), and Contrave (naltrexone-bupropion). None are recommended for persons younger than age 18 years because their safety and effectiveness have not been established for this age group, nor have any short-term weight-loss medications. Metformin and, to a lesser degree, bupropion are cited as being used off label for weight loss but are not approved for this purpose, including among children and adolescents.

Adolescents who have severe obesity and have not had success with other intervention approaches may be candidates for bariatric surgery. Gastric banding devices have been approved by the FDA for patients age 18 years or older. According to the National Institute of Diabetes and Digestive and Kidney Diseases, childhood obesity experts suggest that bariatric surgery may be considered for youth who have tried for at least 6 months to lose weight and not had success, have extreme obesity (BMI >40 kg/m^2^), are at their adult height, and have serious health problems linked to weight.^87^ The American Society for Metabolic and Bariatric Surgery recommends that BMI selection criteria for a bariatric procedure include a BMI of 35 kg/m^2^ or higher with major comorbid conditions (e.g., diabetes, severe steatohepatitis, pseudotumor cerebri, moderate-to-severe obstructive sleep apnea) or a BMI of 40 kg/m^2^ or higher with other comorbid conditions (e.g., hypertension, insulin resistance, glucose intolerance, substantially impaired quality of life or activities of daily living, dyslipidemia, sleep apnea with apnea-hypopnea index >5). Adolescents undergoing bariatric surgery should be carefully assessed for their ability to comply with the medical regimens and followup care.^88^

## Current Clinical Practice in the United States

Routine assessment of BMI percentiles appears to have increased substantially in the past decade, starting from approximately 5 percent of visits in the mid-2000s, soon after the CDC’s 2000 growth charts were published.^1, 89^ A study of 10 large health plans showed a range of 21 to 81 percent of children with visits had BMI percentile recorded in 2005–2006, with most plans reporting a range of 62 to 73 percent.^90^ A large managed care organization with an electronic medical record reported that after clinical practice guidelines (including automatic calculation of BMI and BMI percentile upon entry of pertinent data) were implemented, BMI percentile calculation increased from 66 percent of visits with pediatric patients in 2007 to 94 percent of visits in 2010.^91^ These data are consistent with focus group data in which physicians reported that access to electronic medical records was an important facilitator of BMI percentile calculations.^92^

The proportion of youth who are overweight or have obesity who have been identified as such by their providers is difficult to determine and undoubtedly varies across settings. The Health Maintenance Organization implementation project noted an increase in documented recognition of excess weight in children and adolescents, from 12 percent (combining youth who are overweight and those with obesity) before implementation of the guidelines to 61 percent afterward.^91^ Other data suggest that providers are much more likely to recognize and note excess weight in the medical charts of youth who have obesity than those in the overweight range. In a study examining chart notes and physician visit surveys, 86 percent of youth with a BMI in the obese range were identified as having obesity in the charts but only 27 percent of those who were overweight were identified as such.^93^ NHANES and chart review data from around 2000 suggest that approximately half of youth with a BMI in the obese range were typically identified as having obesity by their physicians,^94, 95^ but more recent chart review data in single locations showed identification rates of 21 to 53 percent for children with obesity.^96–98^ Based on NHANES data only, 17 percent of youth who were overweight (but did not have obesity) were identified as such.^95^ These disparate data suggest that recognition of obesity varies considerably across settings and is substantially lower for overweight than obesity.

Once a child or adolescent was recognized as being overweight or having obesity, 50 percent had documentation of weight management counseling in a large health maintenance organization, after clinical practice guidelines for childhood obesity were implemented (measured in 2010).^91^ These results are not out of line with studies of chart review from the 2000s, in which one half to three quarters of patients recognized and noted in charts as being overweight or having obesity were counseled to change their diet or physical activity level.^1, 94, 98^

### Weight Loss Activities in U.S. Adolescents

According to the 2011 Youth Risk Behavior Survey Philadelphia sample, 79.0 percent of girls and 63.9 percent of boys who were overweight or had obesity reported wanting to lose weight. Further, 52.2 percent of girls and 29.6 percent of boys who wanted to lose weight were actively trying. Of those who wanted to lose weight, approximately one third performed physical activity 5 to 7 days per week and more than two thirds reported 2 or more hours of screen time per day. Almost one third of girls and one fifth of boys who wanted to lose weight reported extreme dieting behaviors (fasting, diet pills, or vomiting for weight loss).^99^ Similarly, a separate study of middle school students reported high rates of weight loss behaviors that are longitudinally associated with increased risk of overweight or obesity, such as fasting, using energy powders or drinks as food substitutes, smoking cigarettes, using laxatives or diuretics, and taking diet pills (82% of girls and 36% of boys).^100^

### National Initiatives Related to Childhood and Adolescent Obesity

Multiple national initiatives at the provider and population levels target reduction in childhood and adolescent obesity. At the provider level, major organizations have developed guidelines for screening and intervention (Table 4). These guidelines are generally consistent in recommending that providers screen for obesity using BMI and CDC growth charts and offer or refer patients to weight control interventions or behavior change counseling. Some recommendations are specific to age, BMI percentile, and treatment progress.^1, 85^

Table 4 Childhood Obesity Screening and Intervention Recommendations and Guidelines by Major Health Organizations

Organization Date | Recommendation
Canadian Task Force on Preventive Health^305^ 2015 | Growth monitoring: For all children and youth aged 17 years and younger who present to primary care, recommend growth monitoring (measurement of height or length, weight, and BMI calculation or weight-for-length according to age) is recommended at all appropriate primary care visits using the 2014 WHO Growth Charts for Canada. (Strong recommendation; very low-quality evidence) Prevention of overweight and obesity in healthy-weight children: For all children and youth aged 17 years and younger who have a healthy weight (i.e., who maintain a healthy BMI trajectory according to the WHO Growth Charts for Canada), it does not apply to children and youth with eating disorders, or who are underweight, overweight or obese, recommend that primary care practitioners not routinely offer structured interventions aimed at preventing overweight and obesity in healthy-weight children and youth aged 17 years and younger. (Weak recommendation; very low-quality evidence) Management of overweight and obesity:; - For children and youth 2 to 17 years of age who are overweight or obese, children and youth with health conditions for which weight management is inappropriate are excluded; recommend that primary care practitioners offer or refer to structured behavioural interventions aimed at healthy weight management. Structured behavioral interventions are intensive behavioural modification programs that involve several sessions that take place over weeks to months, follow a comprehensive approach delivered by a specialized interdisciplinary team, involve group sessions, and incorporate family and parent involvement. Interventions examined included behaviourally based prevention interventions focused on diet, increasing exercise, making lifestyle changes or any combination of these. These can be delivered by a primary care team in the office or through a referral to a formal program within or outside of primary care, such as hospital-based, school-based or community programs. (Weak recommendation; moderate quality evidence); - Recommend that primary care practitioners not offer orlistat aimed at healthy weight management for children aged 2 to 11 years. (Strong recommendation; very low-quality evidence); - Recommend that primary care practitioners not routinely offer orlistat aimed at healthy weight management for youth aged 12 to 17 years. (Weak recommendation; moderate-quality evidence); - Recommend that primary care practitioners not routinely refer for surgical interventions. (Strong recommendation; very low-quality evidence)
National Association of Pediatric Nurse Practitioners (NAPNAP)^306^ 2015 | Identification of childhood overweight/obesity through accurate measurement and documentation of height and weight parameters including height/weight ratio in children younger than 2 years and height and weight parameters and BMI in children 2 years and older and blood pressure beginning at age 3. Pediatric health care providers should obtain a comprehensive health and medical history, including family history and risk for comorbid conditions, family eating and physical activity patterns, home and neighborhood environments, and community resources. Interventions should be culturally sensitive, family-centered interventions that focus on health and lifestyle modifications, not weight, when working with children who are overweight and obese. Patient-centered practices, such as motivational interviewing, should be used when partnering with children and families to identify goals for lifestyle and health behavior changes that are targeted, realistic, and attainable. Pediatric health care providers should incorporate clinical practicum experiences related to prevention of pediatric overweight and obesity in educational programs for pediatric health care providers who care for children and families. They should recognize and utilize current, evidence-based, and evolving platforms such as social media and mobile technology to identify, prevent, and manage childhood overweight and obesity.
American Association of Family Physicians (AAFP)^307^ 2010 | [Endorsement of USPSTF Recommendation] Clinicians should screen children aged 6 years and older for obesity and offer or refer them to comprehensive, intensive behavioral interventions to promote improvement in weight status. (Grade: B recommendation)
Institute for Clinical Systems Improvement (ICSI)^308^ 2013 | BMI should be calculated and documented in the medical record of all children ages 2–8 at least annually and CDC growth charts should be used for children ages 2–18. Assessment of diet, physical activity, and sedentary behaviors should be done annually and used to target appropriate messages to each family.
Community Preventive Services Task Force^309^ 2013 | The Community Guide has issued a series of recommendations related to provider-level interventions for obesity prevention and control. Specifically, they found insufficient evidence to determine the effectiveness of the following to prevent and control obesity among children, adolescents, or adults:; - Provider education alone; - Provider feedback alone; - Provider reminders alone; - Multicomponent provider-oriented strategies; - Combination of multicomponent provider-oriented interventions
National Heart, Lung, and Blood Institute (NHLBI) Expert Panel^85^ 2011 | Panel recommended identifying children and adolescents aged 2–21 years at high risk for obesity (based on parental obesity, excessive gain in BMI, and change in physical activity) (Grade B). The guidelines concluded that “there is good evidence for the effectiveness of combined weight loss programs that included behavior change counseling, negative energy balance through diet, and increased physical activity in addressing obesity in children older than age 6 years with a BMI at or greater than 95th percentile and no comorbidities (Grade A). However, such programs have primarily been shown to be effective in a comprehensive weight loss program or research settings, with only a small number shown to be effective in primary care settings.”
Institute of Medicine (IOM)^310^ 2011 | Recommended that health care providers measure weight and length or height in a standardized way, plotted on WHO growth charts (ages 0–23 months) or CDC growth charts (ages 24–59 months), as part of every well-child visit. They also recommend that health care professionals consider children’s attained weight-for-length or BMI ≥ 85th percentile, rate of weight gain, and parental weight status as risk factors in assessing which young children are at highest risk of later obesity and its adverse consequences.
The Expert Committee^1^ 2007 (convened by American Medical Association, Health Resources and Services Administration, and Centers for Disease Control and Prevention, endorsed by the American Academy of Pediatricians) | Primary care providers should universally assess children for obesity risk to improve early identification of elevated BMI, medical risks, and unhealthy eating and physical activity habits. Providers can provide obesity prevention messages for most children and suggest weight control interventions for those with excess weight. The writing groups also recommend changing office systems so that they support efforts to address the problem. BMI should be calculated and plotted at least annually, and the classification should be integrated with other information such as growth pattern, familial obesity, and medical risks to assess the child’s obesity risk.

Abbreviations: BMI=body mass index; CDC=Centers for Disease Control and Prevention; USPSTF=U.S. Preventive Services Task Force; WHO=World Health Organization.

Because of the multiple layers of influence on eating and physical activity and the limited long-term success of obesity treatment, major organizations have called for population-based obesity prevention approaches as a necessary complement to clinical preventive strategies and treatment programs for those who already have obesity.^101^ Population-based approaches involve educational and motivational messages targeted at the entire population as well as efforts from worksite, government, public health, and health care organizations to promote health consciousness and accessibility of healthy choices; such programs are designed to “make healthy eating and physically active lifestyles easier to adopt and more socially acceptable and reinforcing.”^101, 102^

HealthyPeople 2020, for example, established multiple population-oriented objectives, which included improving access to healthier food in schools and communities, encouraging daily physical education and recess in schools, reducing screen time, and encouraging physical activity opportunities in child care settings. Population-based guidelines and policies from other bodies are shown in Table 5.

Table 5 Population-Based Guidelines and Policies for Childhood Obesity Prevention, Screening, and Treatment

Organization | Recommendation
Medicaid^311^ | Diagnostic and Treatment (Early Pediatric Screening, Diagnostic and Treatment) benefit covers all medically necessary obesity-related services, including screening.
Affordable Care Act^312^ | The Affordable Care Act requires health plans to cover childhood obesity screening and counseling
Community Preventive Services Task Force^309^ | The Community Guide found insufficient evidence to recommend school-based obesity prevention and control programs and mass media campaigns to reduce screen time or change weight-related behaviors and outcomes.
Center for Disease Control and Prevention^313^ | Recommends 26 community strategies to prevent obesity in the United States, many of which directly affect children and adolescents. Recommendations include strategies to: promote availability of affordable healthy food and beverages, promote healthy food and beverage choices, encourage breastfeeding, encourage physical activity among children and youth, create safe communities that support physical activity, and encourage communities to organize for change.

Additionally, performance measures are used at the health systems level to encourage screening and intervention for childhood obesity. The 2014 Healthcare Effectiveness Data and Information Set measures include a metric for “Weight Assessment and Counseling for Nutrition and Physical Activity for Children/Adolescents.” This measure assesses the percentage of health system members ages 3 to 17 years who had an outpatient visit with a primary care physician or obstetrician/gynecologist and who had evidence of BMI percentile documentation, counseling for nutrition, and counseling for physical activity during the year of measurement.^103^

## Previous U.S. Preventive Services Task Force Recommendation

In 2010, the U.S. Preventive Services Task Force (USPSTF) recommended that clinicians screen for obesity in children age 6 years and older and offer or refer them to comprehensive, intensive behavioral interventions to promote improvement in weight status (B recommendation).^104^ This recommendation was based on the USPSTF’s conclusion that there was moderate certainty that the net benefit is moderate for screening for obesity in children age 6 years and older and for offering or referring them to moderate- or high-intensity interventions to improve weight status.