# Appendix F Ongoing Studies

Author, Year Study Country | Aim | Participants (number of participants) | Intervention | Comparator | Relevant Outcomes | Status as of April 2016
Alia, 2015^328^ Families Improving Together (FIT) for weight loss United States | Multi-theoretical, multilevel process evaluation was used to assess implementation of the Families Improving Together (FIT) for weight loss intervention | African American adolescent ages 11–16 who is overweight or obese, defined as having a BMI ≥85th and <99th percentile for age and sex (n=520) | (1) Group Motivational coaching and Family Weight Loss (M + FWL) -re-randomised (2) M+ FML + online health education program + booster sections | (1) Group comprehensive health education program -re-randomised (2) Online health education program + booster sections | zBMI | In progress, estimated completion date: Jun 2017
Anderson, 2015^329^ Whanau Pakari: a multidisciplinary intervention for child and adolescent obesity New Zealand | Inform the development of management programs for obese children and adolescents that are appropriate for indigenous populations and investigate whether those at the preparation/action stage of “readiness” to make lifestyle changes are more successful in making changes than those who are contemplative | Children from the Taranaki region ages 5–16, with a BMI ≥98th percentile, or those >91st percentile with weight related comorbidities (n=107) | Individualized, culturally appropriate program: home visits + group PA sessions or psychology sessions | Standard practice: Brief dietary education (pamphlet) | BMI SDS; HRQoL; PA; Diet knowledge and behavior; sedentary behavior; cardiovascular and metabolic profile | Protocol Published, Follow-up continuing
Ayala, 2015^330^ Our Choice/Nuestra Opcion: the Imperial County, California, Childhood Obesity Research Demonstration study (CA-CORD) United States | 1 of 3 CORD studies funded by the CDC in 2011 to test multisector, multilevel approaches to prevent and control childhood obesity; multisector, multilevel intervention targets improvements in 4 health behaviors: fruit, vegetable, and water consumption; physical activity; and quality sleep | Families with 1 child per household ages 2 to 10, with BMI ≥75th percentile (n=1184) | Family Wellness workshops + family PA sessions (targeting health behaviors: F/V intake, water consumption, PA, and sleep) | No intervention | zBMI; WC (child & parent); Parent BMI | In progress: estimated completion date: Sep 2016
Bean, 2014^331^ Nourishing Our Understanding of Role modeling to Improve Support and Health +Motivational Interviewing (NOURISH +MI) United States | Investigate if a brief, motivational interviewing intervention improves retention and treatment adherence for parents enrolled in program for their overweight child | Parents aged ≥18 years with a child aged 5–11 years with BMI >85^th^ percentile (n=NR) | Telephone and in person MI session prior to starting an 8 week parent-exclusive treatment focused on parenting skills to improve child’s overweight | Received no MI sessions prior to starting 8 week parent-exclusive treatment focused on parenting skills to improve child’s overweight | BMI | Currently recruiting participants
Boutelle, 2015^332^ Intervention for Regulation of Cues (iROC) United States | Text extinction processes as a method of decreasing physiological and psychological responses to food cures in overweight children and those with obesity | Overweight children and those with obesity with BMI ≥ 85^th^ percentile | Single or multiple context with consistent of enhanced partial reinforcement schedule (2×2 trials) | NA | Medical history, psychopathology (e.g., anxiety), physical activity, acceptability | Only protocol published
Christie, 2011^333^ Healthy Eating and Lifestyle Programme (HELP) United Kingdom | Assess the efficacy of HELP in improving management of adolescent obesity | Adolescents aged 13–17 years with BMI >98^th^ percentile (n=162) | MI and solution-focused approach, 12 sessions with families over 6 months | Enhanced standard care – only 1 session delivered | BMI, HR-QOL, cardiometabolic risk factors, | Completed, only protocol published
Cohen, 2013^334^ McGill Youth Lifestyle Intervention for Food and Exercise (MYLIFE) Canada | Determine effects of family-centered lifestyle intervention focused on nutrient dense food intake plus total and weight-bearing physical activity on body composition in overweight children or those with obesity | Children aged 6–12 years who are overweight or have obesity, BMI >97^th^ percentile (n=NR) | 6 planning sessions based on TTM and TPB to increase intake of vegetables, fruits, and milk along with increased activity and less screen time | Usual care - no intervention delivered | BMI Z-score, anthropometric measures | Completed, only protocol published
Dalton, 2013^335^ Parent-Led Activity and Nutrition (PLAN) United States | Develop and evaluate a parent-mediated approach utilizing physician’s brief MI and parent group sessions to treat child overweight and obesity | Children aged 5–11 years, BMI ≥85^th^ percentile (n=67) | 10 week intervention with parents of children who were overweight or obese consisting of 2 individual MI sessions and 4 group sessions focused on providing the tools needed to make healthy changes in eating and physical activity using NIH We Can! Curriculum + copy of the NIH We Can! “Families Finding the Balance: A Parent Handbook” | Routine care + copy of the NIH We Can! “Families Finding the Balance: A Parent Handbook” | HR-QOL, BMI | Completed, only protocol and parental outcomes published
Danielsen, 2015^336^ Family-based behavioral treatment of obesity – the FABO study Norway | Evaluate the effect of family-based behavioral weight loss treatment (FBBT) compared with the effect of today’s standard treatment given to children and adolescents suffering from obesity | Children and adolescents (8–16 years) with BMI ≥35, or BMI ≥30 with obesity related comorbidity (n=120) | Behavioral treatment sessions | Not specified | BMI, WC & body compositions; physiologic measures | Poster abstract presented 2015. No published results
Ek, 2015^337^ The More & Less Study: A Trial Testing Different Treatment Approaches to Obesity in Preschoolers (M&;L) Sweden | Evaluate the effectiveness of early treatment of childhood obesity with respect to treatment focus (parenting practices or lifestyle), length and intensity. Examine the influence of gender, age, parental weight status, parenting practices, child behavior as well as parents’ socioeconomic status and child and parental psychosocial health on children’s weight status. | Families with children aged 4–6 years with obesity as defined by the age and gender specific international cut-offs for BMI (n=180) | 1) Parent group sessions (parenting practices + lifestyle coaching) or 2) Parent group sessions + booster sessions (phone calls) | Standard care | BMI; Parenting practices; child PA, diet, metabolic health; Parent and family functioning | In Progress: Recruitment 2012–2016; estimated completion date Mar 2017
Eneli, 2015^338^ Feeding Dynamic Intervention (FDI) study for self-regulation of energy intake in preschoolers United States | Investigate the efficacy of the FDI for decreasing Eating in the Absence of Hunger (EAH) and improving energy compensation (COMPX). | Parent-reported child BMI ≥85th percentile (to be confirmed at the baseline visit) and child age 3–5. (n=84) | Group education: Lifestyle counseling + Feeding behaviors | No intervention (Wait-list) | Energy regulation; BMI | Completion date Jul 2015. No published results
Farpour-Lambert, 2012^339^ Switzerland | Determine the effects of family-based behavioral therapy in a group or individual setting in children with obesity | Pre-pubertal children with obesity (n=75) | Family-based therapy group 1 session/week or 1 individual session/month for 6 months | No intervention | BMI z-score, blood pressure, glucose, cardio-respiratory fitness | Published meeting abstract only
Foster, 2015^340^ A randomized clinical trial of the effects of parent mentors on early childhood obesity United States | Evaluate the effects of parent mentors trained to use a positive-deviance approach on early childhood obesity in a high-risk population of low-income Latino children in south Texas enrolled in Head Start | Children ages 2–5 at the time of enrollment who were obese (BMI ≥95th percentile for age and gender) (59) | Peer mentoring (parent) + community education meetings | Invitation to monthly community education meetings (separate from tx group) | zBMI; HRQoL; Screen time; sleep; play; feeding behaviors | Protocol published Nov 2015. No published results
Hage, 2013^341^ France | Determine the effects of a 6-month physical training program on body composition in children with obesity | Children aged 7–11 years with obesity (n=37) | 6 month physical training program where children engaged in exercise for 90 minutes twice a week | Did not participate in any kind of exercise | Weight, height, body composition | Published meeting abstract only
Hare, 2012^342^ The Positive Lifestyles for Active Youngsters trial (Team PLAY) United States | Assess the efficacy of a 6-month, moderate intensity, primary care feasible, family-based behavioral intervention, targeting both young children and parents, in promoting healthy weight change | Children aged 4–7 who are overweight and have obesity with BMI ≥85^th^ percentile (n=270) | 14 1-hour group sessions focused on dietary, physical activity, and behavioral components. Parents attended co-occurring sessions based on SCT using the NIH We Can! curriculum | Routine care – no intervention | BMI z-score, cardiovascular function, anthropometric measures, body esteem | Completed, only protocol published
Hingle, 2015^343^ The EPIC Kids Study: a randomized family focused YMCA-based intervention to prevent type 2 diabetes in at-risk youth United States | Develop and test a group-randomized family-centered community-based type 2 diabetes prevention intervention targeting at-risk children, 9- to 12-years-old. | 9 to 12-years-olds that have a BMI ≥85th percentile for age and sex, AND have ≥1 T2D risk factors (n=60) | Group education sessions (adapted YMCA Diabetes Prevention Program) + mobile technology | Group education sessions (adapted YMCA Diabetes Prevention Program)) | BMI; WC; PA; Diet; Cardiometabolic measures | Protocol published. Estimated completion date: Hun 2016
Janicke, 2013^344^ The Community-based Healthy-lifestyle Intervention for Rural Preschools (CHIRP) United States | Assess the effectiveness of a behavioral family weight management intervention among overweight children in underserved rural locations | Overweight children aged 3–6 years, BMI ≥85^th^ percentile | 12 family-based behavioral sessions addressing healthy habits and improved weight status | Waitlist control – no intervention | BMI z-score | Completed, only protocol published
Matthan, 2015^345^ Effect of a Family Based Intervention on Biomarkers of Diet Quality/Endogenous Metabolism and BMI z-score United States | Assess how participation in a family-based weight management intervention affected biomarkers of diet quality/endogenous metabolism and cardiometabolic outcomes in children | Children aged 7–12 years with baseline BMI z-score (BMIz) >85^th^ percentile (n=309) | Weekly lifestyle counseling sessions and follow up | Quarterly lifestyle counseling sessions + Educational material given | zBMI, dietary metabolism biomarkers | Poster Abstract published Mar 2015. No additional published results
McGavock, 2014^346^ Physical Activity for Overweight Youth at Risk for Type 2 Diabetes Mellitus (POWER) Canada | Assess effectiveness of high intensity exercise training in reducing risk factors for type 2 diabetes compared to moderate intensity exercise training in overweight adolescents | Sedentary adolescents aged 13–19 years who are overweight and have obesity (n=120) | High- or moderate-intensity exercise training at local YMCA 3 days a week for 6 months | No intervention | BMI z-score | Completed, published meeting abstracts only
Moore, 2013^347^ Ideas Moving Parents and Adolescents to Change Together (IMPACT) United States | Compare the effects of three distinct behavioral obesity management interventions on BMI in middle school, urban youth who are overweight or have obesity | Children with BMI ≥85^th^ percentile entering 6^th^ grade (target: n=360) | 2 distinct behavioral interventions; SystemCHANGE focused on system redesign of family environment and routine, and HealthyCHANGE focused on cognitive behavioral motivational interviewing techniques | Attention Control – Tools4change focused on diet and physical activity counseling | BMI | Protocol published, study recruiting participants
Onnerfalt, 2012^348^ Lund Overweight and Obesity Preschool study (LOOP) Sweden | Evaluate effects of family-based intervention program for parents of pre-school children who are overweight or have obesity | Children aged 4–6 years who are overweight and have obesity (target: n=260) | Behavioral interventions using internet-based information and communication tool “Sundabarn.se” in conjunction with either parent-targeted, psychologist-led seminars focused on tools to change family patterns or lifestyle, OR parent-targeted group treatment led by occupational therapist focused on daily life patterns alterations | No Intervention | BMI z-score | Protocol published, study recruiting participants
Polacsek, 2009^349^ Keep ME Healthy – The Maine Youth Overweight Collaborative (MYOC) United States | Evaluate the effect of a pediatric primary-care based intervention on improved clinical decision support and family management of risk behaviors for childhood overweight | Youth aged 5–18 years | Family and patient counseling using motivational interviewing techniques to promote 5-2-1-0 behavioral goals | No intervention | BMI | Completed, only protocol and preliminary findings published
Raben, 2015^350^ PREVIEW: Prevention of diabetes through lifestyle intervention and population studies in Europe and around the world International | To identify the most efficient lifestyle pattern for the prevention of type-2 diabetes in a population of pre-diabetic overweight and obese individuals. Six year project involving 15 partners from Europe, Australia, Canada, and New Zealand | RCT with up to 2,500 participants as well as large population studies in about 170,000 individuals across all age groups | (1) impact of a high-protein, low-glycemic index diet in combination with (2) moderate or high intensity physical activity | (1) high-carbohydrate, medium-glycemic index diet in combination with (2) moderate or high intensity physical activity | Not described (incidence of type-2 diabetes and related end-points) | Poster abstract presented 2015. No published results. Estimated completion date 2018
Robertson, 2013^351^ Families for Health V2 United Kingdom | Assess the effectiveness of the Families for Health program in reducing BMI z-score in children who are overweight or have obesity | Children aged 6–11 years who are overweight or have obesity, BMI ≥91^st^ percentile | Family-based group delivered program combining information on parenting skills, social and emotional development, as well as lifestyle change based on the Nurturing Programme from Family Links | No intervention – usual care | BMI z-score | Completed, only protocol published
Sherwood, 2013^352^ Healthy Homes/Healthy Kids (HHHK 5–10) United States | Evaluate the efficacy of low cost pediatric primary-care based obesity prevention intervention | Children aged 5–10 years with BMI between 70^th^ and 95^th^ percentiles | Brief pediatrician counseling based on SCT and motivational interviewing as well as phone counseling for parents of overweight children | Contact control group | BMI percentile change | Completed, only protocol published
Sousa, 2014^353^ Next.Step Portugal | Determine effectiveness of an e-therapeutic intervention program on behavior change and health impact | Adolescents aged 12–18 years with obesity, BMI ≥95^th^ percentile | POC standard treatment protocol including behavioral counseling combined with access to internet-based e-therapeutic platform with resources, self-monitoring, social support, interactive training modules, and motivational tools | POC standard treatment protocol – initial evaluation session with pediatrician and one session with a nutritionist and exercise physiologist | BMI | Protocol published
Stoner, 2013^354^ Combating Obesity in Maori and Pasifika Adolescent School-Children Study (COMPASS) New Zealand | Investigate efficacy of culturally-sensitive, non-contact, boxing-oriented training program on obesity in Maori and Pasifika adolescents | Male and female Maori and Pasifika adolescents aged 14–16 years with obesity (BMI >95^th^ percentile) | 6-month theory-based program conducted 3 times per week in culturally appropriate setting, each session included 40 min boxing-oriented training and 20 min resistance training | Control group – wait list | BMI | Protocol published
Taveras, 2015^355^ Connect for Health: clinical-community childhood obesity intervention testing best practices of positive outliers United States | Assess whether a novel approach to care delivery that leverages clinical and community resources and addresses socio-contextual factors will improve BMI and family-centered, obesity-related outcomes of interest to parents and children | 2–12 year old children with overweight or obesity (BMI ≥85th percentile) (n=721) | Tailored health coaching, community resources, & interactive text messaging program | Enhanced primary care (best-practice) + non-tailored health coaching | BMI, zBMI, QoL; Behavioral: PA, screentime, sleep, diet. Pediatric obesity care quality, effectiveness, and family-centeredness | Estimated completion date Nov 2016
van der Aa, 2014^295^ METFORMIN The Netherlands | Assess effectiveness of adding metformin treatment to lifestyle intervention in reducing BMI in adolescents with obesity | Children aged 10–16 years defined as having obesity (BMI-SDS ≥3.4) | Metformin + lifestyle intervention | Placebo + lifestyle intervention | BMI | Study recruiting, only protocol published
Willeboordse, 2013^356^ Multifactorial intervention for children with asthma and overweight (Mikado) The Netherlands | Evaluate the effectiveness of long-term multifactorial weight reduction intervention on asthma in children with asthma and high body weight | Children aged 6–16 years with asthma diagnosis and BMI indicating overweight/obese | Multifaceted intervention based on theoretical health counseling model including physical exercise, nutrition counseling, and behavioral intervention in the form of group and individual sessions, and parental sessions | No intervention – usual care | BMI | Completed, only protocol published

Abbreviations: BMI=body mass index; HR-QOL=health-related quality of life; MI=motivational interviewing; min=minute(s); NIH=National Institutes of Health; SCT=social cognitive theory; SDS=standardized deviation score; POC=point of care; TPB=theory of planned behavior; TTM=transtheoretical model; YMCA=Young Men’s Christian Association.