# Appendix E Acceptability of Behavior-Based Weight Management Interventions

Nineteen included studies (18 behavior-based interventions and one pharmacotherapy with counseling) reported on the acceptability of weight management interventions, which varied in intensity from a brief use of a computerized clinical decision support system using motivational interviewing for weight management^164^ to multiple group sessions addressing healthy lifestyle behaviors with the parents and child meeting separately.^133^ Participants—both parents and children—rated their satisfaction with the weight management interventions highly on various satisfaction questionnaires. In most trials, 80 percent or more of participants had high satisfaction or acceptability ratings, and continuous satisfaction scores typically were above 4 on a 5-point scale (Table 1).^118, 129, 130, 136, 147, 160, 163, 164^ In a good-quality trial that involved a computerized clinical decision support system with point of care prompts at well-child visits, motivational interviewing with their primary care provider, and four health coaching phone sessions with an optional text messaging component, ninety-one percent of parents would recommend the intervention to family and friends.^163^ In another fair-quality trial in younger children (age 6 to 9 years) involving an estimated 24 hours of contact via group and phone sessions, the majority of parents reported that they would undergo the intervention again.^130^ Many of the participants also found the behavior-based interventions to be helpful or useful in weight loss (Table 1).^118, 126, 129, 130, 138, 140, 147, 166^ The interventions were also rated high in quality and value; for example, all the parents of one fair-quality study rated the Positive Parenting Program (Triple P) as good to excellent.^130^ Primary care providers also found the interventions to be valuable^143, 166^ and helpful^169^ and intended to deliver the intervention again.^143^ The participants of four included studies reported that the intervention met their particular weight loss needs.^126, 130, 147, 166^

Appendix E Table 1 Acceptability of Behavior-Based Interventions in Included Studies, Participant Report

Author, Year & Quality | Details of Acceptability Ascertainment | Satisfaction | Usefulness/Helpfulness | Quality/Value | Component Preferences | Brief Intervention Description
Behavior-based interventions
Croker, 2012^124^ Fair | NR | | | | Based on feedback from pilot participants, study investigators changed calorie goals to goals on food types and portion size, and removed goals for daily weighing | 15 90-min comprehensive multicomponent family-based behavioral therapy group sessions, parents and children meeting separately for 10 sessions and together for 5 sessions
DeBar, 2012^126^ Good | Ratings of quality of intervention and whether treatment met their needs (rated on scale of 1–5, higher is better) | | Program met their needs (4.0 ± 1.0 for teens and 3.9 ± 1.1 for parents) | Quality of intervention (4.4 ± 0.8 for teens and 4.4 ± 0.8 for parents) | | 16 90-min developmentally-tailored multicomponent behavioral intervention group sessions for adolescent girls; 12 with concurrent parent sessions; trained PCP to support behavioral weight management goals; 2 PCP meetings
Gerards, 2015^129^ Fair | CSQ, 13 items rated on a scale of 1–7 (overall rated on scale 13–91, higher is better) What is your general impression of the program? (rated on scale of 1–5, directionality NR) Do you think program was interesting? (rated on scale of 1–5, directionality NR) Do you think the program was clear? (rated on scale of 1–5, directionality NR) Overall rating for intervention value (rated on scale of 1–10, directionality NR) | Parent-report CSQ mean score, 66.67 (10.57) General impression, 4.04 (0.66) Interesting, 4.12 (0.77) Clear, 4.15 (0.73) | | Value of intervention, 7.7 (1.03) 85% of parents rated intervention as 7 or higher | The recipes provided were found to be quite difficult for parents and not always appropriate to the Dutch eating habits. Furthermore, parents indicated that they would have liked a booster session (for example after 6 months) to refresh their knowledge and skills. | 10 90-minute group sessions and four individual 15–30 minute phone sessions aimed at changing parenting practices and styles with specific strategies around lifestyle change; workbook, recipes and active games booklet
Golley, 2007^130^ Fair | Parent satisfaction assessed using a validated 16-item questionnaire Response rate to satisfaction questionnaire: IG1 26/38 (68%) IG2 10/37 (27%) Additional questions about perceived barriers to program attendance and implementation were included | 85% IG1 and 100% IG2 satisfied to very satisfied with amount of help received 77% IG1 and 60% IG2 would repeat program | 50% IG1 and 80% IG2 reported generally to definitely receiving the type of help they wanted 92% IG1 and 100% IG2 found study helped somewhat to help a greater deal to make family lifestyle changes Reported as being useful training resources: parenting sessions 58%, calls 53%, manual 44%, lifestyle sessions 14%, lifestyle written material 17% | 100% rated quality of service as good to excellent | | IG1: Four 2-hr group sessions + 7 individual phone calls aimed at changing parenting practices and general parenting styles, and 7- session behavioral healthy lifestyle group for parents and concurrent child PA sessions IG2: Four 2-hr group sessions and 7 individual phone followup sessions aimed at changing parenting practices and general parenting styles (no behavioral lifestyle component); workbook, and healthy lifestyle pamphlet
Kalavainen, 2007^133^ Fair | Parents asked to evaluate each group session immediately after the session; to be returned during fall and spring term (rated on a scale of 0–10, higher is better) 21 (64%) of parents returned fall term questionnaires; 26 (79%) of parents returned spring term questionnaires. Ratings broken down by session in Tables 3 and 4 | | | Fall term session ratings, ranged from 8.1 (1.0) to 9.6 (0.4); mean, 8.9 (0.7) Spring term session ratings, ranged from 8.7 (0.9) to 9.0 (1.1); mean, 8.8 (0.8) | | 15 90-min group sessions, parents and children mostly separate; parents targeted as main agents of change; interactive activities and PA for children; manuals for parents, workbooks for children and homework assigned
Kong, 2013^136^ Fair | Participant satisfaction (rated on scale of 0–5, higher is better) Survey completed by: 93% of IG students, 88% of caregivers, and 100% of CG students | IG student average satisfaction score, 4.4 IG caregiver average satisfaction score, 4.4 CG students average satisfaction score, 4.2 | | | | Initial MI visit with PCP and student to review medical history/lab results, assess diet and PA, receive DVD; 7 followup MI visits with PCP to discuss DVD and work toward healthy lifestyle goals; newsletter and 8 post-visit MI calls to parents/caregivers
Looney, 2014^138^ Fair | At 6 months, families evaluated usefulness; number of additional contacts and additional overall comments; ease of achieving program-related goals and ability to implement behavioral changes | | 95% of families reported the program provided caretaker with important information about their child’s health | 90% of families reported the information provided was easy to understand 90% of families rates the overall program as very good or excellent | Reported monitoring monthly very easy or extremely easy: height (69.3%), weight (92.3%), using BMI wheel (96.3%), plotting on growth chart (53.9%) In IG1, easiest behavior change was decreasing SSBs (83.4%) Most commonly used strategies were caretakers modeling drinking fewer SSBs (100%), keeping F/V in home (100%), removing SSBs from home (73.3%) and praising child (73.3%) | IG1: Six 20–30 min in-person or phone sessions for growth monitoring/feedback and caretaker behavioral counseling; 6 monthly educational newsletters on nutrition and activity; usual care from the pediatrician IG2: Six 10–15 minute in-person or phone growth monitoring sessions with standardized feedback; 6 monthly educational newsletters on nutrition and leisure-lime activity; usual care from the pediatrician
O’Connor, 2013^147^ Fair | NR | Exit interviews (85% of IG parents interviewed) revealed they were positive about the Helping HAND program and received what they wanted from the Helping HAND program | | | Parents liked involving both themselves and their child and the broad selection of lifestyle behaviors to choose from. Approximately half wanted to target more than 1 behavior a month, attend more frequent program visits or receive more frequent phone calls A few would have preferred home visits or alternative site for the program session usually because of convenience or transportation issues. | Six monthly individual family sessions with health advisors with followup phone call after each session; set monthly child-behavior goals with implementation plan and behavior-specific parenting practice goals
Saelens, 2002^154^ Fair | Rated satisfaction with intervention components (computer program, physician counseling, manual and other written materials) at posttreatment for helpfulness, perceived satisfaction, perceived impact on weight-related behaviors, and overall appeal (rated on scale of 1–5, higher is better) | Telephone counseling satisfaction, 4.05 Mailing satisfaction, 3.57 Physician counseling satisfaction, 3.39 Computer program, 2.98 | | | Adolescents more satisfied with telephone counseling (4.05) than all other intervention components (p<0.01 for all other components) More satisfied with mailed materials/manual than computer interaction (p<0.01) | Computer assessment with 1 pediatrician session to discuss results with family; 11 phone counseling calls, 3 mailings
Sherwood, 2015^157^ Fair | Parent satisfaction survey assessed on the 6-month survey | | Phone coaching helped family improve or maintain health behaviors, 72% of intervention parents | | | One brief primary care session followed by 8 15–30 min phone coaching sessions for goal setting and MI
Stark, 2011^160^ Fair | Treatment Satisfaction Questionnaire, measures parents satisfaction with treatment content and ability to make recommended changes at treatment completion (rated on scale 1–5, higher is better) | Nutritional information, 4.86 Physical activity, 4.71 Ability to make recommended changes, 4.26 | | | Anecdotally, parents reported the home component to be essential to following recommendations | Nine clinic-based 90-min comprehensive behavioral lifestyle group sessions for parents and children separately plus 9 home visits; vegetable taste tests, pedometers, parents received 2 weeks worth of vegetables, child sessions included 15-min PA.
Taveras, 2011^163^ Good | Asked parents of IG during the 12 month interview how satisfied they were with program and if they would recommend it to family and friends and whether to had chosen to work on specific behaviors | 97% reported being somewhat or very satisfied with the intervention 91% would recommend it to family and friends | | | | 4 25-min in-person + 3 15-min phone motivational interviewing sessions with nurse practitioner. Pediatricians endorsed messages during well-child visits. Tailored materials, behavior monitoring tools, enhanced electronic medical record.
Taveras, 2015^164^ Good | Parents rated how satisfied they were with program and whether they would recommend the program to family and friends | Parent very satisfied with experience in STAR intervention, % IG1: 81.3 IG2: 46.9 Increased satisfaction with health care system, % IG1: 62.7 IG2: 47.9 Would recommend STAR to friends and family, % IG1: 94.0 IG2: 85.1 Telephone calls w/health coach: Very satisfied with counseling received, %: 87.1 Very good/excellent quality of advice provided, %: 73.7 Text message or email from health coach Very satisfied with the content received, %: 68.8 Very good/ excellent quality of advice received, %: 55.1 | | | Ratings consistently lower for program without health coach contact; text message component lower satisfaction than phone calls | IG1: Computerized clinical decision support system with point of care prompts at well-child visit, motivational interview, pt materials + 4 phone motivational interviewing sessions by health coach and optional text msg program IG2: Computerized clinical decision support system with point of care prompts at well-child visit, motivational interview, pt materials
Van Grieken, 2013^166^ Fair | Parents asked to indicate whether the information provided during the sessions was appreciated; also gave an overall grade (rated on a scale of 1–10, directionality NR) | | 87% (78/90) of parents reported receiving overall useful information 79% (71/90) of parents reported receiving advice suited to them | 90% (81/90) of parents rated the additional sessions w/ a grade of 7 or higher | | Prevention protocol involving MI during a well-child visit; three additional structured healthy lifestyle counseling sessions matched to parents’ stage of change could be offered.
Wake, 2013^169^ Good | Various measures of acceptability (rated as agree, neutral or disagree) | 85% of parents felt understood by specialist; 89% by GP | 81% of parents understood how to implement goals set by specialist; 79% by GP 72% of parents confident of weight change after meeting specialist; 77% after meeting GP | | | One hour-long family visit with obesity specialist team to develop plan and goals followed by GP visits every 4–8 weeks using brief solution-focused techniques; web-based software (HopSCOTCH) used to track progress and link specialist with GP
Non-lifestyle counseling
Boutelle, 2014^118^ Fair | How much did you like the ROC program? (rated on scale of 1–5, higher is better) Because of ROC, I feel more control of my eating? (rated on scale of 1–3, higher is better)? Do you think other kids your age would like the ROC program? (Yes/No) | 50% of kids rated it a 4 or 5 (liked a lot, loved it) 67% of parents rated it a 4 or 5 (liked a lot, loved it) 47% of parents thought their child rated it a 4 or 5 (liked a lot, loved it) 85% of kids thought other kids would like ROC program | 62% of kids rated it a 3 on helpfulness 81% of parents believed it taught child to be more in control of eating | | | 14 group sessions behavioral counseling based on appetite awareness and cue exposure treatment; core components included psychoeducation, parenting skills, coping skills, self-monitoring of hunger and cravings, and experiential learning
Pharmacotherapy
Love-Osborne, 2008^140^ Fair | NR | | | | “In this study, subjects almost universally felt that goal setting was helpful to them, regardless of outcome” | Metformin 850 mg bid + 6 monthly individual goal-setting sessions; initial session included written material and video

Abbreviations: bid=twice daily; BMI=body mass index; CG=control group; CSQ=Client Satisfaction Questionnaire; DVD=digital video disc; F/V=fruits and vegetables; GP=general practitioner; hr=hour; IG=intervention group; MI=motivational interviewing; min=minute; msg=message; NR=not reported; PA=physical activity; PCP=primary care physician; pt=participant; ROC=regulation of cues; SSB=sugar-sweetened beverages; STAR=Study of Technology to Accelerate Research; w/=with.

A few themes emerged when asking families for feedback on their experiences, both in the included trials and other studies, including a qualitative study of 14 parents who had dropped out of a weight management program.^318^ Themes included a desire for more frequent and direct contacts or visits with the interventionist, appreciation for a component or option directed in the home, and increased parental involvement and family education, rather than only targeting the child. In one good-quality trial evaluating monthly individual family sessions with health advisors, the parents liked involving both themselves and their child during the sessions as well as the broad selection of lifestyle behaviors for modification from which to choose.^147^ About half wanted to target more than one behavior change a month, attend more frequent visits, and receive more frequent followup telephone calls between sessions. A few parents would have also preferred home visits or for the intervention to take place at an alternative site for convenience or due to transportation issues. The parents of one-fair quality trial found the home component of the intervention essential to following the treatment recommendations (e.g., clean out pantry of junk food).^159^ In another fair-quality study of an intervention aimed at parenting skills with an estimated 38 hours of contact, the parents indicated that they would have liked a booster session to refresh their knowledge and skills since the intervention only lasted 14 weeks and followup assessment occurred at 12 months.^129^ Other studies have reported that parents of children in weight management programs strongly support interventions that include behavioral modification through collaborative goals and family support,^319, 320^ which the majority of interventions in included studies provided. At least one included fair-quality study reported modifying the SHAPEDOWN intervention to include more extensive parental involvement and supportive family education materials based on feedback from group leaders.^143^ Similarly, the survey of families dropping out of a weight management program indicated a preference for greater family involvement rather than the child being the primary target.^318^

When designing weight management interventions, consideration of the preferences of the participating children and adolescents, such as focusing on healthy eating and physical activity and not restricting activities that they enjoy (e.g., playing computer games), is also important. A survey of middle school students reported that the most important components were those that focused on adopting healthy eating and physical activity behaviors as opposed to drinking less soda pop, playing less video/computer games, and watching less television.^321^ The survey among middle school students also reported that they preferred to increase physical activity, rather than reduce calories, for improved energy balance.^321^ In contrast, the caretakers of children in one included fair-quality trial suggested reducing sugar-sweetened beverages was the easiest behavior to target in children compared to increasing intake of fruits and vegetables, increasing moderate-to-vigorous physical activity, or decreasing television time.^138^

Weight management interventions should also be developed to be relevant, applicable, and feasible to a primary care setting by considering the perspective of the primary care provider. Four included trials that involved primary care providers assessed the acceptability of the interventions from their perspective (Table 2). One good-quality trial evaluated the effect of four consultations with a general practitioner on weight management.^142^ At each consultation, the family could choose an appropriate healthy lifestyle behavior change from a set of evidence-based materials (e.g., drink more water), and the general practitioner provided solution-based support to families during the consultations. Eighty-five percent of the general practitioners found the intervention materials had good or very good relevance to primary care. In another good-quality trial, intervention participants visited their general practitioners every 4 to 8 weeks after an initial hour-long family session with an obesity specialist team.^169^ The general practitioner reviewed BMI and lifestyle change progress, identified and solved problems, and set new goals using a brief solution-focused technique. Data from all sessions was shared between the obesity specialist team and the general practitioner using the HopSCOTCH web-based shared care software, which provided a structured intervention for each session. The majority of general practitioners thought that the overall shared care approach was helpful (77%), the specialists management plan was helpful (88%), and being able to contact the specialist team was helpful (67%). Half of general practitioners, however, did not find the HopSCOTCH software easy to use. In a fair-quality trial that evaluated the use of an overweight prevention protocol during a well-child visit, 65 percent of the professionals (72% of which were pediatricians) at the Youth Health Center graded the intervention as a seven or higher on a 10-point scale (directionality not reported).^166^ The professionals indicated that motivating the parents to attend additional sessions and changing the family health-related lifestyle were the most often experienced difficulties while using the overweight prevention protocol (specific details not reported). And finally, the majority of pediatric primary care physicians who provided a brief session to participants in one fair-quality trial reported the training (88%) and materials (68 to 71%) were helpful and useful.^157^ Although children in these interventions were not more likely to reduce excess weight than the usual care groups, the generally positive attitude of the participating providers suggests that these interventions may be useful and feasible components of a more intensive intervention.

Appendix E Table 2 Acceptability of Behavior-Based Weight Management Interventions in Included Studies, Provider Report

Author, Year & Quality | Details of Acceptability Ascertainment | Satisfaction | Usefulness/Helpfulness | Quality/Value | Component Preferences | Brief Intervention Description
Behavior-based interventions
McCallum, 2007^142^ Good | 34 GPs asked to provide feedback on the conduct of the study Materials edited and refined according to expert opinion and GP feedback then piloted successfully with family attending a weight management clinic (unclear if occurred during trial or previously) | | | 85% reported good or very good relevance to general practice | | Four GP consultations using brief solution-focused family therapy for healthy lifestyle goals; 16-page folder of materials included topic sheets, wall cart, reward stickers, and shopping tips
Mellin, 1987^143^ Fair | Group leaders perceptions of program content, process and outcomes were elicited at the conclusion of the intervention…through post-intervention interviews and questionnaires | All group leaders indicated they intended to deliver the program again | | Group leaders rated the process, content and outcomes of program highly with all evaluating those aspects as good or excellent | Group leaders made numerous recommendation for minor content and process changes, many of which were subsequently incorporated into program materials Program revised to include more extensive parental involvement and supportive family education (unclear if this is what the group leaders suggested) | 14 90-minute weekly group adolescent sessions and 2 90-minute parent sessions plus separate workbooks for parent and adolescent; focus on successive, sustainable, small lifestyle modifications
Sherwood, 2015^157^ Fair | Provider feedback obtained by survey after they completed 3 well-child visits; it assessed comfort level addressing BMI percentile and obesity and safety/injury prevention with parents as well as study training and resource usefulness | 96% comfortable addressing health eating and physical activity | 88% reported study training was helpful | | 71% reported pamphlet was useful for communicating with families 68% reported flipchart was useful for communicating with families | One brief primary care session followed by 8 15–30 min phone coaching sessions for goal setting and MI
Van Grieken, 2013^166^ Fair | YHC professionals (72% were pediatricians) could indicate the challenges of the prevention protocol and give an overall grade (rated on a scale of 1–10, directionality NR) 54 YHC professionals completed evaluation form | | | 65% (15/23) reported a grade of 7 or higher | Difficulties included motivating parents to attend additional sessions and changing the family health-related lifestyle. | Prevention protocol involving MI during a well-child visit; three additional structured healthy lifestyle counseling sessions matched to parents’ stage of change could be offered.
Wake, 2013^169^ Good | Various measures of acceptability (rated as agree, neutral or disagree) | | 77% of GPs thought overall shared care approach was helpful 88% of GPs thought specialist’s management plan was helpful 67% of GPs thought being able to contact specialist helpful | | 40% of GPs thought opening sidebar was easy 24% of GPs thought speed of sidebar was easy 21% of GPs thought general usability of sidebar was easy | One hour-long family visit with obesity specialist team to develop plan and goals followed by GP visits every 4–8 weeks using brief solution-focused techniques; web-based software (HopSCOTCH) used to track progress and link specialist with GP

Abbreviations: GP=general practitioner; MI=motivational interviewing; YHC=youth health center.

Study investigators also need to consider reasons participants choose to discontinue a weight management intervention. High attrition rates and poor adherence are important limitations of weight management studies. Although the followup rates of included studies in this review were adequate (ranging from 63.4 percent^117^ to 100 percent^150^), some interventions were modified to improve adherence and compliance. One trial, for example, changed calorie goals to goals on food types and portion size, and removed goals for daily weighing due to considerable resistance from families and health professionals during the pilot study (specific details not reported).^124^ It is possible that adhering to such frequent self-monitoring is difficult whereas monthly monitoring of weight and height was rated as very or extremely easy to do in another fair-quality study.^138^ A survey of 14 parents who did not return to the Canadian Nutrition Services Pediatric Weight Management Program reported physical barriers (e.g., logistics), organizational barriers (e.g., clinic environment), motivation (i.e., the family’s readiness to change), and components of the interventions as common reasons for attrition.^318^ The qualitative responses indicated that information-only interventions were vulnerable to dropouts because many participants were already knowledgeable about the information (e.g., what is a food pyramid).^318^ The survey also indicated that parents wanted the intervention to be targeted more toward the family and not the child only.^318^ Tailoring the counseling technique in weight management interventions based on sex or race/ethnicity and other sociodemographic characteristics (e.g., immigration status) may also improve attendance and satisfaction.^217^ The survey also reported that parents would prefer having the interventionist gain an understanding of what the family knows and how to address diet and lifestyle areas with which the family struggles (and thus, tailoring the intervention).^318^ Overall, addressing preferences and barriers may improve adherence and compliance in weight management interventions.

Although we identified no studies on screening for childhood overweight or obesity, we did find studies reporting that parents believe primary care physicians play an integral role in identifying and treating childhood weight issues^322, 323^ and find screening to be acceptable^324^ in a health care setting. Primary care physicians who provide parents with weight-related feedback improve the parent’s recognition and awareness of child overweight and increase the likelihood of participating in weight loss and healthy lifestyle programs.^325–327^