# Appendix D Evidence Tables

Appendix D Table 1 Health Outcomes in Included Behavior-Based Weight Loss Intervention Trials (KQ 3)

Author, Year & Quality | Est hrs of contact | Followup (months since tx ended) | Outcome (unit) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Vos, 2011^167^ Fair | 45 | 12 (**) | DISAKIDS, child, total score | 6.6 (11.0) | 32 | 2.8 (13.6) | 35 | NR
Kalarchian, 2009^132^ Fair | 44 | 6 (**) | Child Health Questionnaire (CHQ), general health perception | 6.88 (15.16) | 97 | 0.46 (16.67) | 95 | 0.006
Kalarchian, 2009^132^ Fair | 44 | 12 (0) | Child Health Questionnaire (CHQ), general health perception | 5.71 (17.82) | 97 | 1.83 (19.10) | 95 | 0.15
Kalarchian, 2009^132^ Fair | 44 | 6 (**) | Child Health Questionnaire (CHQ), global health | 6.55 (20.68) | 97 | −0.28 (23.29) | 95 | 0.32
Kalarchian, 2009^132^ Fair | 44 | 12 (0) | Child Health Questionnaire (CHQ), global health | 4.13 (24.52) | 97 | 0.48 (27.68) | 95 | 0.33
Stark, 2011^160^ Fair | 38 | 6 (0) | PedsQL, parent/caregiver, physical functioning | 9.5 (13) | 7 | −1.7 (6.5) | 10 | 0.042
Stark, 2011^160^ Fair | 38 | 12 (6) | PedsQL, parent/caregiver, physical functioning | 13.8 (8.6) | 7 | −2.7 (5.6) | 9 | 0.001
DeBar, 2012^126^ Good | 37 | 6 (1) | PedsQL, parent/caregiver, total score | 6.51 (15.06) | 104 | 5.09 (15.68) | 102 | 0.189
DeBar, 2012^126^ Good | 37 | 12 (7) | PedsQL, parent/caregiver, total score | 6.68 (15.15) | 85 | 2.86 (16.47) | 76 | 0.189
DeBar, 2012^126^ Good | 37 | 6 (1) | Body Satisfaction Scale, total score | 0.33 (0.70) | 104 | 0.21 (7.08) | 102 | 0.026
DeBar, 2012^126^ Good | 37 | 12 (7) | Body Satisfaction Scale, total score | 0.43 (0.65) | 85 | 0.2 (0.71) | 76 | 0.026
DeBar, 2012^126^ Good | 37 | 6 (1) | Rosenburg Self-Esteem Scale, total score | 0.01 (0.25) | 104 | −0.02 (0.26) | 102 | 0.275
DeBar, 2012^126^ Good | 37 | 12 (7) | Rosenburg Self-Esteem Scale, total score | 0.06 (0.26) | 85 | −0.01 (0.26) | 76 | 0.275
DeBar, 2012^126^ Good | 37 | 6 (1) | Patient Health Questionnaire-Adolescents (PHQ-A), % mood disorder | 5 (4.49) | 104 | 6 (6.02) | 102 | 0.362
DeBar, 2012^126^ Good | 37 | 12 (7) | Patient Health Questionnaire-Adolescents (PHQ-A), % mood disorder | 6 (7.32) | 85 | 4 )5.26) | 76 | 0.362
Sacher, 2010^153^ Fair | 36 | 6 (3.75) | Harter Scale, total score | 0.4 (0.6) | 37 | 0.1 (0.7) | 44 | 0.04 | Baseline
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | PedsQL, parent/caregiver, physical functioning | 6.60 (13.55) | 44 | 2.20 (12.6) | 33 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | PedsQL, parent/caregiver, psychosocial functioning | 2.20 (12.31) | 44 | 2.40 (10.73) | 33 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | PedsQL, parent/caregiver, total score | 3.40 (11.73) | 44 | 2.20 (10.37) | 33 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | Body Esteem Scale, weight satisfaction | 0.1 (0.7) | 44 | 0.1 (0.7) | 33 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | Child Health Questionnaire (CHQ), physical summary | 2 (11.68) | 44 | 4.20 (10.55) | 33 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | Child Health Questionnaire (CHQ), psychosocial summary | 1.70 (10.52) | 44 | 2.40 (9.27) | 33 | NSD | Age, sex, ethnicity
Boudreau, 2013^117^ Fair | 11 | 6 (0) | PedsQL, parent/caregiver, total score | 8.30 (NR) | NR | 7.10 (NR) | NR | 0.16 | Maternal BMI and caregiver education
Boudreau, 2013^117^ Fair | 11 | 6 (0) | PedsQL, child, total score | 5.80 (NR) | NR | 0.60 (NR) | NR | 0.33 | Primary household language and child’s sex
Taylor, 2015^165^ Good | 7 | 24 (−12) | PedsQL, parent/caregiver, emotional functioning | 0.10 (14.62) | 89 | 0 (14.97) | 92 | NR, NS | Baseline value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention
Taylor, 2015^165^ Good | 7 | 24 (−12) | PedsQL, parent/caregiver, physical functioning | −1.1 (14.93) | 89 | −3.8 (15.94) | 92 | NR, NS | Baseline value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention
Taylor, 2015^165^ Good | 7 | 24 (−12) | PedsQL, parent/caregiver, psychosocial functioning | −0.4 (11.93) | 89 | −2.1 (12.90) | 92 | NR, NS | Baseline value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention
Taylor, 2015^165^ Good | 7 | 24 (−12) | PedsQL, parent/caregiver, social functioning | −1.90 (14.73) | 89 | −5.60 (16.71) | 92 | NR, NS | Baseline value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention
Taylor, 2015^165^ Good | 7 | 24 (−12) | PedsQL, parent/caregiver, school functioning | 0.70 (13.25) | 89 | −0.5 (15.32) | 92 | NR, NS | Baseline value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention
Wake, 2013^169^ Good | 3 | 12 (0) | Harter Scale, total score | NR (NR) | NR | NR (NR) | NR | >0.9 | Children’s sex and age at randomization, neighborhood socioeconomic disadvantage score, raw baseline BMI, and baseline value of outcome measures where available
Wake, 2013^169^ Good | 3 | 12 (0) | PedsQL, child, total score | NR (NR) | NR | NR (NR) | NR | 0.5 | Children’s sex and age at randomization, neighborhood socioeconomic disadvantage score, raw baseline BMI, and baseline value of outcome measures where available
Wake, 2013^169^ Good | 3 | 12 (0) | Body Satisfaction Scale, total score | NR (NR) | NR | NR (NR) | NR | 0.3 | Children’s sex and age at randomization, neighborhood socioeconomic disadvantage score, raw baseline BMI, and baseline value of outcome measures where available
McCallum, 2007^142^ Good | 1 | 9 (6) | PedsQL, parent/caregiver, total score | 3.90 (12.35) | 58 | 3.80 (12.56) | 67 | 0.23 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 15 (12) | PedsQL, parent/caregiver, total score | 2.90 (13.45) | 63 | 0 (12.85) | 69 | 0.91 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 9 (6) | Harter Scale, total score | NR (NR) | 73 | NR (NR) | 80 | 0.65 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 15 (12) | Harter Scale, total score | NR (NR) | 72 | NR (NR) | 74 | 0.64 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 9 (6) | PedsQL, child, total score | NR (NR) | 73 | NR (NR) | 80 | 0.7 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 15 (12) | PedsQL, child, total score | NR (NR) | 72 | NR (NR) | 74 | 0.19 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 9 (6) | Collins Body Figure Perception Scale, total score | NR (NR) | 73 | NR (NR) | 80 | 0.58 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 1 | 15 (12) | Collins Body Figure Perception Scale, total score | | 72 | | 74 | 0.3 | SES, age, sex, baseline BMI
Wake, 2009^168^ Good | 1 | 6 (3) | PedsQL, child, physical functioning | NR (NR) | NR | NR (NR) | NR | 0.7 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 12 (9) | PedsQL, child, physical functioning | NR (NR) | NR | NR (NR) | NR | 0.1 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 6 (3) | PedsQL, child, psychosocial functioning | NR (NR) | NR | NR (NR) | NR | 0.3 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 12 (9) | PedsQL, child, psychosocial functioning | NR (NR) | NR | NR (NR) | NR | 0.5 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 6 (3) | PedsQL, child, total score | NR (NR) | NR | NR (NR) | NR | 0.4 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 12 (9) | PedsQL, child, total score | NR (NR) | NR | NR (NR) | NR | 0.3 | Social disadvantage index, age at randomization, sex
Wake, 2009^168^ Good | 1 | 6 (3) | Collins Body Figure Perception Scale | NR (NR) | 130 | NR (NR) | 115 | 0.5 | Social disadvantage index, age, sex, raw BMI at BL
Wake, 2009^168^ Good | 1 | 12 (9) | Collins Body Figure Perception Scale | NR (NR) | 125 | NR (NR) | 112 | 0.6 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL
Wake, 2009^168^ Good | 1 | 6 (3) | Positive vs negative appearance/self-worth, number of participants | 91 (70.1) | 130 | 80 (69.6) | 115 | 0.5 | Social disadvantage index, age, sex, raw BMI at BL
Wake, 2009^168^ Good | 1 | 12 (9) | Positive vs negative appearance/self-worth, number of participants | 96 (76.4) | 125 | 83 (73.8) | 112 | 0.4 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; est=estimated; hrs=hours; IG=intervention group; NR=not reported; NS=not significant; NSD=no significant difference; SD=standard deviation; SES=socioeconomic status.

Appendix D Table 2 Detailed Intervention Descriptions of Included Behavior-Based Intervention Trials, in Alphabetical Order (KQs 3–5)

Author, Year & Quality | Intervention Group | Intervention Description | Control Group | Control Group Description
Boudreau, 2013^117^ Fair | IG1: PowerUp + coaching | Five weekly (with a sixth, 3 months later) 90-minute PowerUp classes educated children and caregivers about nutrition, activity, and stress management. Classes separated children and caregivers who participated in interactive activities; topics included portion control, healthy snacking, label reading, dangers of liquid calories, goal setting, TV viewing, family changes, stress and overeating, stress reduction, and physical activity; classes ended with physical activity component. Lessons reinforced at home via journals, assignments, and giveaway items. Concurrent monthly culturally-sensitive coaching for 6 months to empower families to incorporate learned behavior and address family and social barriers to lifestyle changes (based on ESFT Model); coaching occurred in-person at the health center, at the families’ home, or by phone. Families met with coach in-person at least once with subsequent in-person or phone meetings determined by family preferences and needs (with monthly contact ideal); home visits offered. | Waitlist | Control participants waited 6 months from baseline to begin the intervention, immediately following the 6-month assessment.
Boutelle, 2014^118^ Fair | IG1: Regulation of Cues (ROC) program | Weekly 45-minute group sessions for 12 weeks and biweekly for an additional two visits. Parents and children had separate but simultaneous meetings (content similar, delivery targeted for children). After group session, parents and children participated in an additional 30-min experiential exercise together. Components included psychoeducation (10 sessions) to increase awareness of overeating in relation to environment, parenting skills, coping skills (e.g., behavioral alternatives, relaxation, attentional focus, motivation to resist cues), self-monitoring of hunger and craving, experiential learning (cue exposure treatment, appetite awareness training). Included workbooks and handouts for parents and children. Individual followup provided when a meeting was missed. | Waitlist | No intervention during the 4 months of treatment. At posttreatment assessment, participants were given a binder for the program including at-home version of the curriculum with handouts and a brief 5-min orientation to the program. No other information provided to control group. Assessments provided at BL, 4 months and 8 months.
Bryant, 2011^120^ Fair | IG1: WATCH IT | Encourage lifestyle changes by taking motivational enhancement and solution focused approach. Included 16 weekly 30-min individual appointments for child and parent together for encouragement, support and motivational counseling using HELP manual. Session included healthy diet and physical activity information as well as discussions on the degree to which behavior change is important to the individual, their confidence in their ability to achieve behavior change, the degree to which change is a priority; views the patient as the expert in “what works” for them. Activities make links between thoughts and emotional responses that contribute to overeating. 16 1-hr weekly group physical activity sessions. Optional further 4 or 8 months of continuing sessions offered. Group parenting sessions mentioned in source article (number NR, may be part of optional additional 4 to 8 months’ treatment, unclear if offered in current study). | Waitlist | 12 month waitlist control
Croker, 2012^124^ Fair | IG1: Family-based behavioral therapy | Family-based behavioral treatment consisting of 15 90-minute group sessions over 6 months (10 weekly, 3 fortnightly, 2 monthly) with parents and children meeting separately but concurrently for 10 sessions and 5 joint parent-child sessions. Behavior modification techniques included: self-monitoring, goal setting, positive reinforcement, stimulus control, and relapse prevention. Advice provided on managing teasing and general problem-solving. Parents taught behavior management principles to assist child’s behavior change and modify home environment for family-wide lifestyle change. Specific dietary targets included regular eating patterns, reduced snacks (≤2 times/day), balanced diet (as described in ‘eatwell plate’ and ‘Traffic Light’ system). Specific physical activity targets included reducing sedentary behavior and 60 mins/day lifestyle or structured activity. Baseline assessment included “motivational assessment” including children and parents’ independent rating of motivation for making lifestyle changes as well as perceived benefits of and barriers to change. | Waitlist | 6-month waitlist control. Baseline assessment included “motivational assessment” including children and parents’ independent rating of motivation for making lifestyle changes as well as perceived benefits of and barriers to change.
Davis, 2012^125^ Fair | IG1: Maintenance (Group classes) | Prior to randomization, participant completed either nutrition only (N) or nutrition + strength training (N+ST) classes that included a cooking component, a snack, nutrition lesson (focused on reducing sugar and increasing fiber intake), and a 45-minute strength training session (for those in N +ST) led by a certified personal trainer. Participants were encouraged to eat healthy and do strength training on their own at home throughout the entire program. All participants received a variety of cooking utensils and gadgets (cutting boards, apple cutters, etc.) throughout the program. Participants in the N+ST group also received resistance bands and an instructional video of exercises to do with the bands. Parents and children had separate classes. For current study, randomized adolescents attended 8 monthly 90-minute weight loss maintenance group classes, similar to those received during the 4-month intervention preceding this maintenance trial. Participants also received 4 motivational interviewing sessions over the phone and lasting approximately 15 minutes designed to help participants resolve ambivalence and engage in healthier eating and strength training in their own home. Parents were also offered separate monthly classes, which were held simultaneously with the teen group classes with the same curriculum that the youth were receiving. Parents were asked to attend a minimum of 2 classes. | Newsletters | 8 monthly newsletters that matched previous 4-month intervention group assignment (nutrition or nutrition plus strength training). Newsletters included dietary tips and recipes, information about benefits of strength training and sample exercises, and information on community resources. Participants were called twice to make sure newsletters were received and to verify contact information; no lifestyle content was delivered. Anthropomorthic measurements taken before and after maintenance phase.
Broccoli, 2016^119^ Good | IG1: Motivational Interviewing | Family pediatrician-led MI consisting of 5 individual meetings based on transtheoretical model of addiction and behavior change; child and parents always had to leave the meeting having agreed on two objectives (1 food, 1 physical activity); during each subsequent interview, degree of achievement of the objectives set at previous meeting assessed; objectives reinforced or redefined and recorded. Pediatricians attended 20-hr training course on motivational interviewing prior to study start. | Obesity prevention booklet | Received a booklet with the main information on obesity prevention, then usual care currently offered by pediatricians (i.e., opportunistic advice if the pediatrician is seeing the child for other reasons).
DeBar, 2012^126^ Good | IG1: Multicomponent behavioral intervention | 16 90-minute group meetings; weekly for 3 months than biweekly during months 4 and 5 where teens were weighed, revised dietary and physical activity self-monitoring records. Telephone sessions offered if unable to attend sessions. Multicomponent intervention included change in dietary intake and eating patterns (e.g., decreasing portion sizes, limiting energy-dense foods, consume lower energy-dense foods); increasing physical activity by using developmentally tailored forms of exercise (e.g., exergaming equipment, yoga, strength training, pedometers, developing goal of 30–60 minutes at least 5 days per week, limiting screen time to 2 hours per day); addressing issues associated w/ obesity in adolescent girls (mood regulation, body image, self esteem, media education, sleep); and training the primary care physician to support behavioral weight management goals. Each sessions reviewed goals, problem solving to overcome barriers and challenges in increased activity. Specific behavioral and cognitive tools for coping included regular self-monitoring of dietary intake, physical activity and screen time; stimulus control and environmental changes, stepwise goal-setting and problem solving; setting goals for increasing pleasant activities; and cognitive restructuring techniques to combat negative self-talk. Parents invited to separate weekly group meetings in first 3 months where they learned to support their daughter and address potential barriers to success; encourage appropriate teen autonomy and improve understanding of how parents’ own attitudes, eating behavior, monitoring and comments may affect daughters. Adolescents met w/ their PCPs who were trained in motivational enhancement techniques at BL and 6 months where they received a health status summary and targeted areas of improvement (e.g., physical activity); PCPs encouraged to help pt select 1–2 of these targets. | PCP Meeting + materials | Received a packet of materials, including approaches to weight management, a parents’ guide to help teens make healthy lifestyle changes, local resources for weight management and healthy activity, and suggested books and online materials on healthy lifestyle change. Met with PCP at study onset to encourage healthy lifestyle changes.
Gerards, 2015^129^ Fair | IG1: Lifestyle Triple P | 14 week parent-only program with 10 90-minute group sessions and four individual 15–30 minute phone sessions. Aimed at changing parenting practices and general parenting styles; used active skills training methods based on self-regulation. Parents individually formulated goals in the first session and were instructed in the following strategies: positive parenting skills, modeling, stimulus control, shopping and cooking, behavior charts/monitoring, managing behavior and using rewards. Telephone sessions provided parents individualized support in implementing strategies at home. Materials included a parent workbook, recipes, and active games booklet. | Control | 2 brochures (1 on healthy nutrition and PA and 1 on positive parenting) and a short internet-based knowledge quiz (sent via email) including tailored advice and suggestions for active exercises at home.
Golley, 2007^130^ Fair | IG1: Triple P + healthy lifestyle group | Positive Parenting Program (Triple P) (4 weekly 2-hour group sessions with 7 15–20 minute individual followup calls) followed by 7 group lifestyle support sessions for parents and concurrent child PA sessions. Lifestyle sessions focused on knowledge and skills including family-focused healthy eating including specific food recommendations, monitoring, label reading, snacks, modifying recipes, being active, and roles and responsibilities about eating, managing appetite, self-esteem and teasing. While parents attended group sessions, children attended supervised PA sessions focused on fun aerobic games designed for play and easily replicated at home; PA sessions were diversional rather than interventional. Triple P parenting component aimed at changing parenting practices and general parenting styles; used active skills training methods based on self-regulation. Core parenting skills included: parent-child relationship enhancement, encouraging desirable behavior, teaching new skills and behaviors, managing misbehavior, preventing problems in high-risk situations, self-regulation, mood management and coping, partner support and communication. Telephone sessions provided parents individualized support in implementing strategies at home. Materials included standard Triple P resources (workbook and video) and a healthy lifestyle pamphlet. | Waitlist | Waitlist control for 12 months; healthy-lifestyle pamphlet and 3–4 telephone calls for retention purposes (content not specified)
Golley, 2007^130^ Fair | IG2: Triple P | Positive Parenting Program (Triple P): 4 weekly 2-hour group sessions with 7 15–20 minute individual followup calls. Aimed at changing parenting practices and general parenting styles; used active skills training methods based on self-regulation. Core parenting skills included: parent-child relationship enhancement, encouraging desirable behavior, teaching new skills and behaviors, managing misbehavior, preventing problems in high-risk situations, self-regulation, mood management and coping, partner support and communication. Lifestyle-specific strategies not addressed. Telephone sessions provided parents individualized support in implementing strategies at home. Materials included standard Triple P resources (workbook and video shown during session) and a healthy lifestyle pamphlet. | Waitlist | Waitlist control for 12 months; healthy-lifestyle pamphlet and 3–4 telephone calls for retention purposes (content not specified)
Hofsteenge, 2014^131^ Fair | IG1: Go4it | Seven 90-min group sessions every 2–3 weeks over 3 months followed by 2 maintenance booster sessions. Sessions consisted of education on healthy dietary, sedentary, and PA behavior and CBT for lifestyle improvement and maintenance of energy balance; sessions were interactive and included homework. Behavior change strategies included: self-monitoring of diet and activity (via pedometers), setting personal goals, and techniques for coping with difficult situations and teasing. Participants remained in same group throughout intervention (8–12 in a group). Two separate parent sessions covered education on health risks of overweight, healthy behavior, and how to support their children. Materials included an information book, workbook, and dietary and PA diaries. [Due to high attrition for 18-month outcomes, only 6-month outcomes used and included in intervention description and intensity calculations]. | Usual care | Regular care in the Netherlands; consisted of referral to a dietician in the home care setting. Teens had to make the appointment themselves.
Kalarchian, 2009^132^ Fair | IG1: Family-based lifestyle intervention | 20 60-min group sessions during first 6 months; adult and child groups met separately and presented with complementary material. Before or after these sessions, adult and child jointly met with lifestyle coach to review self-monitoring records and set weekly goals. 6 booster sessions (3 group, 3 telephone calls) between 6 and 12 months with no further contact after 12 months. Intervention adapted from Epstein and included modified Stoplight Eating Plan with daily energy range, and goal to increase PA and decrease PA to less than 15 hours/week. Behavior change techniques included: self-monitoring, environmental changes, step-wise goal setting, stimulus control, and positive reinforcement. Instruction provided in setting realistic expectations, promoting body image, minimizing emotional eating, and coping with teasing. Adults instructed to set goals and model behavior change; overweight adults encouraged to lose weight. | Nutrition consultation | Adults and children offered 2 nutrition consultation sessions to develop an individual nutrition plan based on the Stoplight Eating Plan; offered intervention after completion of 18-month assessment. This group intended as usual care in patients with severe obesity.
Kalavainen, 2007^133^ Fair | IG1: Health-promoting lifestyle | 15 90-minute group sessions; 14 held separately for parents and children and one session held together (10 weekly sessions, and 5 every 2 weeks). Program focused on healthy lifestyle as opposed to weight management and parents were targeted as the main agents of change; lifestyle changes intended for entire family and overweight parents who desired to lose weight were encouraged. Parent sessions included education on healthy lifestyle, parenting skills, and behavior change techniques (pros and cons, goal-setting, self-monitoring, stimulus control and cue elimination, action planning, problem-solving, and relapse prevention). Child sessions involved functional activities and non-competitive PA. Parents given treatment manuals and children given workbooks; materials based on Magnificent Kids and Magnificent Teens and “Think Good-Feel Good” CBT workbook. Homework assigned to parents and children; the importance of regular weighing at home emphasized. | Brief education + booklets | Booklets for families and 2 30-min individual sessions for each child with school nurse. Booklets contained information about weight management, eating habits and PA. Appointments intended for child only but parents allowed if willing. Themes of sessions were self-knowledge and PA; weight and height measured at each session. Children completed workbooks with school nurse and at home with parents. Booklets and workbooks based on Magnificent Kids material and “Think Good-Feel Good” CBT workbook.
Kong, 2013^136^ Fair | IG1: ACTION | Transtheoretical model based-intervention consisting of 8 motivational interviews with PCP and student over the academic year (1 session every 2–3 weeks), DVD and print materials from a toolkit, and 8 motivational interview followup calls with caregivers. At 1st visit, patient received DVD player and DVD (content included adolescent motivation for change, strategies targeting energy balance and nutritional quality, physical aerobic dance and strength training) and summary of medical results; this visit dedicated to reviewing medical history, assessing diet and PA and stage of change, and feedback about status relative to recommendations. Participants asked to review DVD and followup with topics they would like to discuss at next session. Subsequent visits tailored to stage of change with intention of moving toward goal setting for healthier eating and PA. Print materials included: weight loss guidelines for clinicians, MI for clinicians, newsletter for caregivers, clinic displays, and adolescent session tools (goal setting, activity/food journal). | Single PCP visit + booklet | 1 PCP clinic visit at beginning of trial for assesment of diet and PA, review of medical results, and feedback about status relative to national recommendations. Provided AAP “Balance for a Healthy Life” booklet.
Lison, 2012^137^ Fair | IG1: Hospital-based group exercise | Two 1-hour parent/child group education sessions and 120 group PA sessions (5 1-hour supervised sessions per week for 6 months). Education sessions covered importance of weight loss and maintenance, therapeutic nutritional approach to childhood obesity, and role of PA in cardiovascular fitness. Dietary focus was Mediterranean diet. Behavior change strategies included stimulus control, pre-planning, problem solving, and skills for shopping and interpreting food labels. Encouraged to reduce sedentary behavior. 60-minute group exercise sessions included stretching, moderate aerobic activity, and resistance training tailored to each participant with increasing intensity throughout program; parents were allowed to remain present for PA sessions. 5 sessions offered per week with minimum attendance at 3 per week strongly advised. Group sessions aimed to foster positive feeling and attitude toward PA. Participants and parents asked to practice PA during the weekend. | Lifestyle instruction during regular visits | Instructed about diet and other lifestyle changes during regular visits to the hospital, but did not receive the education or PA sessions. Maintained usual levels of of daily activity with no additional exercise components.
Lison, 2012^137^ Fair | IG2: Home-based exercise | Two 1-hour parent/child education sessions and detailed plan for 120 sessions of home-based exercise (5 1-hour sessions per week for 6 months). Education sessions covered importance of weight loss and maintenance, therapeutic nutritional approach to childhood obesity, and role of PA in cardiovascular fitness. Dietary focus was Mediterranean diet. Behavior change strategies included stimulus control, pre-planning, problem solving, and skills for shopping and interpreting food labels. Encouraged to reduce sedentary behavior. Home-based exercise program included demonstration of how to perform exercises, daily exercise log book, and detailed plan for home exercise sessions which included resistance and aerobic training with progressively increasing duration throughout program. Exercise plan was for 5 1-hr sessions per week for 6 months with minimum participation of 3 per week strongly advised. | Lifestyle instruction during regular visits | Instructed about diet and other lifestyle changes during regular visits to the hospital, but did not receive the education or PA sessions. Maintained usual levels of daily activity with no additional exercise components.
Looney, 2014^138^ Fair | IG1: Newsletters + Growth Monitoring + Family-based Behavioral Counseling | 6 monthly sessions (3 30-min in-person and 3 20-minute calls); half of session time was used for growth monitoring and standardized feedback and half of session time for behavioral counseling for the caretaker. A family-based approach was used where both the caretaker and child were encouraged to change and monitor eating and activity behaviors. Behavioral strategies included: self-monitoring, modeling, stimulus control, and positive reinforcement. Child behavioral goals included: <3 sugar-sweetened beverages/week, ≥1.5 cups vegetables/day, ≥1 cup fruit/day, ≥60 minutes/day of exercise, <2 hours/day TV; children asked to achieve 3 of 5 goals each day. Caretaker goals included <3 sugar-sweetened beverages/week, ≥2.5 cups vegetables/day, ≥1.5 cups fruit/day, ≥150 minutes exercise/week, <10 hours TV viewing/week. Level of goals increased incrementally until full program goal reached by month 4. Caretakers and children asked to monitor sugar-sweetened beverages, fruit, vegetables, activity and TV time; weekly picture-based diaries provided. 6 monthly mailed educational newsletters on nutrition and leisure-lime activity topics with recommendations to assist with child overweight and obesity plus usual care from the pediatrician (e.g., well-child visits, sick visits). | Newsletters | 6 monthly educational newsletters on nutrition and leisure-lime activity topics with recommendations to assist with child overweight and obesity plus usual care from the pediatrician (e.g., well-child visits, sick visits).
Looney, 2014^138^ Fair | IG2: Newsletters + Growth Monitoring | 6 monthly growth monitoring sessions with standardized feedback (3 15-min in-person appointments and 3 10-minute calls) with tools provided: scale, BMI wheel, wall growth chart, BMI-for-age growth chart, plotting tool, and growth self-monitoring diary. 6 monthly educational newsletters on nutrition and leisure-lime activity topics with recommendations to assist with child overweight and obesity plus usual care from the pediatrician (e.g., well-child visits, sick visits). | Newsletters | 6 monthly educational newsletters on nutrition and leisure-lime activity topics with recommendations to assist with child overweight and obesity plus usual care from the pediatrician (e.g., well-child visits, sick visits).
Love-Osborne, 2014^139^ Fair | IG1: Health educator visits | Initial visit with health educator (HE) consisted of feedback from diet and PA assessment using motivational interviewing to support change and goal-setting. Goals reviewed and modified at each subsequent visit. HE encouraged participants to choose 1 nutrition and 1 PA goal. Frequency of HE visits directed by participant (mean 5, range 1–8 visits). HE linked patients to existing resources for healthy eating and PA, including facilitating applications for free parks and recreation memberships. Self-monitoring of weight and lifestyle behaviors encouraged and incentives provided for returning log sheets. IG further randomized to 2 weekly text messages (1 individualized goal-related and one log sheet reminder) or no text messages during the first semester. Physical examination and laboratory screening as needed by physician. | Physical exam and lab screening if due, followup as needed | If physical exam and lab screening for comorbidities of obesity had not been done in previous 2 years, considered standard of care in the organization, a visit was scheduled in the school-based health center. Abnormal lab testing evaluated by physician investigators and addressed within school-based health center with referral for specialty care as needed.
McCallum, 2007^142^ Good | IG1: LEAP | Four GP consultations of brief solution-focused family therapy to support healthy lifestyle goals. 20-page family folder included 7 topic sheets targeting areas of behavioral change (sedentary time, physical activity, water consumption, eating habits and lower fat food options). Topic sheets summarized supporting evidence for the target behavior, modelled solutions to common challenges, and provided suggestions for reaching the goal. Materials included wall chart, reward stickers, and shopping tips. Parents encouraged to offer family meals, engage in shared parent-child activities, use praise and non-food rewards, and use contracting for behavior change. Before first appointment, GPs received intervention materials, summary of parent’s responses from baseline questionnaire regarding nutrition, physical activity and weight status concern, and child’s BMI. GP also provided brief encouragement during non-counseling visits. | Usual care | Usual care. Control families notified of control status via letter and never identified to GPs. Medical records of CG children audited to assess possible contamination (i.e., discussion of weight at a medical visit).
Mellin, 1987^143^ Fair | IG1: SHAPEDOWN | 14 90-minute weekly group sessions for adolescents and 2 90-minute parent sessions using SHAPEDOWN materials (a Leader’s Guide, parent workbook and adolescent workbook). Focus of the program was successive, sustainable, small modifications in diet, exercise, relationships, lifestyle, communication and attitudes; very-low calorie or restrictive diets avoided. Each session included voluntary weigh-in, leader-facilitated group interaction and exercise period. Parents instructed on strategies to support adolescents’ weight loss efforts including altering family diet and activity and improving parenting and communication skills. Techniques included: problem-solving, parenting skills (limit-setting and nurturing), cognitive therapy, stress management, body image therapy, and instruction in eating regular meals and eating in response to hunger and satiety. Content integrated ethnic, cultural, and economic differences and used examples of a broad range of family types. | Waitlist | Subjects received no treatment initially and were informed they could enroll in the next program that would commence after 6 months.
Nemet, 2005^144^ Fair | IG1: Dietitian + PA sessions | Four evening lectures w/ parents on childhood obesity, general nutrition, therapeutic nutritional approach for childhood obesity, physical activity and childhood obesity). Met w/ dietician 6 times and differed based on age of participant; if 6–8 years, parent only during first 2 sessions then child joined; if 8 year - pubertal, parent and child for all meetings; if adolescent, alternated child-only and parent-only meetings after joint 1st meeting. First session 45–60 minutes, all other sesssions 30–45 minutes. Instructed on nutritional education (e.g., food pyramid), food choices, dietary/cooking habits, and motivation for weight loss. Received a balanced hypocaloric diet (5021–8368 kg depending on age and weight), a caloric deficit of 30% from reported intake and intake 15% less than estimated daily required intake. Exercise program consisted of twice-weekly 1-hour training sessions, pts encouraged to add extra 30–45 minutes of walking or weight-bearing sports activities at least once per week. Encouraged to reduce sedentary activities. | Nutrition referral | Control subjects were referred to an ambulatory nutritional consultation at least once and were instructed to perform physical activity 3 times per week on their own.
Norman, 2015^145^ Fair | IG1: Stepped-down Care | Based on a combination of the chronic care model and social cognitive theory; followed recommendations from AAP about treatment of childhood obesity. Consisted of 3 4-month steps with a goal of 4lb weight loss every 4 months. If the participant did not meet the goal, the step was repeated. If the 4-lb weight loss was achieved, the participant ‘stepped down’ to the next level of reduced intensity. At the start of the program, the physician provided brief counseling on health diet and PA behaviors. If progress is not made, a follow-up physician visit occurred at month 8 and focused on weight management strategies. Face-to-face health educator visits occurred monthly in step 1 and bi-monthly in step 2, and included discussion of weight management concepts, identification of barriers to healthy eating and PA, and brainstorming problem-solving strategies to overcome barriers. These meetings were available to child and parent, but parents were not required to attend. Phone calls (biweekly in steps 1 and 2, monthly in step 3) were used to review progress, help set new goals and discuss barriers and solutions, speak to parents to reinforce parental involvement and emphasize importance of healthy changes in the home environment to encourage goal attainment. Diet and PA education materials were distributed at health education visits at pediatric clinics. Adolescent and parents asked to keep self-monitoring logs for steps and weight that could be shared with health counselor for feedback. Pedometers were distributed at the initial visit to monitor PA and help participants set PA goals. | Enhanced Usual Care | Received an initial counselling visit by physician, one visit with a health educator, materials on how to improve weight-related behaviors, and monthly follow-up mailings on weight-related issues. Labelled “enhanced” because participants received more than the current standard of practice in the Children’s Primary Care Medical Group for adolescents with obesity with no medical comorbidities. Participants also received pedometer at initial health educator visit
Nowicka, 2008^146^ Fair | IG1: Family Weight School | Based on systemic family and solution-focused therapies, using a systemic interactional method. Therapist aimed to reinforce family resources and create optimal emotional climate to help the child with obesity emphasizing parent cooperation, communication skills, mutual support, consistency and establishment of appropriate limits. 4 group meetings (up to 12 families) for 4 hours, including 10 minute individual family meetings w/ pediatric nurse or pediatrician with feedback (e.g., on child’s strengths) at each session. Intervention toolbox included nutrition (regular family meal planning, adequate portion sizes, limited intake of nutrient-poor foods, increased intake of F/V, water over SSBs), physical activity (≥60 minutes per day), decreasing sedentary time (max 2 hours per day), and lifestyle modifications (select 1–2 changes for subsequent visits). Child and parents met together for at least 1 hour at all meetings, separately for 1.5 hours during meeting 2 and 3 only. | Waitlist | Once the treatment condition was filled, additionally referred children were placed on the waiting list for treatment. This group served as the control group. The control group did not receive any treatment during the 1 year study period.
O’Connor, 2013^147^ Fair | IG1: Helping HAND | 6 monthly individual family sessions with health advisors with followup phone call 2 weeks after each session. Behavior change strategies included: collaborative goal setting for children and parents, action planning, behavioral contract, self-monitoring of goal-specific behavior, and problem solving. Child behavior goals selected from menu of goals about healthy diet, PA, and TV time; goals were for 1-month period with option to work on the goal for an additional month. Parent goals included behavior-specific parenting practices (responsiveness, structure and nondirected control for diet; logistic support and modeling for PA; and mediation and social coviewing for TV). Worksheets used during sessions to facilitate goal-setting and problem-solving. | Waitlist | Asked to see doctor as regularly scheduled and follow doctor’s advice and treatment plans. Recontacted after 7 months for post-intervention data collection and to start intervention; asked to avoid participation in other obesity prevention or treatment programmes during this time.
Raynor, 2012a^148^ Fair | IG1: DECREASE + Growth Monitoring | 8 45-minute parent-only group behavioral sessions (biweekly for 2 months and monthly for months 3–6). Behavior change strategies included: self-monitoring, pre-planning, problem-solving, shaping, setting goals, positive reinforcement, stimulus control, and parental modeling. Children and parents self-monitored targeted behaviors and submitted logs at meetings. Used a restrictive approach to reduce intake of non-nutrient-dense, energy-dense foods. Goal was to reduce intake of sweet and salty snacks to ≤3 servings/week and sugar-sweetened beverages to ≤3 servings/week. Growth assessed at 0, 3, and 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. | Monthly newsletters + growth monitoring | Monthly newsletter with information about healthy eating and leisure-time behaviors; growth assessed at 0, 3, + 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. Families provided with research staff contact information and encouraged to contact staff with any questions about information in the letter.
Raynor, 2012a^148^ Fair | IG2: INCREASE + Growth Monitoring | Eight 45-minute parent-only group behavioral sessions (biweekly for 2 months and monthly for months 3–6). Behavior change strategies included: self-monitoring, pre-planning, problem-solving, shaping, setting goals, positive reinforcement, stimulus control, and parental modeling. Children and parents self-monitored targeted behaviors and submitted logs at meetings. Increase healthy food intake to shape food preference for these foods and lower energy density of the diet. Goal was to consume 2 servings/day of whole fruit, 3 servings/day of vegetables, and 2 servings/day of low-fat dairy products. Growth assessed at 0, 3, and 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. | Monthly newsletters + growth monitoring | Monthly newsletter with information about healthy eating and leisure-time behaviors; growth assessed at 0, 3, + 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. Families provided with research staff contact information and encouraged to contact staff with any questions about information in the letter.
Raynor, 2012b^148^ Fair | IG1: TRADITIONAL + Growth Monitoring | Eight 45-minute parent-only group behavioral sessions (biweekly for 2 months and monthly for months 3–6). Behavior change strategies included: self-monitoring, pre-planning, problem-solving, shaping, setting goals, positive reinforcement, stimulus control, and parental modeling. Children and parents self-monitored targeted behaviors and submitted logs at meetings. Focused on two typically targeted behaviors in pediatric weight management programs, decreasing sugar-sweetened beverages and increasing PA. Goals were 60 minutes/day of moderate-intensity PA (30 minutes/day for parents) most days of the week and for children and parents to consume ≤3 servings of sugar-sweetened beverages/week. Growth assessed at 0, 3, and 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. | Monthly newsletters + growth monitoring | Monthly newsletter with information about healthy eating and leisure-time behaviors; growth assessed at 0, 3, + 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. Families provided with research staff contact information and encouraged to contact staff with any questions about information in the letter.
Raynor, 2012b^148^ Fair | IG2: SUBSTITUTES + Growth Monitoring | Eight 45-minute parent-only group behavioral sessions (biweekly for 2 months and monthly for months 3–6). Behavior change strategies included: self-monitoring, pre-planning, problem-solving, shaping, setting goals, positive reinforcement, stimulus control, and parental modeling. Children and parents self-monitored targeted behaviors and submitted logs at meetings. Used behavioral economics approach to enhance the feeling of choice for engaging in and liking the targeted behaviors in order to increase long-term adherence. Goals were to watch ≤2 hours of TV per day (as a substitute for PA) and consume 2 servings of low-fat milk per day (as a substitute for sugar-sweetened beverages). Growth assessed at 0, 3, and 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. | Monthly newsletters + growth monitoring | Monthly newsletter with information about healthy eating and leisure-time behaviors; growth assessed at 0, 3, + 6 months. Letters providing changes in height, weight, BMI, BMI percentile, and % overweight and interpretation of changes were sent to families and the child’s PCP after each growth assessment. Families provided with research staff contact information and encouraged to contact staff with any questions about information in the letter.
Reinehr, 2006^149^ Fair | IG1: Obeldicks | Covered physical exercise, nutrition education and behavioral therapy including individual psychological care of child and family. Intensive phase (3 months): nutritional education (traffic light system, target 30% fat, 15% protein, 55% carbohydrates) and behavior therapy groups (6 group sessions, 1.5 hours each); concurrent parent sessions; weekly PA sessions. Establishing phase (6 months): 3 parent group “talk rounds” sessions, solution-focused individual family therapy (30 min/month), weekly PA sessions. Followup phase (3 months): further individual psychogical care as needed, weekly PA sessions. PA sessions included ballgames, jogging, trampoline jumping, instruction in PA as part of daily life, instruction to reduce sedentary time. Behavioral course included behavior contracts, booster systems, self-reflecting curves, impulse control techniques, self instruction, cognitive restructuring, development of problem-solving strategies, training in social competences, model learning via parents, and relapse prevention. | Distance control | Control group comprised of children who met eligibility criteria but whose families lived too far away to travel regularly to the obesity clinic.
Reinehr, 2009^150^ Fair | IG1: Obeldicks | Covered physical exercise, nutrition education and behavioral therapy including individual psychological care of child and family. Intensive phase (3 months): nutritional education (traffic light system, target 30% fat, 15% protein, 55% carbohydrates) and behavior therapy groups (6 group sessions, 1.5 hours each); concurrent parent sessions; weekly PA sessions. Establishing phase (6 months): 3 parent group “talk rounds” sessions, solution-focused individual family therapy (30 min/month), weekly PA sessions. Followup phase (3 months): further individual psychogical care as needed, weekly PA sessions. PA sessions included ballgames, jogging, trampoline jumping, instruction in PA as part of daily life, instruction to reduce sedentary time. Behavioral course included behavior contracts, booster systems, self-reflecting curves, impulse control techniques, self instruction, cognitive restructuring, development of problem-solving strategies, training in social competences, model learning via parents, and relapse prevention. | Distance control | The control group was made up of children with 1 year of follow up available who were not treated with the lifestyle intervention because they lived too far away and had no means of transportation. Children and their families were advised in a 15 minute consultation about healthy diet and necessary physical exercise and behaviors. Written information on nutrition with recipes was provided.
Reinehr, 2010^151^ Fair | IG1: Obeldicks light | Intervention included PA training, nutrition education, and behavior counseling and was performed in group sessions with individual counseling for child and family. Children divided into groups based on sex and age. PA training involved weekly 1.5 hour sessions for 6 months with exercise activities and instruction in PA and reduction in TV and computer game time. Nutrition course based on “Optimized Mixed Diet” which was fat and sugar reduced and contained 30% of energy from fat, 15% energy from protein, and 55% energy from carbohydrates. Children followed traffic light system. During intensive phase of first 3 months, 6–1.5 hour group sessions for kids about nutrition and eating behavior and 6–1.5 hour parent sessions which included nutrition, PA and behavior education, 1 30-min individual nutrition counseling session. During “establishing phase” (next 3 months) 4 30-minute individual child/parent counselling sessions were held (2 nutrition-focused), plus continuation of weekly PA sessions. | Waitlist | Waitlist control for 6 months
Resnicow, 2015^152^ Fair | IG1: PCP + RD MI | Same as IG2 + 6 additional motivational interviewing counseling sessions conducted by RD over 2 years. RDs given flexibility in scheduling counseling sessions, though encouraged to provide more visits toward the beginning of the intervention. RD sessions delivered in-person or by phone. | Usual care | Measurements at BL, 1- + 2-year F/U and provided routine care by PCP, as well as standard educational materials for parents that addressed healthy eating and exercise. Usual care PCPs attended a half-day orientation session that included current treatment guidelines.
Resnicow, 2015^152^ Fair | IG2: PCP MI | 3 brief PCP-delivered MI counseling sessions with parents in year 1 and 1 additional “booster” visit in year 2 (flexibility allowed in session scheduling). Techniques include reflective listening, autonomy support, shared decision-making, and eliciting change talk (e.g. building discrepancy through values clarification, importance/confidence rulers). Targeted dietary and activity behaviors included: snack foods, sweetened beverages, eating in restaurants, fruits, vegetables, TV/screen time, video and computer games and PA/exercise. Target behaviors identified by a brief screener. PCPs asked to provide positive feedback on “green” behaviors and collaboratively identify with the parent “red” or “yellow” behaviors they would be willing to discuss and possibly modify. Provided materials were tailored to the chosen targeted behavior. Self-monitoring logs offered. | Usual care | Measurements at BL, 1- + 2-year F/U and provided routine care by PCP, as well as standard educational materials for parents that addressed healthy eating and exercise. Usual care PCPs attended a half-day orientation session that included current treatment guidelines.
Sacher, 2010^153^ Fair | IG1: MEND | Multicomponent group healthy lifestyle program based on nutritional and sports science plus from psychology, learning and social cognitive theories. Engages family in process of weight management by addressing education, skills training and motivational enhancement. 18 group (8–15 children w/ parents or carers and siblings) sessions over 9 weeks (2-hour health twice a week in early evening) by two MEND leaders and one assistant. Sessions included 1 introduction, 8 behavior change (apply techniques to change such as stimulus control, goal setting, reinforcement, and response prevention), 8 nutrition education (healthy eating, weekly achievable diet targets, label reading, supermarket tour, recipes and food preparation, food samples, discouraged weighing in favor of increasing healthy habits), 16 PA sessions (1 hour exercise) for children, and a closing session. Free access to community swimming pool for 12 weeks. | Waitlist | Received intervention after 6 months wait period
Saelens, 2002^154^ Fair | IG1: Healthy Habits Intervention | Healthy habits intervention: 1 computerized assessment followed by 1 meeting with pediatrician to discuss assessment results, develop action plan; 11 10–20 min counseling calls; mailed participant manual in 3 different mailings (part of manual mailed each time, included information sheet for parents); encouraged self-monitoring of food intake and PA; single session to discuss intervention and self-monitoring with child and parents | Single pediatrician session | Meeting with pediatrician assessing motivation and providing (non-tailored) information on healthy eating and PA
Savoye, 2007^156^ Fair | IG1: Bright Bodies | Family group sessions twice per week for 6 months, then twice monthly for 6 months. First 6 months: two 50-min exercise sessions/week (parents and children together), 1 weekly weigh-in (both parents and children), and 1 weekly 40-min class covering nutrition (parents and children together) and behavior modification (parents and children in separate groups). Encouraged to exercise 3 additional days/week. Used motivational tools to increase attendance, such as a game accumulating points for participation in group activities and exercise. Dietician led the nutrition portion of the class using the Smart Moves workbook and emphasized a non-diet approach to healthy eating. Behavior modification portion was facilitated by dietician or social worker, and included self-awareness, goal setting, stimulus control, coping skills training, cognitive behavior strategies, and contingency management. Exercise consisted of warm-up, high-intensity and cool-down; once per month special exercise activities planned (e.g., Zumba class). During behavioral modification portion parents attended a separate coping skills training class that emphasized the important of parent as role model, led by psychologist or dietician. | Semi-annual individual counseling | Seen in pediatric obesity clinic every 6 months; Diet (decrease intake of juice, switching to diet produts, bringing lunch to school) and exercise (decrease sedentary activities) counseling by RD and physician, and brief psychological counseling with social worker; caregiver involved in nutrition an activity goal-setting
Savoye, 2014^155^ Fair | IG1: Bright Bodies | Group family sessions twice per week for 6 months at two separate locations (one w/ Spanish bilingual instructors); two 50-min exercise sessions/week, 1 weekly weigh-in, and 1 weekly 40-min nutrition and behavior modification class. Encouraged to exercise 3 additional days/week. Earned tickets for monthly raffle for weight maintenance or loss and, in some cases, for turning in exercise logs. Dietician led the nutrition and behavioral modification class using the Smart Moves workbook. Nutrition component emphasized a non-diet approach to healthy eating. Behavior modification included self-awareness, goal setting, stimulus control, coping skills training, cognitive behavior strategies, and contingency management. Exercise consisted of warm-up, high-intensity and cool-down; once per month special exercise activities planned (e.g., Zumba class). During behavioral modification portion parents attended a support class with solution-focused brief therapy elements and tool (e.g., strength cards, so help parent identify their own and their child’s strengths), led by psychologist or dietician. | General advice + brief psychosocial counseling | Followed in the clinic every 6 months and received general diet and exercise counseling by dieticians and physicians along with brief psychosocial counseling by a social worker.
Sherwood, 2015^157^ Fair | IG1: Busy Bodies/Better Bites | Brief pediatric primary care component (including the use of a flipchart and pamphlet) regarding obesity and injury prevention in addition to eight biweekly (15–30 min) phone coaching sessions focusing on healthy eating and physical activity and received a bag of relevant activities and workbooks (Busy Bodies / Better Bites). Phone sessions including goal setting and MI to reduce screen time, increase physical activity, decrease SSBs, increase availability of healthy foods. Each phone session reviewed behavior changes with a discussion of challenges and successes. | Attention control (injury prevention) | Brief pediatric primary care component (including use of a flipchart and pamphlet) regarding obesity and injury prevention plus 8 biweekly (15–30 min) phone coaching sessions focusing on safety and injury prevention and received a bag of relevant activities and workbooks (Healthy Tots/Safe Spots). Phone sessions including goal setting and MI to reduce distracted driving, prevent falls, fire safety, poison control, and sun protection. Each phone session reviewed behavior changes with a discussion of challenges and successes.
Stark, 2011^160^ Fair | IG1: LAUNCH | Phase 1 (intensive intervention), 12 weekly sessions that alternated btwn group-based clinic session (parent and child concurrent groups) and individual home visits; Phase 2 (maintenance), 6 sessions (every other week over 12 weeks) alternating btwn group clinic-base sessions and home sessions. Parent clinic-based sessions (90 minutes) addressed dietary education (snacks/beverages, breakfast/lunch, dinner) and kept dietary diaries for child (caloric goal 1000–1200/day); decreasing screen time (<2 hours/day) and increasing physical activity (60 minutes/day). Both parent and child provided w/ pedometers (goal 5000–10000 steps/day). Parents taught by license clinical psychologist to use child bx management skills including praise and attention to increase healthy bx, ignoring and timeouts to manage tantrums, contingency management and modeling; taught stimulus control; provided w/ 14 day supply of vegetables for taste-testing w/ child. Children received nutrition education, tried new foods during structured meals, and complete 15 minutes of moderate-to-vigorous exercise in a group format conducted by a pediatric psychology postdoc and research coordinator. In-home sessions (60–90 minutes) to support generalization of clinic-taught skills as well as clean-outs of pantry (high-calorie/low-nutrient foods) and assisted parents w/ setting a safe place in home for active play. During maintenance stage, session focused on helping families continue or maintain changes by identifying barriers and problem-solving; diet diary recording reduced to 3 days/week and pedometers worn but not longer recorded. | Enhanced standard of care | Each family met with a pediatrican for 1 45-minute session to review child’s growth chart and to explain BMI, BMI percentiles, and the child’s current BMI percentile. Recommendations were made in accordance with “Prevention Plus” for preschool children with obesity: amount of screen time, amount of active play time, amount of soda and juice, amount of fruits and vegetables, limiting eating out, and appropriate portion sizes. Received 1-page healthy food and activity brochure.
Stark, 2014^159^ Fair | IG1: LAUNCH-clinic | 10-session manualized intervention to produce small decreases or stabilize rate of child weight gain consistent w/current obesity treatment recommendations. Parent-group clinic sessions (90 min) concurrent w/child group sessions (90 min). Parent sessions (90 min) addressed dietary education (snacks/beverages, breakfast/lunch, dinner) and kept dietary diaries for child (caloric goal 1000–1200/day); decreasing screen time (<2 hours/day) and increasing physical activity (60 min/day), emphasized parental modeling of health lifestyle behaviors. Both parent and child provided w/pedometers (goal 5000–10000 steps/day). Children received nutrition education, tried new foods during structured meals, and complete 15 min of moderate-to-vigorous exercise in a group format conducted by a pediatric psychology postdoc and research coordinator. Parents taught by license clinical psychologist to use child bx management skills including praise and attention to increase healthy bx, ignoring and timeouts to manage tantrums, contingency management and modeling; taught stimulus control. At each sessions, parents provided w/vegetables for daily taste tests (14 days worth of food) and kept food diaries. Also received a home clean-out box to use on their own to eliminate high-calorie, low-nutrient foods from home. Sessions conducted every other week during first 3 months, then monthly during next 3 months for 10 treatment sessions | Enhanced standard of care | Pediatrician met with each family to explain BMI, BMI percentiles, and to review the child’s growth chart in a single 45-minute meeting. Modeled on AAP “Prevention Plus” guideline--Pediatrician made recommendations regarding daily screen time, active play, eliminating soda, fruit and vegetable servings, limiting eating out, and appropriate portion sizes for preschoolers. Received 1 page healthy food and activity brochure.
Stettler, 2014^161^ Fair | IG1: Multiple-behavior change | 12 15–25 min weekly (1–4 sessions), biweekly (5, 6), monthly (7, 8) and bimonthy (9–12) with child, parent/guardian and clinician. Bx goals to reduce intake of “Whoa” sugary drinks (e.g., soda, lemonade), increase intake of “Go” drinks (water, milk), increase pedometer to 15000 steps/day, and reduce screen time ≤ 2 hours/day. Increase knowledge of serving sizes, benefits of water intake, detrimental effects of sugary drinks, importance of parent modeling behavior, healthy eating, screen time, and physical activity. Skill-building of self-monitoring and stimulus control. Point-system used with children for positive reinforcement for both session attendance and behavioral change, behavioral contract signed by parent, child and clinician. Role-playing and other activities (e.g., grocery receipt review, measure target HR, identify alternatives to sedentary bx). | Attention control (bullying prevention) | 12 15–25-minute clinician, child, and parent sessions. Bullying prevention attention control condition to aid children in developing strategies for improving friendship making skills and anger management abilities. Children received cartoons of different social situations and discussed them with the clinician. Homework assignments included similar cartoons and other creative assignments including drawing places where bullying might happen, drawing what different emotions look like, and strategies for handling negative social situations. Point-system used with children for positive reinforcement for positive social behaviors and handling friendship-making problems but no behavioral contract. Sessions occurred on same schedule and for same length of time as IG conditions.
Stettler, 2014^161^ Fair | IG2: Combined | Combined participants from IG2 and IG3 | Attention control (bullying prevention) | 12 15–25 min clinician, child, and parent sessions. Bullying prevention attention control condition to aid children in developing strategies for improving friendship making skills and anger management abilities. Children received cartoons of different social situations and discussed them with the clinician. Homework assignments included similar cartoons and other creative assignments including drawing places where bullying might happen, drawing what different emotions look like, and strategies for handling negative social situations. Point-system used with children for positive reinforcement for positive social behaviors and handling friendship-making problems, but no behavioral contract. Sessions occurred on same schedule and for same length of time as IG conditions.
Stettler, 2014^161^ Fair | IG3: Beverage-only intervention | 12 15–25 min weekly (1–4 sessions), biweekly (5, 6), monthly (7, 8) and bimonthy (9–12) sessions with child, parent/guardian and clinician. Bx goals to reduce intake of “Whoa” sugary drinks (e.g., soda, lemonade), increase intake of “Go” drinks (water, milk). Increase Knowledge of serving sizes, benefits of water intake, detrimental effects of sugary drinks, and importance of parent modeling bx. Skill-building of self-monitoring and stimulus control. Point-system used with children for positive reinforcement for both session attendance and behavioral change, behavioral contract signed by parent, child and clinician. Role-playing and other activities (e.g., label reading, tooth brushing). | Attention control (bullying prevention) | 12 15–25 min clinician, child, and parent sessions. Bullying prevention attention control condition to aid children in developing strategies for improving friendship making skills and anger management abilities. Children received cartoons of different social situations and discussed them with the clinician. Homework assignments included similar cartoons and other creative assignments including drawing places where bullying might happen, drawing what different emotions look like, and strategies for handling negative social situations. Point-system used with children for positive reinforcement for positive social behaviors and handling friendship-making problems, but no behavioral contract. Sessions occurred on same schedule and for same length of time as IG conditions.
Tanofsky-Kraff, 2010^162^ Fair | IG1: IPT-Weight Gain Prevention | One individual 90-minute pre-group session and 12 75–90 minute weekly group sessions for the adolescents of interpersonal psychotherapy (IPT-WG) for the prevention of excessive weight gain. IPT is based on the assumption that binge eating occurs in response to poor social functioning and consequent negative mood and focused on improving interpersonal difficulties and social deficits. Group sessions offered psychoeducation and general skill-building that could be applied to different relationships within the framework of interpersonal problem areas; episodes of overeating and loss-of-control eating were linked to interpersonal functioning. | Attention control (health education) | 12 group health education sessions as attention control. Curriculum topics included: avoiding alcohol, drug, and tobacco use, identifying signs of depression and suicide, nonviolent conflict resolution, sun safety, domestic violence, and very basic information on nutrition, body image, and exercise. Information provided in didactic manner.
Taveras, 2011^163^ Good | IG1: MI + enhanced EMR and training | Chronic Care Model-based intervention where all practice team members were trained and electronic medical record enhanced to assist clinicians with decision support, patient tracking, followup, scheduling, and billing. 4 25-min face-to-face + 3 15-min phone motivational interviewing sessions with NP, which used tailored educational modules targeting TV viewing and fast food and SSB intake. Included printed and electronic behavior monitoring tools, lists of resources for PA, and interactive website. Focus on de-emphasizing labeling, giving the parent responsibility for identifying which behaviors are problematic, encouraging parents to clarify and resolve ambivalence about behavior change, and settings goals to initiate change process. Pediatricians trained to use brief, focused negotiation (based on motivational interviewing) in routine well-child exams to endorse family behavior change. Posters in waiting rooms highlighted targeted behaviors. Behavioral goals were <1 hr/ day TV or video viewing, no TV where child sleeps, ≤1 serving/week fast food, and ≤1 serving/day SSB. 1 year intervention period followed by less intensive maintenance period (not further described). | Usual care | Current standard of care offered by the pediatric practice. This included well-child care visits and follow-up appointments for weight checks with their pediatrician or a specialist (e.g., nutritionist). Families in the UC group visited the practice for the baseline and annual well-child appointment.
Taveras, 2015^164^ Good | IG1: CDS + coaching | Modified existing electronic health record to deploy a computerized, point-of-care CDS alert to pediatric clinicians at time of well-child visit for child with a BMI at ≥95th percentile. Alert contained links to growth charts, evidence-based childhood obesity screening and management guidelines, and a prepopulated standardized note template specific for obesity that included options for 1) documenting and coding for BMI percentile, 2) documenting and coding for nutrition and physical activity counseling, 3) placing referrals for weight management programs, 4) placing orders for lab studies if appropriate, and 5) printing educational materials. Clinicians were trained to use brief motivational interviewing to negotiate followup weight management plan with the patient and their family. A comprehensive set of educational materials were provided by pediatric clinicians to patients that focused on individual- and family-level behaviors, including 1) decreases in screen time, 2) decreases in consumption of sugar sweetened beverages, 3) increases in moderate and vigorous physical activity, and 4) improvement of sleep duration and quality. 4 newsletters were provided throughout the intervention period that included self-guided behavior change. 4 phone motivational interview sessions (time NR) with health coach and optional text messaging program for parents (2 texts/week, 1 educational message about a target behavior, 1 self-monitoring message asking how child did with specific target behavior with followup message after parent reply). Families were assigned a health coach who used motivational interviewing to support families by phone at 1, 3, 6, + 9 months. Parents were also invited to participate in interactive text message program. Parents who chose not to receive texts had option to receive same messages by email. Texts were received 2x/week during 1 year followup period and provided support for behavior change for the patient and their family. 1st text each week is an educational message about 1 of the recommended behaviors and 2nd is a self-monitoring message that asks how child did with a certain target behavior the day before. Outgoing text asks parents to reply to these messages, in turn they receive an automated feedback response message tailored to how they indicated they are doing meeting that behavior goal. | Usual care | Received the current standard of care offered by their pediatric office. No new decision support tools for obesity were made available in the electronic health records of the 4 usual care practices. Received generic health-related materials in the mail.
Taveras, 2015^164^ Good | IG2: CDS | Modified the existing electronic health record to deploy a computerized, point-of-care clinical decision support (CDS) alert to pediatric clinicians at the time of a well-child visit for a child with a BMI at the 95th percentile or greater. Alert contained links to growth charts, evidence-based childhood obesity screening and management guidelines, and a pre-populated standardized note template specific for obesity that included options for (1) documenting and coding for BMI percentile, (2) documenting and coding for nutrition and physical activity counseling, (3) placing referrals for weight management programs, (4) placing orders for lab studies if appropriate, and (5) printing educational materials. Clinicians were trained to use brief motivational interviewing to negotiate a follow-up weight management plan with the patient and their family. A comprehensive set of educational materials were developed to be provided by pediatric clinicians to patients that focused on individual- and family-level behaviors, including (1) decreases in screen time, (2) decreases in consumption of sugar sweetened beverages, (3) increases in moderate and vigorous physical activity, and (4) improvement of sleep duration and quality. Additionally, 4 newsletters were provided throughout the intervention period that included self-guided behavior change. | Usual care | Received the current standard of care offered by their pediatric office. No new decision support tools for obesity were made available in the electronic health records of the 4 usual care practices. Received generic health-related materials in the mail.
Taylor, 2015^165^ Good | IG1: Tailored lifestyle support | One individual 1–2 hour multidisciplinary session (mentor, dietician, exercise specialist, clinical psychologist) with parents followed by regular brief contact with mentor (nutritionist or exercise trainer) tailored to family’s goals and priorities, monthly for 1st year, ~ every 3 months in the 2nd year (total sessions ~14). At baseline, extensive report generated from collected data, specialists used the report to identify areas for change, but families took lead in identifying specific targets. Remaining contacts alternated between in-person visits at the university or in the home (30–40 min) and phone calls (5–10 min). Individual goals were negotiated and relevant resources, based on well-established behavioral strategies, were discussed. Resources covered parenting (talking about the study, goals, action plan, influences on child’s behavior, ground rules and rewards, actions and consequences, problem solving, stress management for parents), diet (“good food guide”, healthy options for fast food, food labels, feeding fussy eaters, shopping), and physical activity (getting the whole family active). Provided support and continued monitoring and adjustment to target behaviors over time. Est total intervention contact 6–7 hrs per family. | Brief feedback and advice | Met with trained researcher at baseline and 6 months. At first appt (30–45min) parents received individualized feedback about their child’s diet and activity habits based on comprehensive baseline assessment. Child’s results were compared with guidelines, other published data. Provided generalized advice using publicly available resources. Reviewed progress at second appt (15–30min), no new information/resources provided.
Van Grieken, 2013^166^ Fair | IG1: Be Active Eat Right | Prevention protocol initiated during a well-child visit, using motivational interviewing approach; 3 additional structured healthy lifestyle counseling sessions to promote overweight-prevention behaviors could be offered (approximately 3, 6, and 12 months after well-child visit). Content of additional counseling sessions was matched to parents’ stage of change as assessed during initial well-child visit. 4 behaviors targeted: play outside >1 hr/day, eat breakfast daily, ≤2 glasses sweet beverages/day, and maximum 2 hrs/day sedentary behavior). Parents together with staff chose 1–2 behaviors to target. Information materials provided, diet and activity diaries discussed, and family-oriented action plans for behavior change discussed. | Usual care | Parents were informed about the overweight status of their child but usual care was given, consisting of general information about a healthy lifestyle provided as part of a normal well-child visit.
Vos, 2011^167^ Fair | IG1: Family-based multidisciplinary lifestyle intervention | 2 individual family screening and counseling visits with a multidisciplinary team results in contract for behavioral goals, followed by 3-month intensive phase involving 7 group meetings, 2.5 hours each (7 child-only sessions, 5 parents-only sessions, 1 parent+child session, every 2 weeks) followed by booster sessions (2–3 per year) for 2 years. Individual visits include nutritional advice (traffic light nutrition), physical activity counseling, and psychological counseling (cognitive behavioral techniques for weight loss and help child deal with/accept their own body. Child group meetings focused on nutritional information, self-control techniques, problem solving, self-reward, self-regulation, stimulus control, self-image, coping strategies, and relapse prevention. Also included physical activity at each meeting (duration NR). Parent group meetings focused on lifestyle change, nutrition, and how to help child; parental role in family treatment conceived as therapeutic helper (positive feedback, positive support) and healthy lifestyle role model. Parenting style of strict rules but pleasant interactions encouraged. Booster sessions to maintain learned behavior through problem-solving and relapse prevention. Detailed description provided in study protocol. | Waitlist | Participants were given an initial physical activity and nutritional advice. After 12 months, they were offered multidisciplinary treatment.
Wake, 2009^168^ Good | IG1: LEAP-2 | Four GP consultations of brief solution-focused family therapy to support healthy lifestyle goals. 16-page family folder included 5 topic sheets each targeting one area of behavioral change (sedentary time, physical activity, water consumption, eating habits and lower fat food options). Topic sheets summarized supporting evidence for the target behavior, modelled solutions to common challenges, and provided suggestions for reaching the goal. Materials included wall chart, reward stickers, and shopping tips. Parents encouraged to offer family meals, engage in shared parent-child activities, use praise and non-food rewards, and use contracting for behavior change. Before first appointment, GPs received intervention materials, summary of parent’s responses from baseline questionnaire regarding nutrition, physical activity and weight status concern, and child’s BMI. GP also provided brief encouragement during non-counseling visits. | Usual care | Usual care. Control families notified of control status via letter and never identified to GPs. Medical records of CG children audited to assess possible contamination (i.e., discussion of weight at a medical visit).
Wake, 2013^169^ Good | IG1: HopSCOTCH | One hour-long family appointment with obesity specialist team (pediatrician and dietitian) followed by one 20–40 minute “long” GP consultation and 4–8 6–20 minute standard appointments; GP and specialist care linked by web-based software. Specialist team provided with individual patient summary about family and medical history, and daily diet, PA and sedentary activities. At this visit, clinicians and families agreed on an initial care plan and specific goals. Subsequent 20–40 minute GP session and regular 6–20 minute standard consultations every 4 to 8 weeks consisting of lifestyle and BMI progress review, problem solving, and goal setting using brief solution-focused techniques. All data entered into HopSCOTCH web-based software which was shared between specialist team and GP. 6 months after enrollment, specialist team accessed software to review participant progress and faxed a summary report to GP. Specialist team available to GP via email or phone. | Usual care | Participants were free to seek assistance from their GP or from any other service.
Weigel, 2008^170^ Fair | IG1: Sea Lion Club | Twice weekly child group sessions of 45–60 minutes for 12 months consisting of PA, dietary education, and coping strategies. The first weekly session was for PA and the second for nutrition and coping strategies. Children encouraged to complete diet and PA logs (which included parent’s signature) and discuss weekly with the group. Child groups divided by age for age-appropriate training and education. Parental support provided at optional separate 2-hour monthly meetings and feedback discussions; these included child-parent activities and social reinforcement. | Brief advice | 2 pediatrician visits with parent and child that included written therapeutic advice and explanation. Written materials included PA recommendations, dietary education, and coping strategies (e.g., awareness of eating behavior and recommendations for habit books); materials were explained to the family by the pediatrician and followed German obesity guidelines. Children and adolescent versions of materials also provided. After 1 year, participants were offered open, fun-based lessons in the sports center where the intervention had been performed.

Abbreviations: AAP=American Academy of Pediatricians; apt=appointment; BL=baseline; BMI=body mass index; btwn=between; bx=behavior; CBT=cognitive behavioral therapy; CDS=clinical decision support; CG=control group; DVD=digital video disc; EMR=electronic medical record; F/U=followup; F/V=fruits and vegetables; GP=general practitioner; HE=health education; HR=heart rate; hr(s)=hour(s); IG=intervention group; IPT=interpersonal therapy; MI=motivational interviewing; min=minute(s); NP=nurse practitioner; PCP=primary care physician; pt=participant; RD=registered dietitian; SSB=sugar-sweetened beverage; TV=television; UC=usual care; w/=with; WG=workgroup.

Appendix D Table 3 Weight Outcomes in Included Lifestyle-Based Weight Loss Trials (KQ 4)

Author, Year & Quality | Followup (months since tx ended) | Est hrs of contact | Outcome (unit) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Lison, 2012^137^ Fair | 6 (0) | 122 | BMI (kg/m^2^) | −0.40 (NR) | 32 | 1.60 (NR) | 20 | <0.0001
Lison, 2012^137^ Fair | 6 (0) | 122 | zBMI (BMI SDS) | −0.16 (NR) | 32 | −0.01 (NR) | 20 | 0.002
Lison, 2012^137^ Fair | 6 (0) | 122 | Weight (kg) | 1.20 (NR) | 32 | 7.80 (NR) | 20 | <0.0001
Lison, 2012^137^ Fair | 6 (0) | 122 | WC (cm) | −0.70 (NR) | 32 | 2.70 (NR) | 20 | 0.012
Weigel, 2008^170^ Fair | 12 (0) | 114 | BMI (kg/m^2^) | −1.50 (3.04) | 36 | 2.80 (3.86) | 30 | <0.001
Weigel, 2008^170^ Fair | 6 (**) | 114 | BMI (kg/m^2^) | −0.10 (3.76) | 36 | 1.70 (3.92) | 34 | <0.01
Weigel, 2008^170^ Fair | 6 (**) | 114 | zBMI (BMI SDS) | −0.14 (0.48) | 36 | 0.18 (0.57) | 34 | <0.05
Weigel, 2008^170^ Fair | 12 (0) | 114 | zBMI (BMI SDS) | −0.34 (0.48) | 36 | 0.26 (0.57) | 30 | <0.01
Savoye, 2007^156^ Fair | 6 (**) | 82 | BMI (kg/m^2^) | −2.10 (2.88) | 105 | 1.10 (2.97) | 69 | <0.001 | BL outcome
Savoye, 2007^156^ Fair | 12 (0) | 82 | BMI (kg/m^2^) | −1.70 (3.14) | 105 | 1.60 (3.18) | 69 | <0.001 | BL outcome
Savoye, 2007^156^ Fair | 12 (0) | 82 | Weight (kg) | 0.30 (8.89) | 105 | 7.70 (9.96) | 69 | <0.001 | BL outcome
Savoye, 2007^156^ Fair | 6 (**) | 82 | Weight (kg) | −2.60 (8.63) | 105 | 5.00 (9.11) | 69 | <0.001 | BL outcome
Savoye, 2014^155^ Fair | 6 (0) | 78 | BMI (kg/m^2^) | −0.37 (1.18) | 31 | 0.67 (1.68) | 27 | 0.005 | BL outcome and body weight, HbA1c, HOMA, DIo
Savoye, 2014^155^ Fair | 6 (0) | 78 | zBMI (BMI SDS) | −0.05 (0.13) | 31 | 0.04 (0.12) | 27 | <0.001 | BL outcome and body weight, HbA1c, HOMA, DIo
Savoye, 2014^155^ Fair | 6 (0) | 78 | Weight (kg) | 0.60 (4.72) | 31 | 3.70 (4.81) | 27 | 0.006 | BL outcome and body weight, HbA1c, HOMA, DIo
Reinehr, 2006^149^ Fair | 12 (0) | 78 | BMI (kg/m^2^) | 0.10 (4.21) | 174 | 2.00 (3.76) | 37 | 0.013
Reinehr, 2006^149^ Fair | 24 (12) | 78 | BMI (kg/m^2^) | 1.20 (4.95) | 174 | 2.90 (4.20) | 37 | NR
Reinehr, 2006^149^ Fair | 24 (12) | 78 | zBMI (BMI SDS) | −0.30 (0.35) | 174 | 0.00 (0.41) | 37 | NR
Reinehr, 2006^149^ Fair | 12 (0) | 78 | zBMI (BMI SDS) | −0.30 (0.35) | 174 | 0.00 (0.41) | 37 | 0.007
Reinehr, 2009^150^ Fair | 12 (0) | 78 | zBMI (BMI SDS) | −0.22 (0.35) | 288 | 0.15 (0.17) | 186 | <0.001 | Age, sex, BL zBMI, and pubertal stage
Reinehr, 2009^150^ Fair | 12 (0) | 78 | WC (cm) | −1.00 (12.53) | 288 | 4.00 (10.54) | 186 | <0.001 | Age, sex, BL zBMI, and pubertal stage
Reinehr, 2009^150^ Fair | 12 (0) | 78 | Percent with obesity | 216 (74.9) | 288 | 185 (99.3) | 186 | NR
Reinehr, 2010^151^ Fair | 6 (0) | 67 | BMI (kg/m^2^) | −0.85 (1.02) | 34 | 0.76 (0.99) | 32 | 0.001
Reinehr, 2010^151^ Fair | 6 (0) | 67 | zBMI (BMI SDS) | −0.26 (0.22) | 34 | 0.05 (0.19) | 32 | <0.001
Reinehr, 2010^151^ Fair | 6 (0) | 67 | WC (cm) | −6.00 (8.00) | 34 | 0.00 (1.00) | 32 | 0.008
Vos, 2011^167^ Fair | 12 (**) | 45 | zBMI (BMI SDS) | −0.40 (1.29) | 32 | −0.10 (1.12) | 35 | 0.02 | BL differences
Kalarchian, 2009^132^ Fair | 12 (0) | 44 | BMI (kg/m^2^) | 0.48 (2.95) | 97 | 1.09 (2.24) | 95 | 0.11
Kalarchian, 2009^132^ Fair | 6 (**) | 44 | BMI (kg/m^2^) | −0.68 (2.86) | 97 | 0.54 (2.05) | 95 | 0.0007
Kalarchian, 2009^132^ Fair | 18 (6) | 44 | BMI (kg/m^2^) | 1.50 (2.95) | 97 | 1.72 (2.05_ | 95 | 0.56
Kalarchian, 2009^132^ Fair | 12 (0) | 44 | Weight (kg) | 6.92 (7.09) | 97 | 9.22 (5.75) | 95 | 0.014
Kalarchian, 2009^132^ Fair | 6 (**) | 44 | Weight (kg) | 1.56 (6.70) | 97 | 4.76 (5.56) | 95 | 0.0003
Kalarchian, 2009^132^ Fair | 18 (6) | 44 | Weight (kg) | 11.77 (6.89) | 97 | 13.35 (5.36) | 95 | 0.077
Kalarchian, 2009^132^ Fair | 6 (**) | 44 | WC (cm) | 1.11 (8.08) | 97 | 4.94 (6.34) | 95 | 0.0003
Kalarchian, 2009^132^ Fair | 12 (0) | 44 | WC (cm) | 6.18 (10.34) | 97 | 9.59 (8.48) | 95 | 0.014
Kalavainen, 2007^133^ Fair | 6 (0) | 44 | BMI (kg/m^2^) | −0.80 (0.91) | 35 | 0.00 (1.06) | 35 | 0.003
Kalavainen, 2007^133^ Fair | 6 (0) | 44 | zBMI (BMI SDS) | −0.30 (0.15) | 35 | −0.20 (0.30) | 35 | 0.022
Kalavainen, 2007^133^ Fair | 6 (0) | 44 | Weight (kg) | 0.50 (1.80) | 35 | 1.80 (2.20) | 35 | NR
Kalavainen, 2007^133^ Fair | 6 (0) | 44 | WC (cm) | −0.70 (3.17) | 35 | 0.80 (3.62) | 35 | 0.062
Stark, 2011^160^ Fair | 6 (0) | 38 | BMI percentile | −2.10 (1.90) | 7 | 0.30 (2.00) | 10 | 0.03
Stark, 2011^160^ Fair | 12 (6) | 38 | BMI percentile | −1.10 (1.90) | 7 | 1.60 (2.70) | 9 | 0.04
Stark, 2011^160^ Fair | 6 (0) | 38 | zBMI (BMI SDS) | −0.49 (0.36) | 7 | 0.10 (0.32) | 10 | 0.003
Stark, 2011^160^ Fair | 12 (6) | 38 | zBMI (BMI SDS) | −0.37 (0.41) | 7 | 0.40 (0.49) | 9 | 0.005
Stark, 2011^160^ Fair | 6 (0) | 38 | Weight (kg) | −0.90 (2.30) | 7 | 1.80 (0.90) | 10 | 0.004
Stark, 2011^160^ Fair | 12 (6) | 38 | Weight (kg) | 0.60 (3.50) | 7 | 4.80 (1.50) | 9 | 0.005
Stark, 2011^160^ Fair | 12 (6) | 38 | Percent Obese | 1 (14.3) | 7 | 5 (55.6) | 9 | NR
Croker, 2012^124^ Fair | 6 (0) | 38 | BMI (kg/m^2^) | −0.36 (1.06) | 31 | −0.03 (1.07) | 27 | 0.17 | Age, baseline value
Croker, 2012^124^ Fair | 6 (0) | 38 | zBMI (BMI SDS) | −0.11 (0.16) | 31 | −0.10 (0.16) | 27 | NS | Age, baseline value
Croker, 2012^124^ Fair | 6 (0) | 38 | Weight (kg) | 0.79 (2.84) | 31 | 2.78 (2.85) | 27 | 0.002 | Age, baseline value
Croker, 2012^124^ Fair | 6 (0) | 38 | WC (cm) | −0.51 (3.23) | 31 | 0.18 (3.24) | 27 | 0.33 | Age, baseline value
DeBar, 2012^126^ Good | 12 (7) | 37 | BMI percentile | −1.90 (5.99) | 90 | −0.82 (2.94) | 83 | 0.067
DeBar, 2012^126^ Good | 6 (1) | 37 | BMI percentile | −1.29 (3.66) | 100 | −0.60 (2.65) | 95 | 0.067
DeBar, 2012^126^ Good | 6 (1) | 37 | zBMI (BMI SDS) | −0.12 (0.38) | 100 | −0.06 (0.36) | 95 | 0.012
DeBar, 2012^126^ Good | 12 (7) | 37 | zBMI (BMI SDS) | −0.15 (0.41) | 90 | −0.08 (0.36) | 83 | 0.012
DeBar, 2012^126^ Good | 6 (1) | 37 | Weight (kg) | 0.17 (15.67) | 100 | 1.63 (16.32) | 95 | 0.015
DeBar, 2012^126^ Good | 12 (7) | 37 | Weight (kg) | 2.22 (16.38) | 90 | 3.21 (16.33) | 83 | 0.015
Sacher, 2010^153^ Fair | 6 (3.75) | 36 | BMI (kg/m^2^) | −1.50 (3.52) | 37 | 0.60 (5.06) | 45 | <0.0001 | Baseline
Sacher, 2010^153^ Fair | 6 (3.75) | 36 | zBMI (BMI SDS) | −0.30 (0.51) | 37 | −0.01 (0.65) | 45 | <0.0001 | Baseline
Sacher, 2010^153^ Fair | 6 (3.75) | 36 | WC (z-score) | −0.36 (0.56) | 37 | 0.06 (0.62) | 45 | <0.0001 | Baseline
Sacher, 2010^153^ Fair | 6 (3.75) | 36 | WC (cm) | −4.10 (7.81) | 37 | 1.70 (8.60) | 45 | <0.0001 | Baseline
Nemet, 2005^144^ Fair | 12 (9) | 33 | BMI (kg/m^2^) | −1.60 (4.26) | 20 | 0.60 (5.52) | 20 | <0.05
Nemet, 2005^144^ Fair | 12 (9) | 33 | BMI percentile | −5.90 (2.86) | 20 | −1.10 (1.21) | 20 | <0.05
Nemet, 2005^144^ Fair | 12 (9) | 33 | Weight (kg) | 0.60 (16.67) | 20 | 5.20 (24.22) | 20 | <0.05
Stark, 2014^159^ Fair | 6 (0) | 30 | zBMI (BMI SDS) | −0.25 (0.25) | 11 | −0.07 (0.18) | 12 | 0.08
Stark, 2014^159^ Fair | 12 (6) | 30 | zBMI (BMI SDS) | −0.59 (0.75) | 11 | −0.03 (0.36) | 12 | 0.04
Stark, 2014^159^ Fair | 12 (6) | 30 | Weight (kg) | 2.30 (3.10) | 11 | 5.20 (2.60) | 12 | 0.03
Stark, 2014^159^ Fair | 6 (0) | 30 | Weight (kg) | 1.10 (2.40) | 11 | 1.90 (0.90) | 12 | 0.37
Bryant, 2011^120^ Fair | 12 (0) | 24 | zBMI (BMI SDS) | 0.03 (0.24) | 35 | −0.03 (0.27) | 35 | NR
Mellin, 1987^143^ Fair | 6 (3) | 24 | Weight (kg) | −1.40 (NR) | 34 | −1.05 (NR) | 29 | NR
Mellin, 1987^143^ Fair | 6 (3) | 24 | % excess of 50th percentile (% relative weight) | −6.2 (NR) | 34 | −5.2 (NR) | 29 | NR
Golley, 2007^130^ Fair | 6 (1) | 24 | zBMI (BMI SDS) | −0.22 (0.56) | 29 | NR (NR) | NR | NR
Golley, 2007^130^ Fair | 12 (7) | 24 | zBMI (BMI SDS) | −0.24 (0.43) | 31 | −0.13 (0.40) | 31 | 0.76
Golley, 2007^130^ Fair | 6 (1) | 24 | WC (z-score) | −0.27 (0.70) | 29 | NR (NR) | NR | NR
Golley, 2007^130^ Fair | 12 (7) | 24 | WC (z-score) | −0.31 (0.53) | 31 | −0.02 (0.58) | 31 | 0.03
Hofsteenge, 2014^131^ Fair | 6 (0) | 17 | BMI (kg/m^2^) | −0.50 (4.65) | 53 | 0.60 (5.20) | 44 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 6 (0) | 17 | zBMI (BMI SDS) | −0.12 (0.46) | 53 | 0.02 (0.53) | 44 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 6 (0) | 17 | Weight (kg) | 1.20 (18.06) | 53 | 2.90 (18.65) | 44 | NSD | Age, sex, ethnicity
Hofsteenge, 2014^131^ Fair | 6 (0) | 17 | WC (cm) | 0.30 (12.30) | 53 | 3.30 (12.26) | 44 | NSD | Age, sex, ethnicity
Gerards, 2015^129^ Fair | 12 (8.5) | 17 | zBMI (BMI SDS) | 0.05 (0.26) | 35 | −0.08 (0.27) | 32 | NSD
Gerards, 2015^129^ Fair | 12 (8.5) | 17 | WC (cm) | 3.88 (2.99) | 35 | 3.44 (3.46) | 32 | NSD
Nowicka, 2008^146^ Fair | 12 (0) | 16 | BMI (kg/m^2^) | 0.00 (4.45) | 65 | 1.20 (4.75) | 23 | NR
Nowicka, 2008^146^ Fair | 12 (0) | 16 | zBMI (BMI SDS) | −0.06 (0.46) | 65 | 0.09 (0.53) | 23 | NS | Age and sex
Nowicka, 2008^146^ Fair | 12 (0) | 16 | Weight (kg) | 3.10 (18.80) | 65 | 8.10 (19.36) | 23 | NR
Boudreau, 2013^117^ Fair | 6 (0) | 11 | zBMI (BMI SDS) | −0.03 (0.14) | 13 | −0.05 (0.08) | 10 | 0.31 | Caregiver education and maternal BMI
Norman, 2015^145^ Fair | 8 (**) | 8 (**) | BMI (kg/m^2^) | 0.2 (4.1) | 53 | 0.3 (3.9) | 53 | NR
Norman, 2015^145^ Fair | 12 (0) | 8 | BMI (kg/m^2^) | 0.2 (4.2) | 53 | 0.4 (4.11) | 53 | NR
Norman, 2015^145^ Fair | 8 (**) | 8 | zBMI (BMI SDS) | −0.1 (0.36) | 53 | −0.1 (0.3) | 53 | NR
Norman, 2015^145^ Fair | 12 (0) | 8 | zBMI (BMI SDS) | −0.1 (0.36) | 53 | −0.1 (0.44) | 53 | NR
Norman, 2015^145^ Fair | 12 (0) | 8 | WC (cm) | −0.1 (11.48) | 53 | −0.1 (11.21) | 53 | NR
Raynor, 2012a^148^ Fair | 12 (6) | 6 | zBMI (BMI SDS) | −0.10 (NR) | 35 | −0.13 (NR) | 33 | NSD
Raynor, 2012a^148^ Fair | 6 (0) | 6 | zBMI (BMI SDS) | −0.08 (NR) | 35 | −0.11 (NR) | 33 | NSD
Raynor, 2012b^148^ Fair | 12 (6) | 6 | zBMI (BMI SDS) | −0.22 (NR) | 26 | −0.22 (NR) | 29 | NR
Raynor, 2012b^148^ Fair | 6 (0) | 6 | zBMI (BMI SDS) | −0.16 (NR) | 26 | −0.13 (NR) | 29 | NR
Taylor, 2015^165^ Good | 12 (**) | 5 | BMI (kg/m^2^) | 0.10 (2.66) | 91 | 0.40 (2.11) | 90 | NR
Taylor, 2015^165^ Good | 24 (**) | 5 | BMI (kg/m^2^) | 0.80 (2.98) | 89 | 1.20 (2.29) | 92 | NR, significant | BL value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention condition
Taylor, 2015^165^ Good | 12 (**) | 5 | zBMI (BMI SDS) | −0.19 (0.52) | 91 | −0.08 (0.43) | 90 | NR
Taylor, 2015^165^ Good | 24 (**) | 5 | zBMI (BMI SDS) | −0.27 (0.53) | 89 | −0.12 (0.44) | 92 | NR, significant | BL value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention condition
Taylor, 2015^165^ Good | 12 (**) | 5 | Weight (kg) | 2.90 (9.34) | 91 | 3.50 (7.45) | 90 | NR
Taylor, 2015^165^ Good | 24 (**) | 5 | Weight (kg) | 7.50 (10.42) | 89 | 8.10 (8.02) | 92 | NR | NR
Taylor, 2015^165^ Good | 12 (**) | 5 | WC (cm) | 1.40 (10.15) | 91 | 2.90 (7.87) | 90 | NR
Taylor, 2015^165^ Good | 24 (**) | 5 | WC (cm) | 4.90 (11.03) | 89 | 6.50 (8.18) | 92 | NR, significant | BL value, age, sex, feedback condition, and interactions btwn time and feedback condition and time and intervention condition
Kong, 2013^136^ Fair | 9 (0) | 4 | Weight (kg) | 1.70 (4.05) | 28 | 2.50 (4.28) | 23 | 0.12
Kong, 2013^136^ Fair | 9 (0) | 4 | WC (cm) | 0.00 (3.78) | 28 | 1.70 (3.06) | 23 | 0.04
Stettler, 2014^161^ Fair | 12 (0) | 4 | BMI (kg/m^2^) | 0.60 (2.65) | 46 | 1.70 (3.31) | 24 | 0.04 | Cluster design
Stettler, 2014^161^ Fair | 12 (0) | 4 | zBMI (BMI SDS) | −0.06 (0.50) | 46 | 0.10 (0.41) | 24 | 0.02 | Cluster design
Stettler, 2014^161^ Fair | 12 (0) | 4 | Weight (kg) | 5.50 (10.01) | 46 | 8.60 (13.75) | 24 | 0.04 | Cluster design
Stettler, 2014^161^ Fair | 12 (0) | 4 | Percent Obese | 15 (15) | 46 | 9 (38) | 24 | 0.05 | Cluster design
Saelens, 2002^154^ Fair | 7 (3) | 4 | BMI (kg/m^2^) | 0.10 (4.09) | 18 | 1.40 (3.50) | 19 | NR
Saelens, 2002^154^ Fair | 7 (3) | 4 | zBMI (BMI SDS) | −0.05 (0.22) | 18 | 0.06 (0.17) | 19 | <0.04
Saelens, 2002^154^ Fair | 7 (3) | 4 | Weight (kg) | 2.00 (15.06) | 18 | 5.30 (14.08) | 19 | NR
Saelens, 2002^154^ Fair | 7 (3) | 4 | % excess of 50th percentile (%) | −2.40 (22.83) | 18 | 4.10 (18.90) | 19 | NR
Broccoli, 2016^119^ Good | 12 (9) | 4 | BMI (kg/m^2^) | 0.49 (1.36) | 187 | 0.79 (1.25) | 185 | 0.007
Broccoli, 2016^119^ Good | 12 (9) | 4 | zBMI (BMI SDS) | −0.11 (0.42) | 187 | 0.01 (0.38) | 185 | NR, significant
Broccoli, 2016^119^ Good | 12 (9) | 4 | % overweight or obese | 137 (73.3) | 187 | 143 (77.3) | 185 | 0.169
O’Connor, 2013^147^ Fair | 7 (0) | 4 | zBMI (BMI SDS) | NR (NR) | 20 | NR (NR) | 20 | 0.86 | LS Mean adjusted for child’s age and parent BMI at BL
Sherwood, 2015^157^ Fair | 6 (0) | 3 | BMI percentile (%) | −0.35 (9.66) | 26 | −1.81 (15.04) | 29 | 0.64
Sherwood, 2015^157^ Fair | 6 (0) | 3 | zBMI (BMI SDS) | −0.02 (0.36) | 26 | −0.01 (0.54) | 29 | 0.89
Taveras, 2011^163^ Good | 12 (0) | 3 | BMI (kg/m^2^) | 0.31 (1.43) | 253 | 0.49 (1.39) | 192 | 0.15 | Age, sex, race/ethnicity, parent education and overweight/ obesity status at BL, household income, and time elapse from BL to followup visit
Taveras, 2011^163^ Good | 12 (0) | 3 | zBMI (BMI SDS) | NR (NR) | NR | NR (NR) | NR | 0.28 | Age, sex, race/ethnicity, parent education and overweight/obesity status at BL, household income, and time elapse from BL to followup visit
Looney, 2014^138^ Fair | 6 (0) | 3 | zBMI (BMI SDS) | −0.16 (0.48) | 7 | −0.07 (0.61) | 8 | NS
Resnicow, 2015^152^ Fair | 24 (0) | 3 | BMI percentile | −4.90 (15.18) | 154 | −1.80 (13.79) | 158 | 0.02 | Age, race, gender, BL BMI, household income, parent BMI, provider age, and practice effects
Wake, 2013^169^ Good | 12 (0) | 3 | BMI (kg/m^2^) | 0.90 (3.39) | 56 | 0.80 (4.19) | 49 | 0.7 | Child’s age and sex at randomization, neighborhood socioeconomic disadvantage score, raw BL BMI and BL value of outcome measure where available
Wake, 2013^169^ Good | 12 (0) | 3 | zBMI (BMI SDS) | −0.20 (0.50) | 56 | −0.10 (0.36) | 49 | 0.2 | Child’s age and sex at randomization, neighborhood socioeconomic disadvantage score, raw BL BMI and BL value of outcome measure where available
Wake, 2013^169^ Good | 12 (0) | 3 | WC (cm) | NR (NR) | 56 | NR (NR) | 49 | 0.1 | Child’s age and sex at randomization, neighborhood socioeconomic disadvantage score, raw BL BMI and BL value of outcome measure where available
Van Grieken, 2013^166^ Fair | 24 (12) | 2 | BMI (kg/m^2^) | 1.37 (1.53) | 277 | 1.44 (1.71) | 230 | 0.46 | Age, cluster
Van Grieken, 2013^166^ Fair | 24 (12) | 2 | zBMI (BMI SDS) | NR (NR) | NR | NR (NR) | NR | 0.07 | Age, cluster
Van Grieken, 2013^166^ Fair | 24 (12) | 2 | WC (cm) | 7.20 (5.49) | 262 | 7.33 (5.30) | 222 | 0.506 | Age, cluster
Van Grieken, 2013^166^ Fair | 24 (12) | 2 | % overweight or obese | 209 (75.4) | 277 | 170 (73.7) | 230 | NR
Van Grieken, 2013^166^ Fair | 24 (12) | 2 | % obese | 40 (14.4) | 277 | 25 (11.0) | 230 | NR
Taveras, 2015^164^ Good | 12 (0) | 1 | BMI (kg/m^2^) | 0.80 (4.41) | 164 | 1.20 (4.41) | 171 | NR | Parent age and country of birth and child race/ethnicity, sex, and age at visit
Taveras, 2015^164^ Good | 12 (0) | 1 | zBMI (BMI SDS) | −0.09 (0.33) | 164 | −0.04 (0.32) | 171 | NR | parent age and country of birth and child race/ethnicity, sex, and age at visit
McCallum, 2007^142^ Good | 15 (12) | 1 | BMI (kg/m^2^) | 1.20 (2.76) | 70 | 1.20 (2.16) | 76 | 1 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 9 (6) | 1 | BMI (kg/m^2^) | 0.50 (2.42) | 73 | 0.80 (2.03) | 80 | 0.25 | SES, age, sex, baseline BMI
McCallum, 2007^142^ Good | 9 (6) | 1 | zBMI (BMI SDS) | −0.04 (0.58) | 73 | 0.03 (0.54) | 80 | 0.12 | SES, baseline zBMI
McCallum, 2007^142^ Good | 15 (12) | 1 | zBMI (BMI SDS) | 0.00 (0.61) | 70 | 0.02 (0.55) | 76 | 0.62 | SES, baseline zBMI
Wake, 2009^168^ Good | 6 (3) | 1 | BMI (kg/m^2^) | 0.30 (2.46) | 132 | 0.30 (2.07) | 118 | 0.4 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL
Wake, 2009^168^ Good | 12 (9) | 1 | BMI (kg/m^2^) | 0.60 (2.59) | 127 | 0.70 (2.19) | 115 | 0.5 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL
Wake, 2009^168^ Good | 6 (3) | 1 | WC (cm) | NR (NR) | 131 | NR (NR) | 117 | 0.8 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL
Wake, 2009^168^ Good | 12 (9) | 1 | WC (cm) | NR (NR) | 125 | NR (NR) | 114 | 0.8 | Social disadvantage index, age, sex, BL score for outcome, raw BMI at BL

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; DIo=basal disposition index; est=estimated; HbA1c=glycated hemoglobin; HOMA=homeostatic model assessment; hrs=hours; IG=intervention group; NR=not reported; NS=not significant; NSD=no significant difference; SD=standard deviation; SDS=standardized deviation score; tx=treatment; WC=waist circumference; zBMI=BMI z score.

Appendix D Table 4 Change in Mean zBMI in Lifestyle-Based Weight Loss Trials, With Columns Showing Mean ± 1 Standard Deviation (KQ 4)

Age category | Author, Year Quality | Intervention Group, zBMI | | | | | Control Group, zBMI
Age category | Author, Year Quality | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD
52+ hours
Wide Age Range | Lison, 2012^137^ Fair | 2.10 | −0.16 | NR | NR | NR | 2.23 | −0.01 | NR | NR | NR
Wide Age Range | Weigel, 2008^170^ Fair | 2.24 | −0.34 | 0.48 | −0.82 | 0.14 | 2.48 | 0.26 | 0.57 | −0.31 | 0.83
Wide Age Range | Savoye, 2014^155^ Fair | 2.20 | −0.05 | 0.13 | −0.18 | 0.08 | 2.30 | 0.04 | 0.12 | −0.08 | 0.16
Wide Age Range | Reinehr, 2006^149^ Fair | 2.40 | −0.30 | 0.35 | −0.65 | 0.05 | 2.30 | 0.00 | 0.41 | −0.41 | 0.41
Wide Age Range | Reinehr, 2009^150^ Fair | 2.48 | −0.22 | 0.35 | −0.57 | 0.13 | 2.43 | 0.15 | 0.17 | −0.02 | 0.32
Wide Age Range | Reinehr, 2010^151^ Fair | 1.73 | −0.26 | 0.22 | −0.48 | −0.04 | 1.59 | 0.05 | 0.19 | −0.14 | 0.24
26–51 hours
Wide Age Range | Vos, 2011^167^ Fair | 4.20 | −0.40 | 1.29 | −1.69 | 0.89 | 4.30 | −0.10 | 1.12 | −1.22 | 1.02
Preschool | Stark, 2014^159^ Fair | 2.50 | −0.59 | 0.75 | −1.34 | 0.16 | 2.40 | −0.03 | 0.36 | −0.39 | 0.33
Preschool | Stark, 2011^160^ Fair | NR | −0.37 | 0.41 | −0.78 | 0.04 | NR | 0.40 | 0.49 | −0.09 | 0.89
Elementary | Croker, 2012^124^ Fair | 3.10 | −0.11 | 0.16 | −0.27 | 0.05 | 3.30 | −0.10 | 0.16 | −0.26 | 0.06
Elementary | Kalavainen, 2007^133^ Fair | 2.60 | −0.30 | 0.15 | −0.45 | −0.15 | 2.50 | −0.20 | 0.30 | −0.50 | 0.10
Elementary | Sacher, 2010^153^ Fair | 2.77 | −0.30 | 0.51 | −0.81 | 0.21 | 2.76 | −0.01 | 0.65 | −0.66 | 0.64
Adolescent | DeBar, 2012^126^ Good | 2.00 | −0.15 | 0.41 | −0.56 | 0.26 | 2.00 | −0.08 | 0.36 | −0.44 | 0.28
6–25 hours
Wide Age Range | Bryant, 2011^120^ Fair | 2.86 | 0.03 | 0.24 | −0.21 | 0.27 | 3.11 | −0.03 | 0.27 | −0.30 | 0.24
Wide Age Range | Hofsteenge, 2014^131^ Fair | 2.93 | −0.12 | 0.46 | −0.58 | 0.34 | 2.93 | 0.02 | 0.53 | −0.51 | 0.55
Wide Age Range | Norman, 2015^145^ Fair | 2.1 | −0.1 | 0.36 | −0.46 | 0.26 | 2.1 | −0.1 | 0.44 | −0.54 | 0.34
Elementary | Gerards, 2015^129^ Fair | 1.82 | 0.05 | 0.26 | −0.21 | 0.31 | 1.87 | −0.08 | 0.27 | −0.35 | 0.19
Elementary | Golley, 2007^130^ Fair | 2.74 | −0.24 | 0.43 | −0.67 | 0.19 | 2.75 | −0.13 | 0.40 | −0.53 | 0.27
Elementary | Boudreau, 2013^117^ Fair | 2.00 | −0.03 | 0.14 | −0.17 | 0.11 | 2.20 | −0.05 | 0.08 | −0.13 | 0.03
Elementary | Taylor, 2015^165^ Good | 1.69 | −0.19 | 0.52 | −0.71 | 0.33 | 1.54 | −0.08 | 0.43 | −0.51 | 0.35
Elementary | Raynor, 2012a^148^ Fair | 2.15 | −0.10 | NR | NR | NR | 2.45 | −0.13 | NR | NR | NR
Elementary | Raynor, 2012b^148^ Fair | 2.25 | −0.22 | NR | NR | NR | 2.27 | −0.22 | NR | NR | NR
Adolescent | Nowicka, 2008^146^ Fair | 3.27 | −0.06 | 0.46 | −0.52 | 0.40 | 3.21 | 0.09 | 0.53 | −0.44 | 0.62
0–5 hours
Preschool | Taveras, 2011^163^ Good | 1.88 | NR | NR | NR | NR | 1.82 | NR | NR | NR | NR
Elementary | Broccoli, 2016^119^ Good | 1.35 | −0.11 | 0.42 | −0.53 | 0.31 | 1.35 | 0.01 | 0.38 | −0.37 | 0.39
Elementary | Sherwood, 2015^157^ Fair | 1.01 | −0.02 | 0.37 | −0.39 | 0.35 | 0.86 | −0.01 | 0.54 | −0.55 | 0.53
Elementary | Stettler, 2014^161^ Fair | 1.22 | −0.05 | 0.54 | −0.59 | 0.49 | 1.34 | 0.10 | 0.41 | −0.31 | 0.51
Elementary | Looney, 2014^138^ Fair | 2.45 | −0.16 | 0.48 | −0.64 | 0.32 | 2.21 | −0.07 | 0.61 | −0.68 | 0.54
Elementary | Wake, 2013^169^ Good | 2.20 | −0.20 | 0.50 | −0.70 | 0.30 | 2.10 | −0.10 | 0.36 | −0.46 | 0.26
Elementary | Taveras, 2015^164^ Good | 2.08 | −0.09 | 0.33 | −0.42 | 0.24 | 2.05 | −0.04 | 0.32 | −0.36 | 0.28
Elementary | McCallum, 2007^142^ Good | 2.00 | 0.00 | 0.61 | −0.61 | 0.61 | 1.90 | 0.02 | 0.55 | −0.53 | 0.57
Adolescent | Saelens, 2002^154^ Fair | 2.06 | −0.05 | 0.22 | −0.27 | 0.17 | 2.09 | 0.06 | 0.17 | −0.11 | 0.23

Abbreviations: BL=baseline; SD=standard deviation.

Appendix D Table 5 Reported or Calculated Change in Mean Weight (lb) in Lifestyle-Based Weight Loss Trials, With Columns Showing Mean ± 1 Standard Deviation (KQ 4)

Age category | Author, Year Quality | Follow-up (months) | Mean age (years) | BL BMI | Intervention Group, lbs | | | | | Control Group, lbs
Age category | Author, Year Quality | Follow-up (months) | Mean age (years) | BL BMI | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD
52+ hours
Wide Age Range | Lison, 2012^137*^ Fair | 6 | 11.9 | 29.1 | 162.9 | 2.6 | NR | NR | NR | 152.4 | 17.2 | NR | NR | NR
Wide Age Range | Weigel, 2008^170†^ Fair | 12 | 11.2 | 28.6 | 127.1 | −7.0 | 14.2 | −21.2 | 7.2 | 139.7 | 13.0 | 18.0 | −5.0 | 31.0
Wide Age Range | Savoye, 2007^156*^ Fair | 12 | 12.1 | 36 | 191.6 | 0.7 | 19.6 | −18.9 | 20.3 | 200.8 | 17.0 | 21.9 | −4.9 | 38.9
Wide Age Range | Savoye, 2014^155*^ Fair | 6 | 12.9 | 33.3 | 184.3 | 1.3 | 10.4 | −9.1 | 11.7 | 202.6 | 8.1 | 10.6 | −2.5 | 18.7
Wide Age Range | Reinehr, 2006^149†^ Fair | 12 | 10.4 | 26.9 | 117.3 | 0.4 | 18.3 | −17.9 | 18.7 | 113.4 | 8.7 | 16.3 | −7.6 | 25.0
Wide Age Range | Reinehr, 2010^151†^ Fair | 6 | 11.5 | 23.8 | 116.5 | −4.1 | 4.9 | −9.0 | 0.8 | 112.1 | 3.7 | 4.8 | −1.1 | 8.5
26–51 hours
Wide Age Range | Nemet, 2005^144*^ Fair | 12 | 11.1 | 28.2 | 130.1 | 1.3 | 36.7 | −35.4 | 38.0 | 139.6 | 11.5 | 53.3 | −41.8 | 64.8
Wide Age Range | Vos, 2011^167^ Fair | 12 | 13.2 | 32.5 | NR§ | NR§ | NR§ | NR§ | NR§ | NR§ | NR§ | NR§ | NR§ | NR§
Preschool | Stark, 2014^159*^ Fair | 12 | 4.5 | NR | 58.6 | 5.1 | 6.8 | −1.7 | 11.9 | 57.5 | 11.5 | 5.7 | 5.8 | 17.2
Preschool | Stark, 2011^160*^ Fair | 12 | 4.1 | NR | NR | 1.3 | 7.7 | −6.4 | 9.0 | NR | 10.6 | 3.3 | 7.3 | 13.9
Elementary | Croker, 2012^124*^ Fair | 6 | 10.3 | 30.6 | 155.9 | 1.7 | 6.3 | −4.6 | 8.0 | 144.2 | 6.1 | 6.3 | −0.2 | 12.4
Elementary | Kalavainen, 2007^133*^ Fair | 6 | 8.1 | 23.2 | 94.9 | 1.1 | 4.0 | −2.9 | 5.1 | 89.0 | 4.0 | 4.8 | −0.8 | 8.8
Elementary | Sacher, 2010^153†^ Fair | 6 | 10.3 | 27.2 | 116.7 | −6.4 | 15.1 | −21.5 | 8.7 | 116.3 | 2.6 | 21.7 | −19.1 | 24.3
Elementary | Kalarchian, 2009^132*^ Fair | 12 | 10.2 | 32.1 | 154.5 | 15.2 | 15.6 | −0.4 | 30.8 | 160.2 | 20.3 | 12.7 | 7.6 | 33.0
Adolescent | DeBar, 2012^126*^ Good | 12 | 14.1 | 31.9 | 189.7 | 4.9 | 36.1 | −31.2 | 41.0 | 186.4 | 7.1 | 36.0 | −28.9 | 43.1
6–25 hours
Wide Age Range | Hofsteenge, 2014^131*^ Fair | 6 | 14.5 | 33.4 | 208.5 | 2.6 | 39.8 | −37.2 | 42.4 | 203.0 | 6.4 | 41.1 | −34.7 | 47.5
Wide Age Range | Norman, 2015^145†^ Fair | 12 | 11.9 | 29.3 | 147.3 | 1.1 | 20.9 | −19.8 | 22.0 | 143.8 | 2.0 | 20.5 | −18.5 | 22.5
Elementary | Boudreau, 2013^117‡^ Fair | 6 | 10.3 | NR | 111.2 | 6.6 | NR | NR | NR | 119.8 | 5.9 | NR | NR | NR
Elementary | Raynor, 2012a^148‡^ Fair | 12 | 7.2 | NR | 75.2 | 10.0 | NR | NR | NR | 84.1 | 9.7 | NR | NR | NR
Elementary | Raynor, 2012b^148‡^ Fair | 12 | 7.1 | NR | 76.6 | 7.0 | NR | NR | NR | 77.3 | 6.8 | NR | NR | NR
Adolescent | Nowicka, 2008^146*^ Fair | 12 | 14.7 | 34.5 | 215.4 | 6.8 | 41.4 | −34.6 | 48.2 | 212.1 | 17.8 | 42.6 | −24.8 | 60.4
Adolescent | Mellin, 1987^143*^ Fair | 6 | 15.6 | NR | 174.4 | −3.1 | NR | NR | NR | 169.4 | −2.3 | NR | NR | NR
0–5 hours
Preschool | Taveras, 2011^163†^ Good | 12 | 4.9 | 19.2 | 49.4 | 0.8 | 3.7 | −2.9 | 4.5 | 49.1 | 1.3 | 3.6 | −2.3 | 4.9
Preschool | Van Grieken, 2013^166†^ Fair | 24 | 5.8 | 18.13 | 51.3 | 3.9 | 4.3 | −0.4 | 8.2 | 51.1 | 4.1 | 4.8 | −0.7 | 8.9
Elementary | Resnicow, 2015^152‡^ Fair | 24 | 5.1 | NR | 50.6 | 12.1 | NR | NR | NR | 50.0 | 14.1 | NR | NR | NR
Elementary | Broccoli, 2016^119†^ Good | 12 | 6.6 | 18.3 | 57.0 | 1.5 | 4.2 | −2.7 | 5.7 | 56.8 | 2.5 | 3.9 | −1.4 | 6.4
Elementary | O’Connor, 2013^147^ Fair | 7 | 6.8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Elementary | Stettler, 2014^161^ Fair | 12 | 10.8 | 21.6 | 103.1 | 12.1 | 22.0 | −9.9 | 34.1 | 108.3 | 18.9 | 30.3 | −11.4 | 49.2
Elementary | Looney, 2014^138‡^ Fair | 6 | 8 | NR | 96.9 | 0.9 | NR | NR | NR | 87.6 | 4.6 | NR | NR | NR
Elementary | Wake, 2009^168†^ Good | 12 | 7.5 | 20.2 | 69.4 | 2.1 | 8.9 | −6.8 | 11.0 | 69.7 | 2.4 | 7.5 | −5.1 | 9.9
Elementary | Wake, 2013^169†^ Good | 12 | 7.3 | 22.5 | 74.7 | 3.0 | 11.3 | −8.3 | 14.3 | 76.4 | 2.7 | 14.0 | −11.3 | 16.7
Elementary | Taveras, 2015^164†^ Good | 12 | 9.8 | 25.8 | 108.4 | 3.3 | 18.4 | −15.1 | 21.7 | 107.1 | 5.0 | 18.4 | −13.4 | 23.4
Elementary | McCallum, 2007^142†^ Good | 15 | 7.4 | 20.3 | 69.3 | 4.1 | 9.3 | −5.2 | 13.4 | 67.6 | 4.1 | 7.3 | −3.2 | 11.4
Adolescent | Saelens, 2002^154*^ Fair | 7 | 14.2 | 30.7 | 188.3 | 4.4 | 33.2 | −28.8 | 37.6 | 177.3 | 11.7 | 31.0 | −19.3 | 42.7
Adolescent | Kong, 2013^136*^ Fair | 9 | 14.8 | NR | 172.9 | 3.7 | 8.9 | −5.2 | 12.6 | 172.0 | 5.5 | 9.4 | −3.9 | 14.9

* Study-reported weight change.

† Calculated weight change.

‡ Calculated weight change using zBMI.

Abbreviations: BL=baseline; BMI=body mass index; SD=standard deviation.

Appendix D Table 6 Blood Pressure Outcomes in Included Lifestyle-Based Weight Loss Trials (KQ 4)

Outcome (unit) | Author, Year & Quality | Est hrs of contact | Planned followup (months since tx ended) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
SBP (mm Hg) | Weigel, 2008^170^ Fair | 114 | 12 (0) | −2.0 (10.5) | 36 | 5.0 (9.2) | 30 | <0.01
SBP (mm Hg) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −2.0 (12.3) | 105 | −0.4 (14.0) | 69 | 0.45 | BL outcome
SBP (mm Hg) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −6.2 (9.3) | 31 | −0.7 (8.5) | 27 | 0.005 | BL outcome and body weight, HbA1c, HOMA, DIo
SBP (mm Hg) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −4.3 (14.4) | 174 | 5.3 (16.2) | 37 | 0.002
SBP (mm Hg) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | −7.0 (16.1) | 288 | 2.0 (14.5) | 186 | <0.001 | Age, sex, BL zBMI, and pubertal stage
SBP (mm Hg) | Reinehr, 2010^151^ Fair | 67 | 6 (0) | −7.0 (4.0) | 34 | −1.0 (5.0) | 32 | <0.001
SBP (mm Hg) | Vos, 2011^167^ Fair | 45 | 12 (**) | −6.6 (18.1) | 32 | −4.3 (19.0) | 35 | NSD | BL differences
SBP (mm Hg) | Kalarchian, 2009^132^ Fair | 44 | 12 (0) | −4.9 (17.6) | 97 | 0.4 (18.8) | 95 | 0.045
SBP (mm Hg) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | −0.9 (6.7) | 34 | 0.0 (5.0) | 35 | 0.503
SBP (mm Hg) | Sacher, 2010^153^ Fair | 36 | 6 (3.75) | −9.6 (12.1) | 36 | −8.2 (10.6) | 45 | 0.7 | Baseline
SBP (mm Hg) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.49
SBP (mm Hg) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | −1.0 (13.5) | 53 | −2.0 (12.5) | 44 | NR | Age, sex, ethnicity
SBP (mm Hg) | Norman, 2015^145^ Fair | 8 | 12 *0) | 2.4 (11.75) | 53 | −1.2 (11.55) | 53 | NR
DBP (mm Hg) | Weigel, 2008^170^ Fair | 114 | 12 (0) | −4.0 (9.2) | 36 | 3.0 (9.6) | 30 | NS
DBP (mm Hg) | Savoye, 2007^156^ Fair | 82 | 12 (0) | 1.4 (11.5) | 105 | 2.8 (13.6) | 69 | 0.47 | BL outcome
DBP (mm Hg) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −0.9 (23.6) | 31 | 8.3 (26.2) | 27 | 0.09 | BL outcome and body weight, HbA1c, HOMA, DIo
DBP (mm Hg) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −3.2 (10.5) | 174 | −1.2 (9.8) | 37 | 0.467
DBP (mm Hg) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | −2.0 (12.0) | 288 | 3.0 (11.5) | 186 | <0.001 | Age, sex, BL zBMI, and pubertal stage
DBP (mm Hg) | Reinehr, 2010^151^ Fair | 67 | 6 (0) | −6.0 (4.0) | 34 | −2.0 (7.0) | 32 | 0.003
DBP (mm Hg) | Vos, 2011^167^ Fair | 45 | 12 (**) | −7.3 (13.6) | 32 | −5.7 (13.9) | 35 | NSD | BL differences
DBP (mm Hg) | Kalarchian, 2009^132^ Fair | 44 | 12 (0) | −3.0 (14.2) | 97 | 0.0 (17.5) | 95 | 0.2
DBP (mm Hg) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | 0.2 (4.3) | 34 | −0.7 (6.5) | 35 | 0.489
DBP (mm Hg) | Sacher, 2010^153^ Fair | 36 | 6 (3.75) | −5.1 (7.9) | 36 | −2.2 (7.8) | 45 | 0.07 | Baseline
DBP (mm Hg) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.82
DBP (mm Hg) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | −1.0 (8.0) | 53 | 0.0 (7.5) | 44 | NR | Age, sex, ethnicity
DBP (mm Hg) | Norman, 2015^145^ Fair | 8 | 12 (0) | −1.7 (10.48) | 53 | −0.2 (10.44) | 53 | NR

Abbreviations: BL=baseline; CG=control group; DBP=diastolic blood pressure; DIo=basal disposition index; est=estimated; HbA1c=glycated hemoglobin; HOMA=homeostatic model assessment; hrs=hours; IG=intervention group; NR=not reported; NSD=no significant difference; SBP=systolic blood pressure; SD=standard deviation; tx=treatment; zBMI=body mass index z score.

Appendix D Table 7 Glucose Outcomes in Included Lifestyle-Based Weight Loss Trials (KQ 4)

Outcome (unit) | Author, Year & Quality | Est hrs of contact | Planned followup (months since tx ended) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
FPG (mg/dL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −3.4 (8.9) | 105 | −1.8 (10.8) | 69 | 0.3 | BL outcome
FPG (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −0.5 (8.0) | 31 | 2.5 (9.9) | 27 | 0.16 | BL outcome and body weight, HbA1c, HOMA, DIo
FPG (mg/dL) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −0.6 (6.5) | 174 | 1.0 (6.6) | 37 | 0.328
FPG (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | 1.8 (7.2) | 288 | 1.8 (7.2) | 186 | 0.318 | Age, sex, BL zBMI, and pubertal stage
FPG (mg/dL) | Vos, 2011^167^ Fair | 45 | 12 (**) | −3.6 (8.7) | 32 | 0.0 (14.4) | 35 | NSD | BL differences
FPG (mg/dL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | 0.0 (5.4) | 34 | 1.8 (5.4) | 34 | 0.145
FPG (mg/dL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.88
FPG (mg/dL) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | 0.0 (7.2) | 53 | 1.8 (7.2) | 44 | NR | Age, sex, ethnicity
FPG (mg/dL) | Norman, 2015^145^ Fair | 8 | 12 (0) | −2.1 (7.35) | 53 | −2.9 (7.45) | 53 | NR
FPG (mg/dL) | Kong, 2013^136^ Fair | 4 | 9 (0) | 5.4 (7.3) | 28 | 1.8 (6.6) | 23 | 0.04
2-hr OGTT (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −27.2 (25.3) | 31 | −10.1 (25.8) | 27 | 0.005 | BL outcome and body weight, HbA1c, HOMA, DIo
2-hr OGTT (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | −9.0 (24.4) | 288 | 3.6 (25.2) | 186 | <0.001 | Age, sex, BL zBMI, and pubertal stage
HOMA^*^ | Savoye, 2007^156^ Fair | 82 | 12 (0) | −1.5 (2.4) | 105 | 0.9 (4.5) | 69 | <0.001 | BL outcome
HOMA^*^ | Savoye, 2014^155^ Fair | 78 | 6 (0) | −1.2 (4.2) | 31 | 1.4 (5.7) | 27 | 0.03 | BL outcome and body weight, HbA1c, HOMA, DIo
HOMA^*^ | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −0.3 (2.8) | 174 | 0.9 (3.1) | 37 | 0.012
HOMA^*^ | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | −0.4 (1.1) | 34 | 0.1 (1.2) | 34 | 0.113
HOMA^*^ | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | 0.1 (2.5) | 53 | 0.0 (2.7) | 44 | NR | Age, sex, ethnicity
HOMA^*^ | Kong, 2013^136^ Fair | 4 | 9 (0) | 0.0 (95% CI, −0.6 to 1.1)^†^ | 28 | 0.7 (95% CI, −0.7 to 2.1) | 23 | 1
Insulin (μIU/mL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −6.1 (31.6) | 105 | 4.5 (19.9) | 69 | <0.001 | BL outcome
Insulin (μIU/mL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −4.9 (17.5) | 31 | 5.2 (22.0) | 27 | 0.03 | BL outcome and body weight, HbA1c, HOMA, DIo
Insulin (μIU/mL) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −1.1 (12.4) | 174 | 3.3 (13.4) | 37 | 0.008
Insulin (μIU/mL) | Vos, 2011^167^ Fair | 45 | 12 (**) | 1.0 (20.0) | 32 | 3.9 (15.9) | 35 | 0.05 | BL differences
Insulin (μIU/mL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | −1.6 (4.5) | 34 | 0.0 (4.6) | 34 | 0.142
Insulin (μIU/mL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.84
Insulin (μIU/mL) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | 2.0 (59.0) | 53 | −1.0 (69.4) | 44 | NR | Age, sex, ethnicity
Insulin (μIU/mL) | Kong, 2013^136^ Fair | 4 | 9 (0) | −1.45 (−3.43 to 4.95)^†^ | 28 | 0.20 (−0.28 to 3.60)^†^ | 23 | 0.59
Diabetes | Savoye, 2014^155^ Fair | 78 | 6 (0) | 0 (0)^‡^ | 38 | 0 (0) ^‡^ | 37 | NR
Diabetes | Love-Osborne, 2014^139^ Fair | 3 | 8 (0) | 0 (0) ^‡^ | 82 | 2 (2.4) ^‡^ | 83 | NR

* HOMA-IR (insulin resistance): insulin [μIU/mL] × glucose [mmol/L]/22.5.

† Median change from baseline (95% CI).

‡ Number (%).

Abbreviations: CG=control group; CI=confidence interval; hr=hour(s); IG=intervention group; IU=international unit; FPG=fasting plasma glucose; HOMA=homeostatic model assessment; NR=not reported; OGTT=oral glucose tolerance test; SD=standard deviation; tx=treatment.

Appendix D Table 8 Lipid Outcomes in Included Lifestyle-Based Weight Loss Trials (KQ 4)

Outcome (unit) | Author, Year & Quality | Est hrs of contact | Planned followup (months since tx ended) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
LDL-C (mg/dL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −2.4 (23.8) | 105 | 1.5 (26.9) | 69 | 0.26 | BL outcome
LDL-C (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −1.3 (25.8) | 31 | 3.5 (22.7) | 27 | 0.37 | BL outcome and body weight, HbA1c, HOMA, DIo
LDL-C (mg/dL) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −4.4 (36.0) | 174 | 10.6 (42.0) | 37 | 0.059
LDL-C (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | −7.7 (30.9) | 288 | 7.7 (29.1) | 186 | 0.002 | Age, sex, BL zBMI, and pubertal stage
LDL-C (mg/dL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | 1.2 (13.2) | 34 | 0.4 (20.4) | 35 | 0.5
LDL-C (mg/dL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.42
LDL-C (mg/dL) | Norman, 2015^145^ Fair | 8 | 12 (0) | −13.5 (24.79) | 53 | −14.9 (26.8) | 53 | NR
HDL-C (mg/dL) | Weigel, 2008^170^ Fair | 114 | 12 (0) | NR | NR | NR | NR | NSD
HDL-C (mg/dL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | 3.2 (10.2) | 105 | 1.4 (11.9) | 69 | 0.32 | BL outcome
HDL-C (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −2.8 (9.6) | 31 | −3.9 (9.3) | 27 | 0.6 | BL outcome and body weight, HbA1c, HOMA, DIo
HDL-C (mg/dL) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | 1.5 (9.4) | 174 | 2.2 (11.3) | 37 | 0.368
HDL-C (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | 0.0 (13.9) | 288 | 0.0 (11.6) | 186 | 0.775 | Age, sex, BL zBMI, and pubertal stage
HDL-C (mg/dL) | Vos, 2011^167^ Fair | 45 | 12 (**) | 0.0 (18.7) | 32 | 0.0 (18.5) | 35 | NSD | BL differences
HDL-C (mg/dL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | 4.6 (6.3) | 34 | 2.7 (8.7) | 35 | 0.317
HDL-C (mg/dL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.96
HDL-C (mg/dL) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | −1.2 (9.1) | 53 | −2.3 (8.0) | 44 | NR | Age, sex, ethnicity
HDL-C (mg/dL) | Norman, 2015^145^ Fair | 8 | 12 (0) | 4.5 (10.16) | 53 | 3.6 (10.05) | 53 | NR
HDL-C (mg/dL) | Kong, 2013^136^ Fair | 4 | 9 (0) | 0.0 (9.4) | 28 | −1.5 (5.2) | 23 | 0.5
TC (mg/dL) | Weigel, 2008^170^ Fair | 114 | 12 (0) | NR | NR | NR | NR | NSD
TC (mg/dL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −9.2 (29.5) | 105 | 3.7 (32.2) | 69 | 0.005 | BL outcome
TC (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −10.8 (35.2) | 31 | −2.1 (29.0) | 27 | 0.24 | BL outcome and body weight, HbA1c, HOMA, DIo
TC (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | 0.0 (34.7) | 288 | 0.0 (31.6) | 186 | 0.311 | Age, sex, BL zBMI, and pubertal stage
TC (mg/dL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | 7.7 (23.0) | 34 | 3.9 (23.3) | 35 | 0.493
TC (mg/dL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.47
TC (mg/dL) | Boudreau, 2013^117^ Fair | 11 | 6 (0) | −8.4 (19.0) | 14 | 0.9 (16.9) | 12 | 0.08 | Primary household language
TC (mg/dL) | Norman, 2015^145^ Fair | 8 | 12 (0) | −12.2 (28.34) | 53 | −12.1 (28.24) | 53 | NR
Triglycerides (mg/dL) | Weigel, 2008^170^ Fair | 114 | 12 (0) | NR | NR | NR | NR | NSD
Triglycerides (mg/dL) | Savoye, 2007^156^ Fair | 82 | 12 (0) | −21.3 (38.7) | 105 | −8.1 (60.0) | 69 | 0.11 | BL outcome
Triglycerides (mg/dL) | Savoye, 2014^155^ Fair | 78 | 6 (0) | −28.4 (35.4) | 31 | −4.6 (42.2) | 27 | 0.005 | BL outcome and body weight, HbA1c, HOMA, DIo
Triglycerides (mg/dL) | Reinehr, 2006^149^ Fair | 78 | 12 (0) | −6.3 (74.5) | 174 | −4.1 (91.9) | 37 | 0.803
Triglycerides (mg/dL) | Reinehr, 2009^150^ Fair | 78 | 12 (0) | 0.0 (62.0) | 288 | 0.0 (62.0) | 186 | 0.493 | Age, sex, BL zBMI, and pubertal stage
Triglycerides (mg/dL) | Vos, 2011^167^ Fair | 45 | 12 (**) | −8.9 (128.5) | 32 | 8.9 (84.6) | 35 | NSD | BL differences
Triglycerides (mg/dL) | Kalavainen, 2007^133^ Fair | 44 | 6 (0) | −20.4 (41.5) | 33 | −1.8 (33.4) | 35 | 0.093
Triglycerides (mg/dL) | Golley, 2007^130^ Fair | 24 | 12 (7) | NR | NR | NR | NR | 0.98
Triglycerides (mg/dL) | Hofsteenge, 2014^131^ Fair | 17 | 6 (0) | NR | 53 | NR | 44 | NSD | Age, sex, ethnicity
Triglycerides (mg/dL) | Norman, 2015^145^ Fair | 8 | 12 (0) | −14.9 (62.17) | 53 | −13.6 (54.05) | 53 | NR
Triglycerides (mg/dL) | Kong, 2013^136^ Fair | 4 | 9 (0) | 8.9 (83.6) | 28 | 8.9 (43.3) | 23 | 0.95
Dyslipidemia | Love-Osborne, 2014^139^ Fair | 3 | 8 (0) | 1 (1.2)^*^ | 82 | 1 (1.2)^*^ | 83 | NSD

* Number (%).

Abbreviations: BL=baseline; CG=control group; DIo=basal disposition index; est=estimated; HbA1c=glycated hemoglobin; HDL-C=high-density lipoprotein cholesterol; HOMA=homeostatic model assessment; hrs=hours; IG=intervention group; LDL-C=low-density lipoprotein cholesterol; NR=not reported; NSD=no significant difference; SD=standard deviation; TC=total cholesterol; zBMI=body mass index z score.

Appendix D Table 9 Results of Lifestyle-Based Weight Maintenance and Nonlifestyle Weight Loss Trials (KQ 4)

Author, Year & Quality | Followup (months since tx ended) | Est hrs of contact | Outcome (unit) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Davis, 2012^125^ Fair | 8 (0) | 16 | zBMI (BMI SDS) | NR | NR | NR | NR | NSD
Davis, 2012^125^ Fair | 8 (0) | 16 | HDL-C (mg/dL) | 1.70 (8.50) | 30 | 1.0 (7.38) | 23 | NSD
Davis, 2012^125^ Fair | 8 (0) | 16 | Insulin (μIU/mL) | −4.6 (9.90) | 30 | −6.6 (11.34) | 23 | NSD
Boutelle, 2014^118^ Fair | 8 (4) | 28 | BMI (kg/m^2^) | −0.1 (4.73) | 21 | 0.6 (4.66) | 18 | 0.23 | Baseline BMI
Boutelle, 2014^118^ Fair | 8 (4) | 28 | zBMI (BMI SDS) | −0.1 (0.43) | 21 | −0.05 (0.40) | 18 | 0.16 | Baseline zBMI
Tanofsky-Kraff, 2010^162^ Fair | 6 (3) | 18 | BMI (kg/m^2^) | 0.87 (0.5) | 19 | 0.31 (1.59) | 19 | NSD
Tanofsky-Kraff, 2010^162^ Fair | 12 (9) | 18 | BMI (kg/m^2^) | 0.81 (1.25) | 19 | 0.68 (2.13) | 19 | NR
Tanofsky-Kraff, 2010^162^ Fair | 6 (3) | 18 | zBMI (BMI SDS) | 0.05 (0.40) | 19 | −0.07 (0.44) | 19 | NSD
Tanofsky-Kraff, 2010^162^ Fair | 12 (9) | 18 | zBMI (BMI SDS) | −0.1 (0.46) | 19 | −0.1 (0.46) | 19 | NR

Abbreviations: BMI=body mass index; CG=control group; est=estimated; HDL-C=high-density lipoprotein cholesterol; hrs=hours; IG=intervention group; IU=international unit; NR=not reported; NSD=no significant difference; SD=standard deviation; SDS=standardized deviation score; tx=treatment; zBMI=body mass index z score.

Appendix D Table 10 Weight Outcomes of Included Pharmacotherapy Trials (KQ 4)

Author, Year & Quality | Followup (months) | Outcome (unit) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Metformin
Freemark, 2001^128^ Fair | 6 | BMI (kg/m^2^) | −0.5 (NR) | 14 | 0.9 (NR) | 15 | <0.02
Freemark, 2001^128^ Fair | 6 | zBMI (BMI SDS) | −0.12 (0.3) | 14 | 0.23 (0.39) | 15 | <0.02
Wiegand, 2010^171^ Fair | 6 | BMI (kg/m^2^) | 0.07 (5.13) | 34 | −0.31 (5.47) | 29 | 0.964 | Age, sex, pubertal stage
Wiegand, 2010^171^ Fair | 6 | zBMI (BMI SDS) | −0.03 (0.7) | 34 | −0.02 (0.7) | 29 | 0.677 | Age, sex, pubertal stage
Kendall, 2013^135^ Fair | 6 | BMI (kg/m^2^) | −0.25 (6.32) | 55 | 0.21 (6.41) | 55 | 0.005 | Baseline BMI
Kendall, 2013^135^ Fair | 6 | zBMI (BMI SDS) | −0.09 (0.61) | 55 | −0.03 (0.52) | 55 | 0.02 | Baseline zBMI
Kendall, 2013^135^ Fair | 6 | Weight (kg) | 2.4 (24.46) | 55 | 0.4 (21.32) | 55 | 0.02 | Baseline weight (also possibly pubertal status, age, sex, and ethnicity in a secondary analysis; methods reporting somewhat unclear)
Love-Osborne, 2008^139^ Fair | 6 | BMI (kg/m^2^) | −0.16 (1.89) | 48 | 0.63 (1.29) | 16 | 0.11
Love-Osborne, 2008^139^ Fair | 6 | ≥5% BMI loss (no. of participants) | 11 (22.9) | 48 | 0 (0) | 16 | 0.001
Clarson, 2014^123^ Fair | 6 | zBMI (BMI SDS) | −0.14 (0.44) | 31 | −0.04 (0.39) | 30 | NR
Clarson, 2014^123^ Fair | 12 | zBMI (BMI SDS) | −0.17 (0.44) | 23 | 0.05 (0.40) | 24 | 0.01
Clarson, 2014^123^ Fair | 6 | BMI (kg/m^2^) | −0.88 (5.63) | 31 | −0.02 (5.54) | 30 | NR
Clarson, 2014^123^ Fair | 12 | BMI (kg/m^2^) | −0.56 (5.60) | 23 | 1.30 (5.67) | 24 | 0.01
Srinivasan, 2006^158^ Fair | 6 | BMI (kg/m^2^) | NR (NR) | NR | NR (NR) | NR | 0.002
Srinivasan, 2006^158^ Fair | 6 | zBMI (BMI SDS) | NR (NR) | NR | NR (NR) | NR | 0.005
Srinivasan, 2006^158^ Fair | 6 | Weight (kg) | NR (NR) | NR | NR (NR) | NR | 0.02
Srinivasan, 2006^158^ Fair | 6 | WC (cm) | NR (NR) | NR | NR (NR) | NR | 0.003
Wilson, 2010^172^ Fair | 12 | BMI (kg/m^2^) | −0.9 (3.12) | 27 | 0.2 (3.08) | 27 | 0.03 | Site, sex, race, ethnicity and age
Wilson, 2010^172^ Fair | 12 | zBMI (BMI SDS) | −0.09 (0.25) | 27 | −0.01 (0.25) | 27 | 0.09 | Site, sex, race, ethnicity and age
Yanovski, 2011^173^ Good | 6 | BMI (kg/m^2^) | −0.78 (2.84) | 53 | 0.32 (3.01) | 47 | 0.006 | Age, sex, race/ethnicity
Yanovski, 2011^173^ Good | 6 | zBMI (BMI SDS) | −0.11 (0.2) | 53 | −0.04 (0.21) | 47 | 0.02 | Age, sex, race/ethnicity
Yanovski, 2011^173^ Good | 6 | Weight (kg) | 1.47 (6.59) | 53 | 4.85 (7.01) | 47 | <0.001 | Age, sex, race/ethnicity
Yanovski, 2011^173^ Good | 6 | WC (cm) | 1.84 (10.57) | 53 | 4.38 (11.02) | 47 | 0.02 | Age, sex, race/ethnicity
Orlistat
Yanovski, 2012^108^ Fair | 6 | BMI (kg/m^2^) | −1.44 (2.6) | 100 | −0.50 (2) | 100 | NR
Yanovski, 2012^108^ Fair | 6 | Weight (kg) | −2.9 (7) | 100 | −0.6 (7) | 100 | NR
Yanovski, 2012^108^ Fair | 6 | zBMI (BMI SDS) | −0.12 (0.2) | 100 | −0.06 (0.2) | 100 | 0.007
Chanoine, 2005^122^ Fair | 12 | BMI (kg/m^2^) | −0.55 (NR) | 352 | 0.31 (NR) | 181 | 0.001 | Treatment center, treatment x center interaction, body weight < or ≥80 kg; weight loss during run-in. Corrected for age and sex by zBMI.
Chanoine, 2005^122^ Fair | 12 | Weight (kg) | 0.53 (NR) | 352 | 3.14 (NR) | 181 | <0.001 | Treatment center, treatment x center interaction, body weight < or ≥80 kg; weight loss during run-in. Corrected for age and sex by zBMI.
Chanoine, 2005^122^ Fair | 12 | WC (cm) | −1.33 (NR) | 352 | 0.12 (NR) | 181 | <0.05 | Treatment center, treatment x center interaction, body weight < or ≥80 kg; weight loss during run-in. Corrected for age and sex by zBMI.
Maahs, 2006^141^ Fair | 6 | BMI (kg/m^2^) | −1.3 (7.16) | 16 | −0.8 (13.42) | 18 | 0.7
Maahs, 2006^141^ Fair | 6 | Weight (kg) | −5.5 (23.91) | 16 | −1.6 (39.39) | 18 | 0.76

Abbreviations: BMI=body mass index; CG=control group; IG=intervention group; NR=not reported; SD=standard deviation; SDS=standardized deviation score; WC=waist circumference; zBMI=BMI z score.

Appendix D Table 11 Change in Mean zBMI in Pharmacotherapy Weight Loss Trials, With Columns Showing Mean ± 1 Standard Deviation (KQ 4)

Age group | Author, Year Quality | Intervention Group | | | | | Control Group
Age group | Author, Year Quality | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD
Metformin
52+ hours
Wide Age Range | Clarson, 2014^123^ Fair | 2.22 | −0.14 | 0.44 | −0.58 | 0.30 | 2.12 | −0.04 | 0.39 | −0.43 | 0.35
26–51 hours
Wide Age Range | Wiegand, 2010^171^ Fair | 2.46 | −0.03 | 0.70 | −0.73 | 0.67 | 2.46 | −0.02 | 0.70 | −0.72 | 0.68
6–25 hours
Adolescent | Wilson, 2010^172^ Fair | 2.28 | −0.09 | 0.25 | −0.34 | 0.16 | 2.29 | −0.01 | 0.25 | −0.26 | 0.24
0–5 hours
Wide Age Range | Kendall, 2013^135^ Fair | 3.44 | −0.09 | 0.61 | −0.70 | 0.52 | 3.34 | −0.03 | 0.52 | −0.55 | 0.49
Wide Age Range | Yanovski, 2011^173^ Good | 2.56 | −0.11 | 0.20 | −0.31 | 0.09 | 2.58 | −0.04 | 0.21 | −0.25 | 0.17
Adolescent | Freemark, 2001^128^ Fair | NR | −0.12 | 0.30 | −0.42 | 0.18 | NR | 0.23 | 0.39 | −0.16 | 0.62
Orlistat
Adolescent | Yanovski, 2012^108^ Fair | NR | −0.12 | 0.2 | −0.32 | 0.08 | NR | −0.06 | 0.2 | −0.26 | 0.14

Abbreviations: BL=baseline; BMI=body mass index; SD=standard deviation.

Appendix D Table 12 Reported or Calculated Change in Mean Weight (lb) in Pharmacotherapy Weight Loss Trials, With Columns Showing Mean ± 1 Standard Deviation (KQ 4)

Age group | Author, Year Quality | Follow-up (months) | Mean age (years) | BL BMI | Intervention Group | | | | | Control Group
Age group | Author, Year Quality | Follow-up (months) | Mean age (years) | BL BMI | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD | BL Mean | Mean Change | SD Change | Mean −SD | Mean +SD
Metformin
52+ hours
Wide Age Range | Clarson, 2014^123^ Fair | 6 | 13.7 | 32.5 | 185.0 | −3.1 | 31.5 | −34.6 | 28.4 | 184.0 | −1.4 | 14.3 | −15.7 | 12.9
26–51 hours
Wide Age Range | Wiegand, 2010^171†^ Fair | 6 | 15.0 | 34.9 | 197.7 | 0.4 | 29.6 | −29.2 | 30.0 | 204.8 | −1.8 | 31.5 | −33.3 | 29.7
6–25 hours
Adolescent | Wilson, 2010^172†^ Fair | 12 | 14.9 | 35.9 | 210.3 | −5.3 | 18.0 | −23.3 | 12.7 | 208.5 | 1.1 | 17.8 | −16.7 | 18.9
0–5 hours
Wide Age Range | Yanovski, 2011^173*^ Good | 6 | 10.2 | 34.4 | 168.2 | 3.2 | 14.5 | −11.3 | 17.7 | 176.4 | 10.7 | 15.4 | −4.7 | 26.1
Wide Age Range | Srinivasan, 2006^158^ Fair | 6 | 12.5 | 35.2 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wide Age Range | Kendall, 2013^135*^ Fair | 6 | 13.7 | 36.5 | 220.9 | 5.3 | 53.9 | −48.6 | 59.2 | 212.3 | 0.9 | 46.9 | −46.0 | 47.8
Adolescent | Love-Osborne, 2008^140†^ Fair | 6 | 15.7 | 39.7 | 228.8 | −0.9 | 11.0 | −11.9 | 10.1 | 228.1 | 3.7 | 7.5 | −3.7 | 11.2
Adolescent | Freemark, 2001^128†^ Fair | 6 | 14.9 | 40.0 | 239.1 | −2.9 | NR | NR | NR | 222.8 | 5.3 | NR | NR | NR
Orlistat
6–25 hours
Adolescent | Yanovski, 2012^108*^ Fair | 6 | 14.59 | 41.7 | NR | −6.4 | 15.4 | −21.8 | 9.0 | NR | −1.3 | 15.4 | −16.7 | 14.1
Adolescent | Chanoine, 2005^122*^ Fair | 12 | 13.6 | 35.6 | 215.1 | 1.2 | NR | NR | NR | 209.4 | 6.9 | NR | NR | NR
0–5 hours
Adolescent | Maahs, 2006^141*^ Fair | 6 | 15.8 | 40.4 | 244.6 | −12.1 | 52.6 | −64.7 | 40.5 | 251.7 | −3.5 | 86.8 | −90.3 | 83.3

* Study-reported weight change.

† Calculated weight change.

Abbreviations: BL=baseline; BMI=body mass index; SD=standard deviation.

Appendix D Table 13 Glucose and Insulin Outcomes of Included Pharmacotherapy Trials (KQ 4)

Outcome (unit) | Author, Year & Quality | Followup (months) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Metformin
FPG (mg/dL) | Freemark, 2001^128^ Fair | 6 | −9.20 (14.59) | 14 | 8.70 (12.78) | 15 | <0.01
FPG (mg/dL) | Kendall, 2013^135^ Fair | 6 | −0.72 (8.29) | 55 | 0.18 (7.93) | 55 | 0.53 | Baseline FPG
FPG (mg/dL) | Clarson, 2014^123^ Fair | 6 | −5.77 (6.23) | 31 | −3.96 (9.42) | 30 | NR
FPG (mg/dL) | Clarson, 2014^123^ Fair | 12 | −1.62 (5.73) | 23 | 1.80 (7.92) | 24 | NR
FPG (mg/dL) | Srinivasan, 2006^158^ Fair | 6 | NR | NR | NR | NR | 0.048
FPG (mg/dL) | Wiegand, 2010^171^ Fair | 6 | 0.60 (8.51) | 34 | 2.00 (11.00) | 29 | 0.189 | Age, sex, pubertal stage
FPG (mg/dL) | Yanovski, 2011^173*^ Good | 6 | −0.88 (10.88) | 53 | 3.47 (11.70) | 47 | 0.007 | Age, sex, race/ethnicity
2-hr OGTT (mg/dL) | Kendall, 2013^135^ Fair | 6 | −5.59 (25.38) | 55 | −5.77 (25.42) | 55 | 0.88 | Baseline 2-hr OGTT
2-hr OGTT (mg/dL) | Clarson, 2014^123^ Fair | 6 | −0.54 (19.28) | 31 | −2.88 (22.74) | 30 | NR
2-hr OGTT (mg/dL) | Clarson, 2014^123^ Fair | 12 | 3.42 (17.97) | 23 | −1.80 (22.31) | 24 | NR
2-hr OGTT (mg/dL) | Wiegand, 2010^171^ Fair | 6 | 2.00 (16.33) | 34 | 3.90 (22.68) | 29 | 0.377 | Age, sex, pubertal stage
HOMA^†^ | Freemark, 2001^128^ Fair | 6 | −3.08 (2.56) | 14 | −0.07 (5.75) | 15 | NR
HOMA^†^ | Kendall, 2013^135^ Fair | 6 | 0.20 (3.21) | 55 | 0.29 (3.29) | 55 | 0.53 | Baseline HOMA
HOMA^†^ | Clarson, 2014^123^ Fair | 6 | −1.04 (1.94) | 31 | −0.5 (2.09) | 30 | NR
HOMA^†^ | Clarson, 2014^123^ Fair | 12 | −0.87 (1.95) | 23 | 0.03 (1.97) | 24 | NR
HOMA^†^ | Wiegand, 2010^171^ Fair | 6 | NR | 34 | NR | 29 | 0.855 | Age, sex, pubertal stage
HOMA^†^ | Wilson, 2010^172^ Fair | 12 | −0.10 (5.00) | 27 | −0.80 (4.32) | 27 | 0.48 | Site, sex, race, ethnicity and age
HOMA^†^ | Yanovski, 2011^173*^ Good | 6 | 0.68 (4.01) | 53 | 2.23 (4.21) | 47 | 0.006 | Age, sex, race/ethnicity
Insulin (μIU/mL) | Freemark, 2001^128^ Fair | 6 | −12.30 (11.04) | 14 | −1.60 (25.95) | 15 | NR
Insulin (μIU/mL) | Kendall, 2013^135^ Fair | 6 | −0.65 (16.30) | 55 | 3.77 (18.05) | 55 | 0.97 | Baseline fasting insulin
Insulin (μIU/mL) | Srinivasan, 2006^158^ Fair | 6 | NR | NR | NR | NR | 0.011
Insulin (μIU/mL) | Wiegand, 2010^171^ Fair | 6 | NR | 34 | NR | 29 | 0.995 | Age, sex, pubertal stage
Insulin (μIU/mL) | Yanovski, 2011^173^ Good | 6 | 3.24 (17.09) | 53 | 9.00 (18.03) | 47 | 0.02 | Age, sex, race/ethnicity
Orlistat
FPG (mg/dL) | Chanoine, 2005^122^ Fair | 12 | NR | 282 | NR | 136 | 0.06 | Center, tx, tx x center
FPG (mg/dL) | Maahs, 2006^141^ Fair | 6 | 2.80 (7.79) | 16 | 4.80 (8.22) | 18 | 0.12
2-hr OGTT (mg/dL) | Chanoine, 2005^122^ Fair | 12 | NR | 283 | NR | 136 | 0.68 | Center, tx, tx x center
Insulin (μIU/mL) | Chanoine, 2005^122^ Fair | 12 | NR | 271 | NR | 132 | 0.41 | Center, tx, tx x center
Insulin (μIU/mL) | Maahs, 2006^141^ Fair | 6 | −0.70 (15.00) | 16 | 1.40 (12.27) | 18 | 0.43
2-hr insulin (μIU/mL) | Chanoine, 2005^122^ Fair | 12 | NR | 276 | NR | 133 | 0.44 | Center, tx, tx x center

* Unadjusted analyses from plots not significant.

† HOMA-IR (insulin resistance): insulin [μIU/mL] x glucose [mmol/L]/22.5.

Abbreviations: CG=control group; hr=hour(s); IG=intervention group; IU=international unit; FPG=fasting plasma glucose; HOMA=homeostatic model assessment; NR=not reported; OGTT=oral glucose tolerance test; SD=standard deviation; tx – treatment.

Appendix D Table 14 Lipid and Blood Pressure Outcomes of Included Pharmacotherapy Trials (KQ 4)

Outcome (mg/dL) | Author, Year & Quality | Followup (months) | IG mean difference (SD) | IG n | CG mean difference (SD) | CG n | Between group p-value | Adjustment details
Metformin
LDL | Freemark, 2001^128^ Fair | 6 | −6.50 (24.91) | 14 | −3.30 (32.97) | 15 | NR
LDL | Kendall, 2013^135^ Fair | 6 | −1.93 (29.24) | 55 | 2.32 (25.56) | 55 | 0.51 | Baseline LDL
LDL | Clarson, 2014^123^ Fair | 6 | −0.77 (22.17) | 31 | −1.93 (25.31) | 30 | NR
LDL | Clarson, 2014^123^ Fair | 12 | −1.93 (25.11) | 23 | −4.63 (25.62) | 24 | NR
LDL | Wiegand, 2010^171^ Fair | 6 | 3.30 (36.74) | 34 | −18.60 (39.20) | 29 | 0.44 | Age, sex, pubertal stage
LDL | Wilson, 2010^172^ Fair | 12 | 0.00 (24.98) | 27 | 0.00 (24.66) | 27 | 0.97 | Site, sex, race, ethnicity and age
LDL | Yanovski, 2011^173^ Good | 6 | −6.57 (27.93) | 53 | −2.78 (29.94) | 47 | 0.37 | Age, sex, race/ethnicity
HDL | Freemark, 2001^128^ Fair | 6 | 0.80 (8.98) | 14 | −1.40 (6.40) | 15 | NR
HDL | Kendall, 2013^135^ Fair | 6 | 1.93 (9.43) | 55 | 4.63 (10.02) | 55 | 0.95 | Baseline HDL
HDL | Clarson, 2014^ 123^ Fair | 6 | −0.39 (12.55) | 31 | −0.77 (13.14) | 30 | NR
HDL | Clarson, 2014^ 123^ Fair | 12 | 3.47 (13.56) | 23 | −2.32 (11.83) | 24 | NR
HDL | Wiegand, 2010^171^ Fair | 6 | −0.70 (14.52) | 34 | 0.80 (14.02) | 29 | 0.36 | Age, sex, pubertal stage
HDL | Wilson, 2010^172^ Fair | 12 | 1.00 (6.24) | 27 | 0.00 (6.16) | 27 | 0.38 | Site, sex, race, ethnicity and age
HDL | Yanovski, 2011^173^ Good | 6 | 0.12 (9.90) | 53 | −0.27 (10.51) | 47 | 0.79 | Age, sex, race/ethnicity
TC | Freemark, 2001^128^ Fair | 6 | −7.10 (21.11) | 14 | −6.80 (39.17) | 15 | NR
TC | Kendall, 2013^135^ Fair | 6 | −2.32 (30.46) | 55 | 0.00 (31.51) | 55 | 0.93 | Baseline TC
TC | Wiegand, 2010^171^ Fair | 6 | −7.60 (31.08) | 34 | −7.60 (32.36) | 29 | 0.55 | Age, sex, pubertal stage
TC | Yanovski, 2011^173^ Good | 6 | −9.05 (28.17) | 53 | −4.52 (29.78) | 47 | 0.27 | Age, sex, race/ethnicity
Triglycerides | Freemark, 2001^128^ Fair | 6 | −1.50 (39.70) | 14 | −13.80 (80.74) | 15 | NR
Triglycerides | Kendall, 2013^135^ Fair | 6 | −12.39 (57.97) | 55 | −21.24 (77.74) | 55 | 0.66 | Baseline triglycerides
Triglycerides | Clarson, 2014^123^ Fair | 6 | −2.65 (74.38) | 31 | −7.08 (55.94) | 30 | NR
Triglycerides | Clarson, 2014^123^ Fair | 12 | −19.47 (61.44) | 23 | −12.39 (48.12) | 24 | NR
Triglycerides | Wiegand, 2010^171^ Fair | 6 | NR | 34 | NR | 29 | 0.37 | Age, sex, pubertal stage
Triglycerides | Wilson, 2010^172^ Fair | 12 | −2.00 (74.94) | 27 | 1.00 (73.97) | 27 | 0.80 | Site, sex, race, ethnicity and age
Triglycerides | Yanovski, 2011^173^ Good | 6 | 7.70 (76.26) | 53 | 3.79 (81.06) | 47 | 0.72 | Age, sex, race/ethnicity
LDL:HDL | Freemark, 2001^128^ Fair | 6 | −0.20 (0.75) | 14 | 0.00 (0.77) | 15 | NR
SBP (mm Hg) | Kendall, 2013^135^ Fair | 6 | 1.5 (14.0)^*^ | 55 | 0.8 (13.9)^*^ | 55 | 0.42 | Baseline SBP
SBP (mm Hg) | Wiegand, 2010^171^ Fair | 6 | −5 (15.6)^*^ | 34 | −2 (14.6)^*^ | 29 | 0.828 | Age, sex, pubertal stage
DBP (mm Hg) | Kendall, 2013^135^ Fair | 6 | 0.3 (9.4)^*^ | 55 | −1 (8.9)^*^ | 55 | 0.36 | Baseline DBP
DBP (mm Hg) | Wiegand, 2010^171^ Fair | 6 | 1 (9.3)^*^ | 34 | 1 (12.1)^*^ | 29 | 0.876 | Age, sex, pubertal stage
Orlistat
LDL | Chanoine, 2005^122^ Fair | 12 | −0.99^*^ (NR) | 322 | 0.88^*^ (NR) | 162 | 0.29 | Center, tx, tx x center
LDL | Maahs, 2006^141^ Fair | 6 | 1.40 (31.63) | 16 | −4.00 (25.73) | 18 | 0.13
HDL | Chanoine, 2005^122^ Fair | 12 | 0.07^*^ (NR) | 323 | −0.31^*^ (NR) | 163 | 0.62 | Center, tx, tx x center
HDL | Maahs, 2006^141^ Fair | 6 | −0.20 (8.68) | 16 | 0.90 (8.60) | 18 | 0.47
TC | Chanoine, 2005^122^ Fair | 12 | 2.26^*^ (NR) | 323 | 3.39^*^ (NR) | 163 | 0.59 | Center, tx, tx x center
TC | Maahs, 2006^141^ Fair | 6 | −1.10 (39.71) | 16 | −3.00 (35.42) | 18 | 0.49
Triglycerides | Chanoine, 2005^122^ Fair | 12 | 17.90^*^ (NR) | 323 | 11.68^*^ (NR) | 163 | 0.30 | Center, tx, tx x center
Triglycerides | Maahs, 2006^141^ Fair | 6 | −12.40 (75.36) | 16 | 0.60 (56.14) | 18 | 0.52
SBP (mm Hg) | Chanoine, 2005^122^ Fair | 12 | 1.09^*^ (NR) | 347 | 1.31^*^ (NR) | 180 | 0.84 | Center, tx, tx x center
DBP (mm Hg) | Chanoine, 2005^122^ Fair | 12 | −0.51^*^(NR) | 347 | 1.30^*^ (NR) | 180 | 0.04 | Center, tx, tx x center

* Study-reported.

Abbreviations: CG=control group; DBP=diastolic blood pressure; hr=hour(s); HDL=high-density lipoprotein; IG=intervention group; LDL=low-density lipoprotein; NR=not reported; SBP=systolic blood pressure; SD=standard deviation; TC=total cholesterol; tx=treatment.

Appendix D Figure 1 Forest Plot of Change in Weight (zBMI, BMI, Weight [kg], or BMI Percentile) in Behavior-Based Weight Loss Intervention Trials, by Estimated Contact Hours, Showing DerSimonian &; Laird Pooled Estimates, by Age Category (KQ 4)

Abbreviations: BL=baseline; BMI=body mass index; CG=control group; CI=confidence interval; DBP=diastolic blood pressure; est=estimated; hrs=hours; IG=intervention group; m=month(s); SBP=systolic blood pressure; SD=standard deviation; SMD=standardized mean difference; tx=treatment.

This figure is a forest plot of change in any weight outcome in behavior-based intervention trials, stratified by age group with pooled estimates