# Appendix C Excluded Studies

E1. Study Relevance; a. Not a trial of childhood overweight screening or treatment; b. Other
E2. Setting: Community/university research laboratories or other nonmedical centers; college setting; mental health clinics (unless recruitment is through primary care); correctional facilities; school classrooms; worksites; inpatient/residential facilities; emergency departments.; a. Countries that are not a member of the OECD
E3. Comparative Effectiveness (multiple active interventions, no control condition, including pharmacogenetic studies and other studies looking at treatment matching)
E4. No relevant outcomes: Behavioral outcomes only (diet, physical activity); b Timing of outcome assessment (KQ 1–4) <6 months after baseline
E5. Population; a. Limited to average age younger than 2 or older than 18 years; b. Limited exclusively to youth who: have an eating disorder, are pregnant or postpartum, are overweight or have obesity secondary to a genetic or medical condition, are in college
E6. Intervention (KQ3–5); a. Primary prevention in children who are normal weight; b. Surgical interventions; c. Studies that include elements that cannot be implemented in a health care setting (e.g., changes to the physical/built environment, legislation); d. Complementary and alternative medicine approaches; e. Studies that provide all or most of participants’ food
E7. Study Design: Not an RCT or CCT (KQ1–4) or comparative observational design, large case series, large event monitoring studies (KQ5 harms of weight loss medications only)
E8. Study Quality; a. High or differential attrition; b. Other quality issue or not enough information to assess quality
E9. Non-English
E10. Published in 1966 or earlier
E11. Unable to locate article

1 Adeyemo MA, McDuffie JR, Kozlosky M, . Effects of metformin on energy intake and satiety in obese children. Diabetes Obes Metab. 2015;17(4):363–70. PMID: 25483291. KQ1E1, KQ2E1, KQ3E4.25483291
2 Aguilera A, Torre A, Kaiser L. Changes in food consumption patterns of mexican-heritage children during a nutrition intervention. Exp Biol. 2015;29(1). PMID: None. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.
3 Alexy U, Reinehr T, Sichert-Hellert W, . Positive changes of dietary habits after an outpatient training program for overweight children. Nutr Res. 2006;26(5):202–8. PMID: None. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.
4 Altman M, Cahill Holland J, Lundeen D, . Reduction in food away from home is associated with improved child relative weight and body composition outcomes and this relation is mediated by changes in diet quality. J Acad Nutr Diet. 2015;115(9):1400–7. PMID: 25963602. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.25963602
5 Amador M, Ramos LT, Morono M, . Growth rate reduction during energy restriction in obese adolescents. Exp Clin Endocrinol. 1990;96(1):73–82. PMID: 2279528. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.2279528
6 Anderson JD, Newby R, Kehm R, . Taking Steps Together: a family- and community-based obesity intervention for urban, multiethnic children. Health Educ Behav. 2015;42(2):194–201. PMID: None. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.25150275
7 Andre N, Beguier S. Using motivational interviewing as a supplement to physical activity program in obese adolescents: a RCT study. Eat Weight Disord. 2015;20(4):519–23. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.26335206
8 Antal H, Buckloh L, Lochrie A, . Family-based intervention for overweight youth: Effects on health-related quality of life and measurements of physical health. 2010. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.
9 Armstrong B, Lim CS, Janicke DM. Park density impacts weight change in a behavioral intervention for overweight rural youth. Behav Med. 2015;41(3):123–30. PMID: 26332930. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.26332930
10 Atabek ME, Pirgon O. Use of metformin in obese adolescents with hyperinsulinemia: a 6-month, randomized, double-blind, placebo-controlled clinical trial. J Pediatr Endocrinol Metab. 2008;21(4):339–48. PMID: 18556965. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E8b.18556965
11 Azad A, Gharakhanlou R, Niknam A, . Effects of aerobic exercise on lung function in overweight and obese students. Tanaffos. 2011;10(3):24–31. PMID: 25191372. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a.25191372
12 Backlund C, Sundelin G, Larsson C. Effect of a 1-year lifestyle intervention on physical activity in overweight and obese children. Adv Physiother. 2011;13(3):87–96. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
13 Backlund C, Sundelin G, Larsson C. Effects of a 2-year lifestyle intervention on physical activity in overweight and obese children. Adv Physiother. 2011;13(3):97–109. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
14 Backlund C, Sundelin G, Larsson C. Evaluation of a 2-year family-based lifestyle intervention regarding physical activity among children with overweight and obesity. Physiotherapy (United Kingdom). 2011;97:eS94–eS5. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
15 Balagopal P, Bayne E, Sager B, . Effect of lifestyle changes on whole-body protein turnover in obese adolescents. Int J Obes Relat Metab Disord. 2003;27(10):1250–7. PMID: 14513074. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.14513074
16 Balagopal P, George D, Patton N, . Lifestyle-only intervention attenuates the inflammatory state associated with obesity: a randomized controlled study in adolescents. J Pediatr. 2005;146(3):342–8. PMID: 15756217. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.15756217
17 Ball GD, Mackenzie-Rife KA, Newton MS, . One-on-one lifestyle coaching for managing adolescent obesity: Findings from a pilot, randomized controlled trial in a real-world, clinical setting. Paediatr child health. 2011;16(6):345–50. PMID: 22654546. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.22654546
18 Barkin SL, Gesell SB, Poe EK, . Changing overweight Latino preadolescent body mass index: the effect of the parent-child dyad. Clin Pediatr (Phila). 2011;50(1):29–36. PMID: 20837625. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.20837625
19 Bauer S, de Niet J, Timman R, . Enhancement of care through self-monitoring and tailored feedback via text messaging and their use in the treatment of childhood overweight. Patient Educ Couns. 2010;79(3):315–9. PMID: 20418046. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.20418046
20 Bean MK, Mazzeo SE, Stern M, . A values-based Motivational Interviewing (MI) intervention for pediatric obesity: study design and methods for MI Values. Contemp Clin Trials. 2011;32(5):667–74. PMID: 21554994. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.21554994
21 Bean MK, Powell P, Quinoy A, . Motivational interviewing targeting diet and physical activity improves adherence to paediatric obesity treatment: results from the MI Values randomized controlled trial. Pediatr Obes. 2014. PMID: 24729537. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24729537
22 Bean MK, Wilson DB, Thornton LM, . Dietary intake in a randomized-controlled pilot of NOURISH: a parent intervention for overweight children. Prev Med. 2012;55(3):224–7. PMID: 22735041. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.22735041
23 Becque MD, Katch VL, Rocchini AP, . Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Pediatrics. 1988;81(5):605–12. PMID: 3357722. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.3357722
24 Berkowitz RI, Fujioka K, Daniels SR, . Effects of sibutramine treatment in obese adolescents: a randomized trial. Ann Intern Med. 2006;145(2):81–90. PMID: 16847290. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.16847290
25 Berkowitz RI, Rukstalis MR, Bishop-Gilyard CT, . Treatment of adolescent obesity comparing self-guided and group lifestyle modification programs: a potential model for primary care. J Pediatr Psychol. 2013;38(9):978–86. PMID: 23750019. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23750019
26 Berkowitz RI, Wadden TA, Tershakovec AM, . Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805–12. PMID: 12684359. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.12684359
27 Bernardita Prado A, Veronica Gaete P, Francisca Corona H, . Metabolic effect of metformin in obese adolescents at risk of diabetes mellitus type 2. Revista Chilena de Pediatria. 2012;83(1):48–57. PMID: None. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
28 Berner N, Jay M, Lewis K, . Comparison of parent and child versus child-only weight management interventions in the patient-centered medical home. J Clin Outcomes Manag. 2015;22(2):57–60. PMID: None. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.
29 Berry D, Savoye M, Melkus G, . An intervention for multiethnic obese parents and overweight children. Appl Nurs Res. 2007;20(2):63–71. PMID: 17481469. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.17481469
30 Berry DC, McMurray R, Schwartz TA, . Rationale, design, methodology and sample characteristics for the family partners for health study: a cluster randomized controlled study. BMC Public Health. 2012;12:250. PMID: 22463125. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2.22463125
31 Berry DC, Schwartz TA, McMurray RG, . The family partners for health study: a cluster randomized controlled trial for child and parent weight management. Nutr Diabetes. 2014;4:e101. PMID: 24418827. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.24418827
32 Best JR, Goldschmidt AB, Mockus-Valenzuela DS, . Shared weight and dietary changes in parent-child dyads following family-based obesity treatment. Health Psychol. 2016;35(1):92–5. PMID: 26192385. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.26192385
33 Bloom T, Sharpe L, Mullan B, . A pilot evaluation of appetite-awareness training in the treatment of childhood overweight and obesity: a preliminary investigation. Int J Eat Disord. 2013;46(1):47–51. PMID: 22826019. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.22826019
34 Bluher S, Panagiotou G, Petroff D, . Effects of a 1-year exercise and lifestyle intervention on irisin, adipokines, and inflammatory markers in obese children. Obesity (Silver Spring). 2014;22(7):1701–8. PMID: 24644099. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.24644099
35 Bocca G, Corpeleijn E, Stolk RP, . Results of a multidisciplinary treatment program in 3-year-old to 5-year-old overweight or obese children: a randomized controlled clinical trial. Arch Pediatr Adolesc Med. 2012;166(12):1109–15. PMID: 23108941. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E4.23108941
36 Bocca G, Corpeleijn E, Stolk RP, . Effect of obesity intervention programs on adipokines, insulin resistance, lipid profile, and low-grade inflammation in 3- to 5-y-old children. Pediatr Res. 2014;75(2):352–7. PMID: 24232638. KQ1E1, KQ2E1, KQ3E4, KQ4E3, KQ5E4.24232638
37 Bocca G, Corpeleijn E, van den Heuvel ER, . Three-year follow-up of 3-year-old to 5-year-old children after participation in a multidisciplinary or a usual-care obesity treatment program. Clin Nutr. 2014;33(6):1095–100. PMID: 24377413. KQ1E1, KQ2E1, KQ3E4, KQ4E3, KQ5E4.24377413
38 Bocca G, Kuitert MW, Sauer PJ, . A multidisciplinary intervention programme has positive effects on quality of life in overweight and obese preschool children. Acta Paediatr. 2014;103(9):962–7. PMID: 24862085. KQ1E1, KQ2E1, KQ3E3, KQ4E4, KQ5E4.24862085
39 Bock DE, Robinson T, Seabrook JA, . The Health Initiative Program for Kids (HIP Kids): effects of a 1-year multidisciplinary lifestyle intervention on adiposity and quality of life in obese children and adolescents--a longitudinal pilot intervention study. BMC Pediatrics. 2014;14:296. PMID: 25475951. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.25475951
40 Bohnert AM, Ward AK. Making a difference: Evaluating the Girls in the Game (GIG) after-school program. J Early Adolesc. 2013;33(1):104–30. PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
41 Bonsergent E, Agrinier N, Thilly N, . Overweight and obesity prevention for adolescents: a cluster randomized controlled trial in a school setting. Am J Prev Med. 2013;44(1):30–9. PMID: 23253647. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.23253647
42 Bonsergent E, Thilly N, Legrand K, . Process evaluation of a school-based overweight and obesity screening strategy in adolescents. Global Health Promot. 2013;20(2 Suppl):76–82. PMID: 23678500. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.23678500
43 Boudreau AD, Kurowski DS, Gonzalez WI, . Latino families, primary care, and childhood obesity: a randomized controlled trial. Am J Prev Med. 2013;44(3 Suppl 3):S247–57. PMID: 23415190. KQ1E1, KQ2E1, KQ5E4.23415190
44 Boutelle KN, Fannin H, Cafri G, . A randomized clinical trial evaluating the efficacy of a guided self-help treatment for families with an overweight child. Obesity (Silver Spring, Md). 2011;19:S103. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
45 Boutelle KN, Norman GJ, Rock CL, . Guided self-help for the treatment of pediatric obesity. Pediatrics. 2013;131(5):e1435–42. PMID: 23545372. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.23545372
46 Boutelle KN, Zucker N, Peterson CB, . An intervention based on Schachter’s externality theory for overweight children: The Regulation of Cues pilot. J Pediatr Psychol. 2014;39(4):405–17. PMID: 24459240. KQ1E1, KQ2E1, KQ3E4, KQ5E4.24459240
47 Braet C, Tanghe A, Decaluwe V, . Inpatient treatment for children with obesity: weight loss, psychological well-being, and eating behavior. J Pediatr Psychol. 2004;29(7):519–29. PMID: 15347700. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.15347700
48 Braet C, Van Winckel M. Long-term follow-up of a cognitive behavioral treatment program for obese children. Behav Ther. 2000;31(1):55–74. PMID: None. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.
49 Braet C, Van Winckel M, Van Leeuwen K. Follow-up results of different treatment programs for obese children. Acta Paediatr. 1997;86(4):397–402. PMID: 9174227. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.9174227
50 Brennan L, Walkley J, Fraser SF, . Motivational interviewing and cognitive behaviour therapy in the treatment of adolescent overweight and obesity: study design and methodology. Contemp Clin Trials. 2008;29(3):359–75. PMID: 17950046. KQ1E1, KQ2E1, KQ3E8a, KQ4E8a, KQ5E4.17950046
51 Brennan L, Walkley J, Wilks R. Parent- and adolescent-reported barriers to participation in an adolescent overweight and obesity intervention. Obesity (Silver Spring). 2012;20(6):1319–24. PMID: 22193923. KQ1E1, KQ2E1, KQ3E8a, KQ4E8a, KQ5E4.22193923
52 Brennan L, Walkley J, Wilks R, . Physiological and behavioural outcomes of a randomised controlled trial of a cognitive behavioural lifestyle intervention for overweight and obese adolescents. Obes Res Clin Pract. 2013;7(1):e23–41. PMID: 24331680. KQ1E1, KQ2E1, KQ3E8a, KQ4E8a, KQ5E4.24331680
53 Brennan L, Wilks R, Walkley J, . Treatment acceptability and psychosocial outcomes of a randomised controlled trial of a cognitive behavioural lifestyle intervention for overweight and obese adolescents. Behav Change. 2012;29(1):36–62. PMID: 24331680. KQ1E1, KQ2E1, KQ3E8a, KQ4E8a, KQ5E4.24331680
54 Broccoli S, Davoli AM, Bonvicini L, . Motivational interviewing to treat overweight children: 24-month follow-up of a randomized controlled trial. Pediatrics. 2016;137(1):1–10. PMID: 26702030. KQ1E1, KQ2E1, KQ3E4, KQ5E4.26702030
55 Brown B, Noonan C, Harris KJ, . Developing and piloting the Journey to Native Youth Health program in Northern Plains Indian communities. Diabetes Educ. 2013;39(1):109–18. PMID: 23150531. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.23150531
56 Brown BD, Noonan C, Harris KJ, . Diabetes prevention program for native american youth: The journey to native youth health feasibility study. Diabetes. 2011;60:A82. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
57 Browning MG, Bean MK, Wickham EP, . Cardiometabolic and fitness improvements in obese girls who either gained or lost weight during treatment. J Pediatr. 2015;166(6):1364–9. PMID: 25890676. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25890676
58 Brufani C, Fintini D, Nobili V, . Use of metformin in pediatric age. Pediatr Diabetes. 2011;12(6):580–8. PMID: 21366813. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.21366813
59 Bruyndonckx L, Hoymans VY, De Guchtenaere A, . Diet, exercise, and endothelial function in obese adolescents. Pediatrics. 2015;135(3):e653–61. PMID: 25667241. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.25667241
60 Bryant M, Farrin A, Christie D, . Results of a feasibility randomised controlled trial (RCT) for WATCH IT: a programme for obese children and adolescents. Clin Trials. 2011;8(6):755–64. PMID: 22024104. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22024104
61 Budd GM, Hayman LL, Crump E, . Weight loss in obese African American and Caucasian adolescents: secondary analysis of a randomized clinical trial of behavioral therapy plus sibutramine. J Cardiovasc Nurs. 2007;22(4):288–96. PMID: 17589281. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.17589281
62 Burgert TS, Duran EJ, Goldberg-Gell R, . Short-term metabolic and cardiovascular effects of metformin in markedly obese adolescents with normal glucose tolerance. Pediatr Diabetes. 2008;9(6):567–76. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b.18761646
63 Campos RM, de Mello MT, Tock L, . Aerobic plus resistance training improves bone metabolism and inflammation in adolescents who are obese. J Strength Cond Res. 2014;28(3):758–66. PMID: 24263653. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.24263653
64 Carraway ME. Project mentor+: Mentor-led exercise with cognitive-behavioral therapy to improve perceived competence, reduce social anxiety, and increase physical activity in overweight adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2015;76(2). PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
65 Caylr A, Turan MI, Gurbuz F, . The effect of lifestyle change and metformin therapy on serum arylesterase and paraoxonase activity in obese children. J Pediatr Endocrinol Metab. 2015;28(5–6):551–6. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25252747
66 Celio AA. Early intervention of eating- and weight-related problems via the internet in overweight adolescents: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;66(4-B):2299. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.
67 Chanoine JP, Hampl S, Jensen C, . Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. JAMA. 2005;293(23):2873–83. PMID: 15956632. KQ1E1, KQ2E1, KQ3E4.15956632
68 Chanoine JP, Richard M. Early weight loss and outcome at one year in obese adolescents treated with orlistat or placebo. Int J Pediatr Obes. 2011;6(2):95–101. PMID: 20858149. KQ1E1, KQ2E1, KQ3E4,.20858149
69 Chen AK, Roberts CK, Barnard RJ. Effect of a short-term diet and exercise intervention on metabolic syndrome in overweight children. Metabolism. 2006;55(7):871–8. PMID: 16784957. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.16784957
70 Chen JL, Kwan M, Mac A, . iStart smart: a primary-care based and community partnered childhood obesity management program for Chinese-American children: feasibility study. J Immigr Minor Health. 2013;15(6):1125–8. PMID: 23595264. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.23595264
71 Chen JL, Weiss S, Heyman MB, . Efficacy of a child-centred and family-based program in promoting healthy weight and healthy behaviors in Chinese American children: a randomized controlled study. J Public Health (Oxf). 2010;32(2):219–29. PMID: 19933120. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.19933120
72 Chen JL, Weiss SJ, Heyman MB, . The Active Balance Childhood program for improving coping and quality of life in Chinese American children. Nurs Res. 2010;59(4):270–9. PMID: 20585223. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.20585223
73 Chirita-Emandi A, Puiu M. Outcomes of neurofeedback training in childhood obesity management: A pilot study. J Altern Complement Med. 2014;20(11):831–7. PMID: None. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E6.25188371
74 Chongviriyaphan N, Sangthien N, Suthutvoravut U, editors. The nutrition counselling with a behavior modification is effective in obese school-aged children. 11th International Congress on Obesity; 2010; Stockholm Sweden. Search 1 CENTRAL 20150210. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
75 Clarson CL, Brown H, Dejesus S, . Structured lifestyle intervention with metformin extended release or placebo in obese adolescents. Diabetes. 2013;62:A337–a8. PMID: None. KQ1E1, KQ2E1, KQ3E4KQ5E4.
76 Clarson CL, Brown HK, Dejesus S, . Effects of a comprehensive, intensive lifestyle intervention combined with metformin extended release in obese adolescents. International Scholarly Research Notices. 2014;2014:13. KQ1E1, KQ2E1, KQ3E4.
77 Clarson CL, Mahmud FH, Baker JE, . Metformin in combination with structured lifestyle intervention improved body mass index in obese adolescents, but did not improve insulin resistance. Endocrine. 2009;36(1):141–6. PMID: 19387874. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19387874
78 Cohen T, Hazell T, Loiselle SE, . A family-centered lifestyle intervention focused on milk and alternatives reduces adiposity in 6-to 8-year-old overweight and obese children compared to control: Results at 6 months from a RCT. Exp Biol. 2014;28(Suppl 1). PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
79 Cohen TR, Hazell TJ, Loiselle S, ., editors. A family-centered lifestyle intervention focused on milk and alternatives reduces adiposity in six to eight Y old overweight and obese children compared to control: Results at six months from a RCT. 91st Annual Conference of the Canadian Paediatric Society; 2014; Montreal, QC Canada. Search 2 CENTRAL 20160122: Pulsus Group Inc. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
80 Cohen TR, Hazell TJ, Vanstone CA, . A family-centered lifestyle intervention to improve body composition and bone mass in overweight and obese children 6 through 8 years: a randomized controlled trial study protocol. BMC Public Health. 2013;13:383. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.23617621
81 Coleman KJ, Tiller CL, Sanchez J, . Prevention of the epidemic increase in child risk of overweight in low-income schools: the El Paso coordinated approach to child health. Archives of Pediatrics & Adolescent Medicine 159(3):217–24,. 2005. PMID: 15753263. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.15753263
82 Condarco TA, Sherafat-Kazemzadeh R, McDuffie JR, ., editors. Long-term follow-up of a randomized, placebo-controlled trial of orlistat in African-American and caucasian adolescents with obesity-related comorbid conditions. The Endocrine Society’s 95th Annual Meeting and Expo; 2013 June 15; San Francisco, CA. Search 2 CENTRAL 20160122: Endocrine Society. KQ1E1, KQ2E1, KQ3E4, KQ5E4.
83 Coppins DF, Margetts BM, Fa JL, . Effectiveness of a multi-disciplinary family-based programme for treating childhood obesity (the Family Project). Eur J Clin Nutr. 2011;65(8):903–9. PMID: 21487425. KQ1E1, KQ2E1, KQ3E4, KQ4E2b, KQ5E4.21487425
84 Croker H, Viner RM, Nicholls D, . Family-based behavioural treatment of childhood obesity in a UK National Health Service setting: randomized controlled trial. Int J Obes (Lond). 2012;36(1):16–26. PMID: 21931327. KQ1E1, KQ2E1, KQ3E8a.21931327
85 Cruz TH, Davis SM, FitzGerald CA, . Engagement, recruitment, and retention in a trans-community, randomized controlled trial for the prevention of obesity in rural American Indian and Hispanic children. J Prim Prev. 2014;35(3):135–49. PMID: 24549525. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.24549525
86 Damaso AR, da Silveira Campos RM, Caranti DA, . Aerobic plus resistance training was more effective in improving the visceral adiposity, metabolic profile and inflammatory markers than aerobic training in obese adolescents. J Sports Sci. 2014;32(15):1435–45. PMID: 24730354. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.24730354
87 Daniels SR, Long B, Crow S, . Cardiovascular effects of sibutramine in the treatment of obese adolescents: results of a randomized, double-blind, placebo-controlled study. Pediatrics. 2007;120(1):e147–57. PMID: 17576783. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.17576783
88 Danielsen YS, Nordhus IH, Juliusson PB, . Effect of a family-based cognitive behavioural intervention on body mass index, self-esteem and symptoms of depression in children with obesity (aged 7–13): a randomised waiting list controlled trial. Obes Res Clin Pract. 2013;7(2):e116–e28. PMID: 24331773. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.24331773
89 Davies MA, Terhorst L, Nakonechny AJ, . The development and effectiveness of a health information website designed to improve parents’ self-efficacy in managing risk for obesity in preschoolers. J Spec Pediatr Nurs. 2014;19(4):316–30. PMID: 25160030. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.25160030
90 Davis AM, James RL, Boles RE, . The use of TeleMedicine in the treatment of paediatric obesity: feasibility and acceptability. Matern Child Nutr. 2011;7(1):71–9. PMID: 21108739. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.21108739
91 Davis AM, Sampilo M, Gallagher KS, . Treating rural pediatric obesity through telemedicine: outcomes from a small randomized controlled trial. J Pediatr Psychol. 2013;38(9):932–43. PMID: 23428652. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.23428652
92 Davis JN, Kelly LA, Lane CJ, . Randomized control trial to improve adiposity and insulin resistance in overweight Latino adolescents. Obesity (Silver Spring). 2009;17(8):1542–8. PMID: 19247280. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.19247280
93 Davis JN, Ventura EE, Tung A, . Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012;7(1):16–27. PMID: 22434736. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22434736
94 Davoli AM, Broccoli S, Bonvicini L, . Pediatrician-led motivational interviewing to treat overweight children: an RCT. Pediatrics. 2013;132(5):e1236–46. PMID: 24144717. KQ1E1, KQ2E1, KQ3E4, KQ5E4.24144717
95 de Carvalho-Ferreira JP, Masquio DC, da Silveira Campos RM, . Is there a role for leptin in the reduction of depression symptoms during weight loss therapy in obese adolescent girls and boys? Peptides. 2015;65:20–8. PMID: 25629253. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a.25629253
96 de Mello ED, Luft VC, Meyer F. [Individual outpatient care versus group education programs. Which leads to greater change in dietary and physical activity habits for obese children?]. J Pediatr (Rio J). 2004;80(6):468–74. PMID: 15622423. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.15622423
97 De Miguel-Etayo P, Moreno LA, Santabarbara J, . Anthropometric indices to assess body-fat changes during a multidisciplinary obesity treatment in adolescents: EVASYON Study. Clin Nutr. 2015;34(3):523–8. PMID: 24993080. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24993080
98 de Niet J, Timman R, Bauer S, . The effect of a short message service maintenance treatment on body mass index and psychological well-being in overweight and obese children: a randomized controlled trial. Pediatr Obes. 2012;7(3):205–19. PMID: 22492669. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22492669
99 de Niet J, Timman R, Bauer S, . Short message service reduces dropout in childhood obesity treatment: a randomized controlled trial. Health Psychol. 2012;31(6):797–805. PMID: 22468714. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22468714
100 DeBar LL, Stevens VJ, Perrin N, . A primary care-based, multicomponent lifestyle intervention for overweight adolescent females. Pediatrics. 2012;129(3):e611–20. PMID: 22331335. KQ1E1, KQ2E1.22331335
101 Denney-Wilson E, Robinson A, Laws R, . Development and feasibility of a child obesity prevention intervention in general practice: the Healthy 4 Life pilot study. J Paediatr Child Health. 2014;50(11):890–4. PMID: 24946199. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.24946199
102 Dennison BA, Nicholas J, de Long R, . Randomized controlled trial of a mailed toolkit to increase use of body mass index percentiles to screen for childhood obesity. Preventing Chronic Disease. 2009;6(4):A122. PMID: 19754998. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.19754998
103 Dennison BA, Russo TJ, Burdick PA, . An intervention to reduce television viewing by preschool children. Arch Pediatr Adolesc Med. 2004;158(2):170–6. PMID: 14757609. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.14757609
104 Dewes O, Sluyter J, Scragg R, . Fanau FAB: Parent-focused weight management programme for Pacific children. Obesity reviews. 2014;15:212. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
105 Diaz M, Bassols J, Lopez-Bermejo A, . Metformin treatment to reduce central adiposity after prenatal growth restraint: a placebo-controlled pilot study in prepubertal children. Pediatr Diabetes. 2015;16(7):538–45. PMID: 25332100. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.25332100
106 Diaz RG, Esparza-Romero J, Moya-Camarena SY, . Lifestyle intervention in primary care settings improves obesity parameters among Mexican youth. J Am Diet Assoc. 2010;110(2):285–90. PMID: 20102858. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.20102858
107 Dorgan JF, Liu L, Barton BA, . Adolescent diet and metabolic syndrome in young women: Results of the Dietary Intervention Study in Children (DISC) follow-up study. J Clin Endocrinol Metab. 2011;96(12):E1999–e2008. PMID: 21994964. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.21994964
108 Dove J. Effects of a multi-component school-based intervention on health markers, body composition, physical fitness, and psychological measures in overweight and obese adolescent females. Waco, Texas: Baylor University; 2008. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
109 Doyle AC, Goldschmidt A, Huang C, . Reduction of overweight and eating disorder symptoms via the Internet in adolescents: a randomized controlled trial. J Adolesc Health. 2008;43(2):172–9. PMID: 18639791. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.18639791
110 Ebbeling CB, Feldman HA, Chomitz VR, . A randomized trial of sugar-sweetened beverages and adolescent body weight. N Engl J Med. 2012;367(15):1407–16. PMID: 22998339. KQ1E1, KQ2E1, KQ3E6e, KQ4E6e, KQ5E6e.22998339
111 Ebbeling CB, Feldman HA, Osganian SK, . Effects of decreasing sugar-sweetened beverage consumption on body weight in adolescents: a randomized, controlled pilot study. Pediatrics. 2006;117(3):673–80. PMID: 16510646. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.16510646
112 Ebbeling CB, Leidig MM, Sinclair KB, . A reduced-glycemic load diet in the treatment of adolescent obesity. Arch Pediatr Adolesc Med. 2003;157(8):773–9. PMID: 12912783. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.12912783
113 Eddy LS, Moral I, Frutos E, . Evaluation of self-awareness of adolescents with overweight and obesity (Obescat Study). Pediatria Catalana. 2013;73(3):107–12. PMID: None. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
114 Eliakim A, Friedland O, Kowen G, . Parental obesity and higher pre-intervention BMI reduce the likelihood of a multidisciplinary childhood obesity program to succeed--a clinical observation. J Pediatr Endocrinol Metab. 2004;17(8):1055–61. PMID: 15379415. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.15379415
115 Eliakim A, Kaven G, Berger I, . The effect of a combined intervention on body mass index and fitness in obese children and adolescents - a clinical experience. Eur J Pediatr. 2002;161(8):449–54. PMID: 12172831. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.12172831
116 Endevelt R, Elkayam O, Cohen R, . An intensive family intervention clinic for reducing childhood obesity. J Am Board Fam Med. 2014;27(3):321–8. PMID: 24808110. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.24808110
117 Epstein LH, Kuller LH, Wing RR, . The effect of weight control on lipid changes in obese children. Am J Dis Child. 1989;143(4):454–7. PMID: 2929526. KQ1E1, KQ2E1, KQ3E10, KQ4E10, KQ5E4.2929526
118 Epstein LH, McKenzie SJ, Valoski A, . Effects of mastery criteria and contingent reinforcement for family-based child weight control. Addict Behav. 1994;19(2):135–45. PMID: 8036961. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.8036961
119 Epstein LH, Paluch RA, Gordy CC, . Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med. 2000;154(3):220–6. PMID: 10710017. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.10710017
120 Epstein LH, Paluch RA, Gordy CC, . Problem solving in the treatment of childhood obesity. J Consult Clin Psychol. 2000;68(4):717–21. PMID: 10965646. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.10965646
121 Epstein LH, Paluch RA, Kilanowski CK, . The effect of reinforcement or stimulus control to reduce sedentary behavior in the treatment of pediatric obesity. Health Psychol. 2004;23(4):371–80. PMID: 15264973. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.15264973
122 Epstein LH, Paluch RA, Wrotniak BH, . Cost-effectiveness of family-based group treatment for child and parental obesity. Child Obes. 2014;10(2):114–21. PMID: 24655212. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24655212
123 Epstein LH, Roemmich JN, Robinson JL, . A randomized trial of the effects of reducing television viewing and computer use on body mass index in young children. Arch Pediatr Adolesc Med. 2008;162(3):239–45. PMID: 18316661. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.18316661
124 Epstein LH, Valoski AM, Vara LS, . Effects of decreasing sedentary behavior and increasing activity on weight change in obese children. Health Psychol. 1995;14(2):109–15. PMID: 7789345. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.7789345
125 Escobar-Chaves SL, Markham CM, Addy RC, . The Fun Families Study: intervention to reduce children’s TV viewing. Obesity. 2010;18 Suppl 1:S99–101. PMID: 20107469. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.20107469
126 Estabrooks PA, Shoup JA, Gattshall M, . Automated telephone counseling for parents of overweight children: a randomized controlled trial. Am J Prev Med. 2009;36(1):35–42. PMID: 19095163. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19095163
127 Etu SF. A test of the compensation and capitalization models in group interpersonal psychotherapy for adolescent girls at risk for obesity. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2012;72(10-B):6412. PMID: None. KQ1E1, KQ2E1.
128 Evans WD, Christoffel KK, Necheles J, . Outcomes of the 5-4-3-2-1 Go! Childhood obesity community trial. Am J Health Behav. 2011;35(2):189–98. PMID: 21204681. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.21204681
129 Evia-Viscarra ML, Rodea-Montero ER, Apolinar-Jimenez E, . The effects of metformin on inflammatory mediators in obese adolescents with insulin resistance: controlled randomized clinical trial. J Pediatr Endocrinol. 2012;25(1–2):41–9. PMID: 22570949. KQ1E1, KQ2E1, KQ3E4, KQ4E4.22570949
130 Ewing LJ, Cluss P, Goldstrohm S, . Translating an evidence-based intervention for pediatric overweight to a primary care setting. Clin Pediatr (Phila). 2009;48(4):397–403. PMID: 19164134. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19164134
131 Fagg J, Chadwick P, Cole TJ, . From trial to population: a study of a family-based community intervention for childhood overweight implemented at scale. Int J Obes (Lond). 2014;38(10):1343–9. PMID: 24919564. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.24919564
132 Faigenbaum A, Farrell A, Radler T, . “Plyo Play”: a novel program of short bouts of moderate and high intensity exercise improves physical fitness in elementary school children. The Physical Educator. 2009;66:37–44. PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
133 Faith MS, Berman N, Heo M, . Effects of contingent television on physical activity and television viewing in obese children. Pediatrics. 2001;107(5):1043–8. PMID: 11331684. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.11331684
134 Fajcsak Z, Gabor A, Kovacs V, . The effects of 6-week low glycemic load diet based on low glycemic index foods in overweight/obese children--pilot study. J Am Coll Nutr. 2008;27(1):12–21. PMID: 18460477. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.18460477
135 Falbe J, Cadiz AA, Tantoco NK, . Active and healthy families: a randomized controlled trial of a culturally tailored obesity intervention for Latino children. Acad Pediatr. 2015;15(4):386–95. PMID: 25937516. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.25937516
136 Farpour-Lambert NJ, Aggoun Y, Marchand LM, . Physical activity reduces systemic blood pressure and improves early markers of atherosclerosis in pre-pubertal obese children. J Am Coll Cardiol. 2009;54(25):2396–406. PMID: 20082930. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.20082930
137 Figueroa-Colon R, Franklin FA, Lee JY, . Feasibility of a clinic-based hypocaloric dietary intervention implemented in a school setting for obese children. Obes Res. 1996;4(5):419–29. PMID: 8885206. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.8885206
138 Finne E, Reinehr T, Schaefer A, . Changes in self-reported and parent-reported health-related quality of life in overweight children and adolescents participating in an outpatient training: findings from a 12-month follow-up study. Health Qual of Life Outcomes. 2013;11:1. PMID: 23281620. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23281620
139 Firoozi M, Gheed Rahmat A. Virtual social network for management of obesity in children and adolescents. Iran. 2013;23:S9–s10. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
140 Flodmark CE, Ohlsson T, Ryden O, . Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91(5):880–4. PMID: 8474806. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.8474806
141 Foley L, Jiang Y, Ni Mhurchu C, . The effect of active video games by ethnicity, sex and fitness: subgroup analysis from a randomised controlled trial. Int J Behav Nutr Phys Act. 2014;11(1):46. PMID: 24694082. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.24694082
142 Follansbee-Junger K, Janicke DM, Sallinen BJ. The influence of a behavioral weight management program on disordered eating attitudes and behaviors in children with overweight. J Am Diet Assoc. 2010;110(11):1653–9. PMID: 21034878. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.21034878
143 Fonseca H, Palmeira AL, Martins SC, . Managing paediatric obesity: a multidisciplinary intervention including peers in the therapeutic process. BMC Pediatrics. 2014;14:89. PMID: 24693926. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24693926
144 Ford AL, Bergh C, Sodersten P, . Treatment of childhood obesity by retraining eating behaviour: randomised controlled trial. BMJ. 2009;340:b5388. PMID: 20051465. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.20051465
145 Fortune R, Love-Osborne K, Sheeder J. Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 2012;50(2 suppl. 1):S33. PMID: None. KQ1E1, KQ2E1, KQ5E4.
146 Foster GD, Wadden TA, Brownell KD. Peer-led program for the treatment and prevention of obesity in the schools. J Consult Clin Psychol. 1985;53(4):538–40. PMID: 4031211. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.4031211
147 Freedman DS, Shear CL, Burke GL, . Persistence of juvenile-onset obesity over eight years: the Bogalusa Heart Study. Am J Public Health. 1987;77(5):588–92. PMID: 3565653. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.3565653
148 Freemark M. Liver dysfunction in paediatric obesity: a randomized, controlled trial of metformin. Acta Paediatrica. 2007;96(9):1326–32. PMID: 17718786. KQ1E1, KQ2E1, KQ3E4.17718786
149 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 2001;107(4):E55. PMID: 11335776. KQ1E1, KQ2E1, KQ3E4.11335776
150 Fulkerson JA, Rydell S, Kubik MY, . Healthy Home Offerings via the Mealtime Environment (HOME): feasibility, acceptability, and outcomes of a pilot study. Obesity. 2010;18 Suppl 1:S69–74. PMID: 20107464. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.20107464
151 Gallagher KS, Davis AM, Malone B, . Treating rural pediatric obesity through telemedicine: baseline data from a randomized controlled trial. J Pediatr Psychol. 2011;36(6):687–95. PMID: 21372069. KQ1E1, KQ2E1, KQ3E4, KQ4E2b, KQ5E3.21372069
152 Garcia-Morales LM, Berber A, Ias-Lara CC, . Use of sibutramine in obese Mexican adolescents: A 6-month, randomized, double-blind, placebo-controlled, parallel-group trial. Clin Ther. 2006;28(5):770–82. PMID: 16861099. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.16861099
153 Garibay N, Queipo G. Metformin vs conjugated linoleic acid and an intervention program with healthy habits in obese children. NCT02063802. https://clinicaltrials.gov/ct2/show/NCT02063802?term=metformin&age=0&rank=58. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
154 Gately PJ, Cooke CB, Barth JH, . Children’s residential weight-loss programs can work: a prospective cohort study of short-term outcomes for overweight and obese children. Pediatrics. 2005;116(1):73–7. PMID: 15995034. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E6.15995034
155 Gee L, Agras WS. A randomized pilot study of a brief outpatient problem-solving intervention to promote healthy eating and activity habits in adolescents. Clin Pediatr (Phila). 2014;53(3):293–6. PMID: 23897759. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.23897759
156 Gerards SM, Dagnelie PC, Gubbels JS, . The effectiveness of lifestyle triple p in the Netherlands: a randomized controlled trial. PLoS One. 2015;10(4):e0122240. PMID: 25849523. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25849523
157 Gerards SM, Dagnelie PC, Jansen MW, . Lifestyle Triple P: a parenting intervention for childhood obesity. BMC Public Health. 2012;12:267. PMID: 22471971. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22471971
158 Gesell SB, Scott TA, Barkin SL. Accuracy of perception of body size among overweight Latino preadolescents after a 6-month physical activity skills building intervention. Clin Pediatr (Phila). 2010;49(4):323–9. PMID: 19605865. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.19605865
159 Gillette ML, Stough CO, Beck AR, . Outcomes of a weight management clinic for children with special needs. J Dev Behav Pediatr. 2014;35(4):266–73. PMID: 17924120. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.24799265
160 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. J Pediatr Endocrinol Metab. 2007;20(2):197–203. PMID: 17396436. KQ1E1, KQ2E1, KQ3E8b, KQ4E8b, KQ5E8b.17396436
161 Glasofer DR. Self-efficacy in adolescent girls at risk for overweight during an obesity prevention program. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(7-B):4420. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ5E4.
162 Godoy-Matos A, Carraro L, Vieira A, . Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90(3):1460–5. PMID: 15613431. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.15613431
163 Golan M, Fainaru M, Weizman A. Role of behaviour modification in the treatment of childhood obesity with the parents as the exclusive agents of change. Int J Obes Relat Metab Disord. 1998;22(12):1217–24. PMID: 9877257. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.9877257
164 Goldaracena-Orozco F, Torres-Alvarez B, Castanedo-Cazares J. Study of efficacy of metformin in the treatment of acanthosis nigricans in children with obesity. NCT02438020. https://clinicaltrials.gov/ct2/show/NCT02438020?term=metformin&age=0&rank=11. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
165 Goldfield GS, Epstein LH, Kilanowski CK, . Cost-effectiveness of group and mixed family-based treatment for childhood obesity. Int J Obes Relat Metab Disord. 2001;25(12):1843–9. PMID: 11781766. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.11781766
166 Goldschmidt AB, Best JR, Stein RI, . Predictors of child weight loss and maintenance among family-based treatment completers. J Consult Clin Psychol. 2014;82(6):1140–50. PMID: 24932567. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.24932567
167 Goldschmidt AB, Stein RI, Saelens BE, . Importance of early weight change in a pediatric weight management trial. Pediatrics. 2011;128(1):e33–9. PMID: 21690118. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.21690118
168 Golley RK, Magarey AM, Baur LA, . Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: a randomized, controlled trial. Pediatrics. 2007;119(3):517–25. PMID: 17332205. KQ1E1, KQ2E1, KQ3E4, KQ5E4.17332205
169 Golley RK, Magarey AM, Daniels LA. Children’s food and activity patterns following a six-month child weight management program. Int J Pediatr Obes. 2011;6(5–6):409–14. PMID: 21838569. KQ1E1, KQ2E1, KQ3E4, KQ5E4.21838569
170 Golley RK, Magarey AM, Steinbeck KS, . Comparison of metabolic syndrome prevalence using six different definitions in overweight pre-pubertal children enrolled in a weight management study. Int J Obes (Lond). 2006;30(5):853–60. PMID: 16404409. KQ1E1, KQ2E1, KQ3E4, KQ5E4.16404409
171 Golley RK, Perry RA, Magarey A, . Family-focused weight management program for five- to nine-year-olds incorporating parenting skills training with healthy lifestyle information to support behaviour modification. Nutr Diet. 2007;64(3):144–50. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ5E4.
172 Gong L, Yuan F, Teng J, . Weight loss, inflammatory markers, and improvements of iron status in overweight and obese children. J Pediatr. 2014;164(4):795–800. PMID: 24518166. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.24518166
173 Gorin AA, Wiley J, Ohannessian CM, . Steps to Growing Up Healthy: a pediatric primary care based obesity prevention program for young children. BMC Public Health. 2014;14:72. PMID: 24456698. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24456698
174 Graves T, Meyers AW, Clark L. An evaluation of parental problem-solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56(2):246–50. PMID: 3372833. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.3372833
175 Grey M, Berry D, Davidson M, . Preliminary testing of a program to prevent type 2 diabetes among high-risk youth. J Sch Health. 2004;74(1):10–5. PMID: 15022370. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.15022370
176 Gunnarsdottir T, Sigurdardottir ZG, Njardvik U, . A randomized-controlled pilot study of Epstein’s family-based behavioural treatment for childhood obesity in a clinical setting in Iceland. Nordic Psychology. 2011;63(1):6–19. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.
177 Guo SS, Roche AF, Chumlea WC, . The predictive value of childhood body mass index values for overweight at age 35 y. Am J Clin Nutr. 1994;59(4):810–9. PMID: 8147324. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.8147324
178 Guo SS, Wu W, Chumlea WC, . Predicting overweight and obesity in adulthood from body mass index values in childhood and adolescence. Am J Clin Nutr. 2002;76(3):653–8. PMID: 12198014. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.12198014
179 Gutin B. Child obesity can be reduced with vigorous activity rather than restriction of energy intake. Obesity. 2008;16(10):2193–6. PMID: 18719647. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.18719647
180 Gutin B, Barbeau P, Owens S, . Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. Am J Clin Nutr. 2002;75(5):818–26. PMID: 11976154. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.11976154
181 Guzman A, Richardson IM, Gesell S, . Recruitment and retention of Latino children in a lifestyle intervention. Am J Health Behav. 2009;33(5):581–6. PMID: 19296748. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.19296748
182 Haire-Joshu D, Nanney MS, Elliott M, . The use of mentoring programs to improve energy balance behaviors in high-risk children. Obesity (Silver Spring). 2010;18 Suppl 1:S75–83. PMID: 20107465. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.20107465
183 Hakanen M, Lagstrom H, Pahkala K, . Dietary and lifestyle counselling reduces the clustering of overweight-related cardiometabolic risk factors in adolescents. Acta Paediatr. 2010;99(6):888–95. PMID: 20002624. KQ1E1, KQ2E1, KQ3E5a, KQ4E5a, KQ5E5a.20002624
184 Hamilton-Shield J, Goodred J, Powell L, . Changing eating behaviours to treat childhood obesity in the community using Mandolean: the Community Mandolean randomised controlled trial (ComMando)--a pilot study. Health Technol Assess. 2014;18(47):i–xxiii, 1–75. PMID: 25043221. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25043221
185 Hammarlund V. Development and evaluation of a weight control program for obese preadolescent children. Fort Collins, CO: Colorado State University; 1992. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
186 Hasson RE, Adam TC, Davis JN, . Randomized controlled trial to improve adiposity, inflammation, and insulin resistance in obese African-American and Latino youth. Obesity (Silver Spring). 2012;20(4):811–8. PMID: 21293446. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.21293446
187 Hay J, Wittmeier K, Macintosh A, ., editors. Physical activity intensity and adiposity in overweight youth: A randomized controlled trial. 3rd National Obesity Summit; 2013; Vancouver, BC Canada. Search 2 CENTRAL 20160122: Elsevier. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
188 Hay J, Wittmeier K, MacIntosh A, . Physical activity intensity and type 2 diabetes risk in overweight youth: a randomized trial. Int J Obes (Lond). 2015. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
189 Herget S, Markert J, Petroff D, . Psychosocial well-being of adolescents before and after a 1-year telephone-based adiposity prevention study for families. J Adolesc Health. 2015;57(3):351–4. PMID: 26299563. KQ1E1, KQ2E1, KQ3E8, KQ4E8, KQ5E4.26299563
190 Herrera EA, Johnston CA, Steele RG. A Comparison of Cognitive and Behavioral Treatments for Pediatric Obesity. Children’s Health Care. 2004;33(2):151–67. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
191 Hills AP, Parker AW. Obesity management via diet and exercise intervention. Child Care Health Dev. 1988;14(6):409–16. PMID: 3228964. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.3228964
192 Ho M, Gow M, Baur LA, . Effect of fat loss on arterial elasticity in obese adolescents with clinical insulin resistance: RESIST study. J Clin Endocrinol Metab. 2014;99(10):E1846–53. PMID: 24955610. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24955610
193 Hoelscher DM, Springer AE, Ranjit N, . Reductions in child obesity among disadvantaged school children with community involvement: the Travis County CATCH Trial. Obesity. 2010;18:Suppl-44. PMID: 20107459. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.20107459
194 Hoffmann-La Roche. A study of xenical (orlistat) in overweight and obese adolescents. NCT00940628. https://clinicaltrials.gov/ct2/show/study/NCT00940628?term=orlistat&age=0&rank=7. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.
195 Hofsteenge GH, Chinapaw MJ, Delemarre-van de Waal HA, . Long-term effect of the Go4it group treatment for obese adolescents: a randomised controlled trial. Clin Nutr. 2014;33(3):385–91. PMID: 23810626. KQ1E1, KQ2E1, KQ5E4.23810626
196 Hofsteenge GH, Chinapaw MJ, Weijs PJ, . Go4it; study design of a randomised controlled trial and economic evaluation of a multidisciplinary group intervention for obese adolescents for prevention of diabetes mellitus type 2. BMC Public Health. 2008;8:410. PMID: 19087330. KQ1E1, KQ2E1, KQ5E4.19087330
197 Hofsteenge GH, Weijs PJ, Delemarre-van de Waal HA, . Effect of the Go4it multidisciplinary group treatment for obese adolescents on health related quality of life: a randomised controlled trial. BMC Public Health. 2013;13:939. PMID: 24103472. KQ1E1, KQ2E1, KQ4E4, KQ5E4.24103472
198 Holland JC, Kolko RP, Stein RI, . Modifications in parent feeding practices and child diet during family-based behavioral treatment improve child zBMI. Obesity (Silver Spring, Md). 2014;22(5):E119–e26. PMID: 24458836. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.24458836
199 Hollar D, Lombardo M, Lopez-Mitnik G, . Effective multi-level, multi-sector, school-based obesity prevention programming improves weight, blood pressure, and academic performance, especially among low-income, minority children. Journal of health care for the poor and underserved. 2010;21(2 Suppl):93–108. PMID: 20453379. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.20453379
200 Hollinghurst S, Hunt LP, Banks J, . Cost and effectiveness of treatment options for childhood obesity. Pediatr Obes. 2014;9(1):e26–34. PMID: 23505002. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23505002
201 Huang F, del-Rio-Navarro BE, Perez-Ontiveros JA, . Effect of six-month lifestyle intervention on adiponectin, Resistin and soluble tumor necrosis factor-alpha receptors in obese adolescents. Endocr J. 2014;61(9):921–31. PMID: 25029953. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25029953
202 Hughes AR, Stewart L, Chapple J, . Randomized, controlled trial of a best-practice individualized behavioral program for treatment of childhood overweight: Scottish Childhood Overweight Treatment Trial (SCOTT). Pediatrics. 2008;121(3):e539–46. PMID: 18310175. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.18310175
203 Hung SH, Hwang SL, Su MJ, . An evaluation of a weight-loss program incorporating E-learning for obese junior high school students. Telemed J E Health. 2008;14(8):783–92. PMID: 18954248. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.18954248
204 Hystad HT, Steinsbekk S, Odegard R, . A randomised study on the effectiveness of therapist-led v. self-help parental intervention for treating childhood obesity. Br J Nutr. 2013;110(6):1143–50. PMID: 23388524. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23388524
205 Ibanez L, Lopez-Bermejo A, Diaz M, . Early metformin therapy (age 8–12 years) in girls with precocious pubarche to reduce hirsutism, androgen excess, and oligomenorrhea in adolescence. J Clin Endocrinol Metab. 2011;96(8):E1262–e7. PMID: 21632811. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21632811
206 Ibanez L, Lopez-Bermejo A, Diaz M, . Early metformin treatment (age 8–12) in girls with precocious pubarche to prevent polycystic ovary syndrome (PCOS) in adolescence: A randomized study over 7 years. Endocr Rev. 2011;32(3). PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
207 Ildiko V, Zsofia M, Janos M, . Activity-related changes of body fat and motor performance in obese seven-year-old boys. J Physiol Anthropol. 2007;26(3):333–7. PMID: 17641452. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.17641452
208 Incledon E, Gerner B, Hay M, . Psychosocial predictors of 4-year BMI change in overweight and obese children in primary care. Obesity (Silver Spring). 2013;21(3):E262–70. PMID: 23404919. KQ1E1, KQ2E1, KQ5E4.23404919
209 Israel AC, Solotar LC, Zimand E. An investigation of two parental involvement roles in the treatment of obese children. Int J Eat Disord. 1990;9(5):557–64. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
210 Jago R, Baranowski T, Baranowski JC, . Fit for Life Boy Scout badge: outcome evaluation of a troop and Internet intervention. Prev Med. 2006;42(3):181–7. PMID: 16458955. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.16458955
211 Janicke DM, Gray WN, Mathews AE, . A pilot study examining a group-based behavioral family intervention for obese children enrolled in Medicaid: Differential outcomes by race. Children’s Health Care. 2011;40(3):212–31. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
212 Janicke DM, Sallinen BJ, Perri MG, . Comparison of parent-only vs family-based interventions for overweight children in underserved rural settings: outcomes from project STORY. Arch Pediatr Adolesc Med. 2008;162(12):1119–25. PMID: 19047538. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.19047538
213 Janicke DM, Sallinen BJ, Perri MG, . Comparison of program costs for parent-only and family-based interventions for pediatric obesity in medically underserved rural settings. J Rural Health. 2009;25(3):326–30. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.19566621
214 John R. Effects of parent-focused media interventions on body mass index, waist size, self-perception, family eating habits, and family activity habits in overweight hispanic children. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2010;70(7-B):4087. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
215 Johnson WG, Hinkle LK, Carr RE, . Dietary and exercise interventions for juvenile obesity: long-term effect of behavioral and public health models. Obes Res. 1997;5(3):257–61. PMID: 9192400. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.9192400
216 Jones RA, Kelly J, Cliff DP, . Acceptability and potential efficacy of single-sex after-school activity programs for overweight and at-risk children: the Wollongong SPORT RCT. Pediatr Exerc Sci. 2015;27(4):535–45. PMID: 26305240. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.26305240
217 Jones RA, Warren JM, Okely AD, . Process evaluation of the Hunter Illawarra Kids Challenge Using Parent Support study: a multisite randomized controlled trial for the management of child obesity. Health Promot Pract. 2010;11(6):917–27. PMID: 19158237. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19158237
218 Kalarchian MA, Levine MD, Arslanian SA, . Family-based treatment of severe pediatric obesity: randomized, controlled trial. Pediatrics. 2009;124(4):1060–8. PMID: 19786444. KQ1E1, KQ2E1, KQ5E4.19786444
219 Kalavainen M, Korppi M, Nuutinen O. Long-term efficacy of group-based treatment for childhood obesity compared with routinely given individual counselling. Int J Obes. 2011;35(4):530–3. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ5E4.
220 Kalavainen M, Utriainen P, Vanninen E, . Impact of childhood obesity treatment on body composition and metabolic profile. World J Pediatr. 2012;8(1):31–7. PMID: 22105574. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22105574
221 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31(10):1500–8. PMID: 17438555. KQ1E1, KQ2E1, KQ3E4, KQ5E4.17438555
222 Kay JP, Alemzadeh R, Langley G, . Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001;50(12):1457–61. PMID: 11735093. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b.11735093
223 Kelishadi R, Zemel MB, Hashemipour M, . Can a dairy-rich diet be effective in long-term weight control of young children? J Am Coll Nutr. 2009;28(5):601–10. PMID: 20439556. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.20439556
224 Kendall D, Vail A, Amin R, . Metformin in obese children and adolescents: the MOCA trial. J Clin Endocrinol Metab. 2013;98(1):322–9. PMID: 23175691. KQ1E1, KQ2E1, KQ3E4.23175691
225 Kerr J. Effects of Promoting Health Among Teens: A Brief General Health Program Intervention for African-American Adolescents From a Multi-Site Trial. Columbia, SC: University of South Carolina; 2010. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
226 Khan NA, Raine LB, Drollette ES, . Impact of the FITKids physical activity intervention on adiposity in prepubertal children. Pediatrics. 2014;133(4):e875–83. PMID: 24685956. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.24685956
227 Klesges RC, Obarzanek E, Klesges LM, . Memphis Girls health Enrichment Multi-site Studies (GEMS): Phase 2: design and baseline. Contemp Clin Trials. 2008;29(1):42–55. PMID: 17588824. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.17588824
228 Klesges RC, Obarzanek E, Kumanyika S, . The Memphis Girls’ health Enrichment Multi-site Studies (GEMS): an evaluation of the efficacy of a 2-year obesity prevention program in African American girls. Arch Pediatr Adolesc Med. 2010;164(11):1007–14. PMID: 21041593. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.21041593
229 Kokkvoll A, Grimsgaard S, Odegaard R, . Single versus multiple-family intervention in childhood overweight--Finnmark Activity School: a randomised trial. Arch Dis Child. 2014;99(3):225–31. PMID: 24336385. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24336385
230 Kolko RP, Teim KR, Stein RI, ., editors. Self-and parent-reported psychosocial symptoms in overweight children. 28th Annual Scientific Meeting of the Obesity Society; 2010; San Diego, CA. Search 2 CENTRAL 20160122: Blackwell Publishing Inc. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
231 Kolotourou M, Radley D, Gammon C, . Long-term outcomes following the MEND 7–13 child weight management program. Child Obes. 2015;11(3):325–30. PMID: 25764056. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25764056
232 Kong AP, Choi KC, Chan RS, . A randomized controlled trial to investigate the impact of a low glycemic index (GI) diet on body mass index in obese adolescents. BMC Public Health. 2014;14:180. PMID: 24552366. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.24552366
233 Kong AS, Sussman AL, Yahne C, . School-based health center intervention improves body mass index in overweight and obese adolescents. J Obes. 2013;2013:575016. PMID: 23589771. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23589771
234 Korsten-Reck U, Kromeyer-Hauschild K, Wolfarth B, . Freiburg Intervention Trial for Obese Children (FITOC): results of a clinical observation study. Int J Obes (Lond). 2005;29(4):356–61. PMID: 15583698. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.15583698
235 Larsen LM, Hertel NT, Molgaard C, . Early intervention for childhood overweight: A randomized trial in general practice. Scand J Prim Health Care. 2015;33(3):184–90. PMID: 26194172. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.26194172
236 Lavine JE, Schwimmer JB, Van Natta ML, . Effect of vitamin E or metformin for treatment of nonalcoholic fatty liver disease in children and adolescents: the TONIC randomized controlled trial. JAMA. 2011;305(16):1659–68. PMID: 21521847. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21521847
237 Lazorick S, Fang X, Hardison GT, . Improved Body Mass Index Measures Following a Middle School-Based Obesity Intervention--The MATCH Program. J School Health. 2015;85(10):680–7. PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.26331750
238 Lee A, Ho M, Keung VM, . Childhood obesity management shifting from health care system to school system: intervention study of school-based weight management programme. BMC Public Health. 2014;14:1128. PMID: 25363153. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a.25363153
239 Lee S, Misra R, Kaster E. Active Intervention Program Using Dietary Education and Exercise Training for Reducing Obesity in Mexican American Male Children. Health Educator. 2012;44(1):2–13. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
240 Libman IM, Miller KM, DiMeglio LA, . Effect of metformin added to insulin on glycemic control among overweight/obese adolescents with type 1 diabetes: a randomized clinical trial. JAMA. 2015;314(21):2241–50. PMID: 26624824. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.26624824
241 Lison JF, Real-Montes JM, Torro I, . Exercise intervention in childhood obesity: a randomized controlled trial comparing hospital-versus home-based groups. Acad Pediatr. 2012;12(4):319–25. PMID: 22634075. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22634075
242 Litwin SE, Pollock N, Waller J, . Effects of aerobic training on arterial stiffness in overweight minority children: A randomized controlled trial. Circulation. 2013;128(22 suppl. 1). PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
243 Lochrie AS, Buckloh LM, Antal H, . Emotional and behavioral functioning in obese children participating in a 14-week lifestyle intervention to prevent DM2. 2010. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.
244 Lochrie AS, Wysocki T, Buckloh LM, . Effects of a family based intervention study for overweight children: 6 month medical outcome data. 2010. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.
245 Lochrie AS, Wysocki T, Hossain J, . The effects of a family-based intervention (FBI) for overweight/obese children on health and psychological functioning. Clin Pract Pediatr Psychol. 2013;1(2):159–70. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.
246 Loeb KL, Doyle AC, Anderson K, . Family-based treatment for child and adolescent overweight and obesity: A transdevelopmental approach. Family therapy for adolescent eating and weight disorders: New applications. New York, NY: Routledge/Taylor & Francis Group; US; 2015. p. 177–229. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
247 Looney SM, Raynor HA. Examining the effect of three low-intensity pediatric obesity interventions: a pilot randomized controlled trial. Clin Pediatr (Phila). 2014;53(14):1367–74. PMID: 25006118. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25006118
248 Love-Osborne K, Fortune R, Sheeder J, . School-based health center-based treatment for obese adolescents: feasibility and body mass index effects. Child Obes. 2014;10(5):424–31. PMID: 25259781. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25259781
249 Love-Osborne K, Sheeder J, Zeitler P. Addition of metformin to a lifestyle modification program in adolescents with insulin resistance. J Pediatr. 2008;152(6):817–22. PMID: 18492523. KQ1E1, KQ2E1, KQ3E4.18492523
250 Lubans DR, Morgan PJ, Collins CE, . Mediators of weight loss in the ‘Healthy Dads, Healthy Kids’ pilot study for overweight fathers. Int J Behav Nutr Phys Act. 2012;9:45. PMID: 22512861. KQ1E1, KQ2E1, KQ3E5a, KQ4E5a, KQ5E5a.22512861
251 Luca P, Dettmer E, Khoury M, . Adolescents with severe obesity: outcomes of participation in an intensive obesity management programme. Pediatr Obes. 2015;10(4):275–82. PMID: 25236943. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.25236943
252 Luna-Pech JA, Torres-Mendoza BM, Luna-Pech JA, . Normocaloric diet improves asthma-related quality of life in obese pubertal adolescents. Int Arch Allergy Immunol. 2014;163(4):252–8. PMID: 24713632. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E4.24713632
253 Luszczynska A, Horodyska K, Zarychta K, . Planning and self-efficacy interventions encouraging replacing energy-dense foods intake with fruit and vegetable: A longitudinal experimental study. Psychol Health. 2016;31(1):40–64. PMID: 26160226. KQ1E1, KQ2E1, KQ3E4, KQ4E6a, KQ5E4.26160226
254 Maahs D, de Serna DG, Kolotkin RL, . Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocr Pract. 2006;12(1):18–28. PMID: 16524859. KQ1E1, KQ2E1.16524859
255 Maddison R, Foley L, Mhurchu CN, . Feasibility, design and conduct of a pragmatic randomized controlled trial to reduce overweight and obesity in children: The electronic games to aid motivation to exercise (eGAME) study. BMC Public Health. 2009;9:146. PMID: 19450288. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.19450288
256 Maddison R, Foley L, Ni Mhurchu C, . Effects of active video games on body composition: a randomized controlled trial. Am J Clin Nutr. 2011;94(1):156–63. PMID: 21562081. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.21562081
257 Maddison R, Marsh S, Foley L, . Screen-Time Weight-loss Intervention Targeting Children at Home (SWITCH): a randomized controlled trial. Int J Behav Nutr Phys Act. 2014;11:111. PMID: 25204320. KQ1E1, KQ2E1, KQ3E4, KQ4E2b, KQ5E4.25204320
258 Maddison R, Mhurchu CN, Foley L, . Screen-time weight-loss intervention targeting children at home (SWITCH): a randomized controlled trial study protocol. BMC Public Health. 2011;11:524. PMID: 21718543. KQ1E1, KQ2E1, KQ3E4, KQ4E2b, KQ5E4.21718543
259 Maddison R, Mhurchu CN, Jull A, . Active video games: the mediating effect of aerobic fitness on body composition. Int J Behav Nutr Phys Act. 2012;9:54. PMID: 22554052. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.22554052
260 Madsen KA, Garber AK, Mietus-Snyder ML, . A clinic-based lifestyle intervention for pediatric obesity: efficacy and behavioral and biochemical predictors of response. J Pediatr Endocrinol Metab. 2009;22(9):805–14. PMID: 19960890. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19960890
261 Magarey AM, Perry RA, Baur LA, . A parent-led family-focused treatment program for overweight children aged 5 to 9 years: the PEACH RCT. Pediatrics. 2011;127(2):214–22. PMID: 21262890. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.21262890
262 Maloney AE, Bethea TC, Kelsey KS, . A pilot of a video game (DDR) to promote physical activity and decrease sedentary screen time. Obesity (Silver Spring). 2008;16(9):2074–80. PMID: 19186332. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.19186332
263 Manley D. Self-efficacy, Physical Activity, and Aerobic Fitness in Middle School Children: Examination of a Pedometer Intervention Program Memphis, TN: University of Tennessee; 2008. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
264 Marcus C. Effect of exercise or metformin on nocturnal blood pressure and other risk factors for CVD among obese adolescents. NCT00889876. https://clinicaltrials.gov/ct2/show/NCT00889876?term=metformin&age=0&rank=59. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
265 Marild S, Gronowitz E, Forsell C, . A controlled study of lifestyle treatment in primary care for children with obesity. Pediatr Obes. 2013;8(3):207–17. PMID: 23172847. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.23172847
266 Markert J, Alff F, Zschaler S, . Prevention of childhood obesity: recruiting strategies via local paediatricians and study protocol for a telephone-based counselling programme. Obes Res Clin Pract. 2013;7(6):e476–86. PMID: 24308890. KQ1E1, KQ2E1, KQ3E8, KQ4E8, KQ5E4.24308890
267 Markert J, Herget S, Petroff D, . Telephone-based adiposity prevention for families with overweight children (T.A.F.F.-Study): one year outcome of a randomized, controlled trial. Int J Environ Res Public Health. 2014;11(10):10327–44. PMID: 25286167. KQ1E1, KQ2E1, KQ3E8, KQ4E8, KQ5E4.25286167
268 Martinez-Andrade GO, Cespedes EM, Rifas-Shiman SL, . Feasibility and impact of Creciendo Sanos, a clinic-based pilot intervention to prevent obesity among preschool children in Mexico City. BMC Pediatrics. 2014;14:77. PMID: 24649831. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.24649831
269 Mauras N, DelGiorno C, Hossain J, . Metformin use in children with obesity and normal glucose tolerance--effects on cardiovascular markers and intrahepatic fat. J Pediatr Endocrinol Metab. 2012;25(1–2):33–40. PMID: 22570948. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22570948
270 Mazzeo SE, Kelly NR, Stern M, . Parent skills training to enhance weight loss in overweight children: evaluation of NOURISH. Eat Behav. 2014;15(2):225–9. PMID: 24854808. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.24854808
271 Mazzeo SE, Kelly NR, Stern M, . Nourishing Our Understanding of Role Modeling to Improve Support and Health (NOURISH): design and methods. Contemp Clin Trials. 2012;33(3):515–22. PMID: 22273843. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.22273843
272 Mazzeo SE, Kelly NR, Thornton L, . Parent skills training to enhance weight loss in overweight children: Evaluation of NOURISH. Obesity (Silver Spring, Md). 2011;19:S106. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
273 McCallum Z, Wake M, Gerner B, . Outcome data from the LEAP (Live, Eat and Play) trial: a randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes (Lond). 2007;31(4):630–6. PMID: 17160087. KQ1E1, KQ2E1.17160087
274 McCallum Z, Wake M, Gerner B, . Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. J Paediatr Child Health. 2005;41(9–10):488–94. PMID: 16150065. KQ1E1, KQ2E1.16150065
275 McCormick DP, Ramirez M, Caldwell S, . YMCA program for childhood obesity: a case series. Clin Pediatr (Phila). 2008;47(7):693–7. PMID: 18448625. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.18448625
276 McDuffie J, Calis K, Uwaifo G, . Efficacy of orlistat as an adjunct to behavioral treatment in overweight African American and Caucasian adolescents with obesity-related co-morbid conditions. J Pediatr Endocrinol Metab. 2004;17(3):307–19. PMID: 15112907. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.15112907
277 McDuffie JR, Calis KA, Uwaifo GI, . Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10(7):642–50. PMID: 12105286. KQ1E1, KQ2E1, KQ3E3.12105286
278 Mellin LM, Slinkard LA, Irwin CE, Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program. J Am Diet Assoc. 1987;87(3):333–8. PMID: 3819254. KQ1E1, KQ2E1, KQ3E4, KQ5E4.3819254
279 Melnyk BM, Jacobson D, Kelly SA, . Twelve-month effects of the COPE healthy lifestyles TEEN program on overweight and depressive symptoms in high school adolescents. J Sch Health. 2015;85(12):861–70. PMID: 26522175. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.26522175
280 Meyer AA, Kundt G, Lenschow U, . Improvement of early vascular changes and cardiovascular risk factors in obese children after a six-month exercise program. J Am Coll Cardiol. 2006;48(9):1865–70. PMID: 17084264. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.17084264
281 Miedema B, Reading SA, Hamilton RA, . Can certified health professionals treat obesity in a community-based programme? A quasi-experimental study. BMJ Open. 2015;5(2):e006650. PMID: 25652801. KQ1E1, KQ2E1, KQ3E5a, KQ4E5a, KQ5E5a.25652801
282 Minossi V, Cecchetto FH, Pellanda LC. Healthy habits education for overweight children impacts both children and caregivers: A randomized clinical trial. Glob Heart. 2014;9(Suppl 1):e226–e7. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a.
283 Moens E, Braet C. Training parents of overweight children in parenting skills: a 12-month evaluation. Behav Cogn Psychother. 2012;40(1):1–18. PMID: 21740603. KQ1E1, KQ2E1, KQ3E4, KQ4E8a, KQ5E4.21740603
284 Monika Siegrist M, Hanssen H, Lammel C, ., editors. Changes in fitness, body weight and inflammatory markers in children: Longitudinal results of a comprehensive school-based intervention study (JuvenTUM 3). EuroPRevent; 2013 Apr 18–20; Rome, Italy. Search 2 CENTRAL 20160122: SAGE Publications Inc. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
285 Moore BA, O’Donohue WT. Evaluating a web-based cognitive behavioral intervention for the prevention and treatment of pediatric obesity. Stepped care and e-health: Practical applications to behavioral disorders. New York, NY: Springer Science + Business Media; US; 2011. p. 137–49. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
286 Morgan PJ, Lubans DR, Callister R, . The ‘Healthy Dads, Healthy Kids’ randomized controlled trial: efficacy of a healthy lifestyle program for overweight fathers and their children. Int J Obes (Lond). 2011;35(3):436–47. PMID: 20697417. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.20697417
287 Morgan PJ, Lubans DR, Plotnikoff RC, . The ‘Healthy Dads, Healthy Kids’ community effectiveness trial: study protocol of a community-based healthy lifestyle program for fathers and their children. BMC Public Health. 2011;11:876. PMID: 22099889. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.22099889
288 Mo-suwan L, Junjana C, Puetpaiboon A. Increasing obesity in school children in a transitional society and the effect of the weight control program. Southeast Asian J Trop Med Public Health. 1993;24(3):590–4. PMID: 7605404. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a.7605404
289 Muller MJ, Asbeck I, Mast M, . Prevention of obesity--more than an intention. Concept and first results of the Kiel Obesity Prevention Study (KOPS). Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S66–74. PMID: 11466593. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.11466593
290 Murphy E, Carson L, Neal W, . Effects of an exercise intervention using Dance Dance Revolution on endothelial function and other risk factors in overweight children. Int J Pediatr Obes. 2009;4(4):205–14. PMID: 19922034. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.19922034
291 Naar-King S, Ellis D, Kolmodin K, . A randomized pilot study of multisystemic therapy targeting obesity in African-American adolescents. J Adolesc Health. 2009;45(4):417–9. PMID: 19766948. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19766948
292 Nadeau KJ, Chow K, Alam S, . Effects of low dose metformin in adolescents with type I diabetes mellitus: A randomized, double-blinded placebo-controlled study. Pediatr Diabetes. 2015;16(3):196–203. PMID: 24698216. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.24698216
293 Nadeau KJ, Miller KM, Dimeglio LA, ., editors. Effect of metformin on cardiovascular risk factors in overweight and obese adolescents with type 1 diabetes. 75th Scientific Sessions of the American Diabetes Association; 2015; Boston, MA. Search 2 CENTRAL 20160122: American Diabetes Association Inc. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.
294 Nemet D, Barkan S, Epstein Y, . Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443–e9. PMID: 15805347. KQ1E1, KQ2E1, KQ3E4, KQ5E4.15805347
295 Nemet D, Levi L, Pantanowitz M, . A combined nutritional-behavioral-physical activity intervention for the treatment of childhood obesity--a 7-year summary. J Pediatr Endocrinol Metab. 2014;27(5–6):445–51. PMID: 24464474. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.24464474
296 Nguyen B, McGregor KA, O’Connor J, . Recruitment challenges and recommendations for adolescent obesity trials. J Paediatr Child Health. 2012;48(1):38–43. PMID: 22250828. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22250828
297 Nguyen B, Shrewsbury V, Lau C, . Adolescent and parent views of an adolescent weight management program: Lessons from the Loozit randomised controlled trial. Obesity research & clinical practice. 2012;6:56. PMID: None. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
298 Nguyen B, Shrewsbury VA, O’Connor J, . A process evaluation of an adolescent weight management intervention: findings and recommendations. Health Promot Int. 2015;30(2):201–12. PMID: 25550288. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25550288
299 Nguyen B, Shrewsbury VA, O’Connor J, . Twelve-month outcomes of the loozit randomized controlled trial: a community-based healthy lifestyle program for overweight and obese adolescents. Arch Pediatr Adolesc Med. 2012;166(2):170–7. PMID: 22312175. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22312175
300 Ni Mhurchu C, Roberts V, Maddison R, . Effect of electronic time monitors on children’s television watching: pilot trial of a home-based intervention. Prev Med. 2009;49(5):413–7. PMID: 19744507. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.19744507
301 Ning Y, Yang S, Evans RK, . Changes in body anthropometry and composition in obese adolescents in a lifestyle intervention program. Eur J Nutr. 2014;53(4):1093–102. PMID: 24212451. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24212451
302 Norgren S, Danielsson P, Jurold R, . Orlistat treatment in obese prepubertal children: a pilot study. Acta Paediatr. 2003;92(6):666–70. PMID: 12856974. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.12856974
303 Norman G, Huang J, Davila EP, . Outcomes of a 1-year randomized controlled trial to evaluate a behavioral ‘stepped-down’ weight loss intervention for adolescent patients with obesity. Pediatr Obes. 2016;11(1):18–25. PMID: 25702630. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25702630
304 Novotny R, Nigg CR, Li F, . Pacific kids DASH for health (PacDASH) randomized, controlled trial with DASH eating plan plus physical activity improves fruit and vegetable intake and diastolic blood pressure in children. Child Obes. 2015;11(2):177–86. PMID: 25671796. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.25671796
305 Nowicka P, Hoglund P, Pietrobelli A, . Family Weight School treatment: 1-year results in obese adolescents. Int J Pediatr Obes. 2008;3(3):141–7. PMID: 18608623. KQ1E1, KQ2E1, KQ3E4, KQ5E4.18608623
306 Nowicka P, Lanke J, Pietrobelli A, . Sports camp with six months of support from a local sports club as a treatment for childhood obesity. Scand J Public Health. 2009;37(8):793–800. PMID: 19717572. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E6.19717572
307 Nuutinen O. Long-term effects of dietary counselling on nutrient intake and weight loss in obese children. Eur J Clin Nutr. 1991;45(6):287–97. PMID: 1915202. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.1915202
308 Nwosu BU, Maranda L, Cullen K, . A randomized, double-blind, placebo-controlled trial of adjunctive metformin therapy in overweight/obese youth with type 1 diabetes. PLoS ONE. 2015;10(9):e0137525. PMID: 26367281. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.26367281
309 O’Connor JN, Golley RK, Perry RA, . A longitudinal investigation of overweight children’s body perception and satisfaction during a weight management program. Appetite. 2015;85:48–51. PMID: 25447017. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.25447017
310 O’Connor TM, Hilmers A, Watson K, . Feasibility of an obesity intervention for paediatric primary care targeting parenting and children: Helping HAND. Child Care Health Dev. 2013;39(1):141–9. PMID: 22066521. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22066521
311 Olson WA. Internet technology and social support: Are they beneficial for overweight older adolescents? Dissertation Abstracts International: Section B: The Sciences and Engineering. 2011;72(2-B):1171. PMID: None. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
312 O’Malley CL, Moore HJ, Batterham AM, ., editors. The TeesCAKE intervention. 20th European Congress on Obesity (ECO); 2013; Liverpool, UK. Search 2 CENTRAL 20160122: S. Karger AG. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.
313 O’Malley G. Aerobic exercise enhances executive function and academic achievement in sedentary, overweight children aged 7–11 years. J Physiother. 2011;57(4):255. PMID: 22093124. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.22093124
314 Omorou AY, Langlois J, Lecomte E, . Adolescents’ physical activity and sedentary behavior: a pathway in reducing overweight and obesity. The PRALIMAP 2-year cluster randomized controlled trial. J Phys Act Health. 2015;12(5):628–35. PMID: 25393601. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.25393601
315 Onnerfalt J, Erlandsson L, Orban K, ., editors. Loops-Lund overweight and obesity preschool study: An intervention involving parents of preschool children with obesity has a long-term effect on the weight development of targeted children. 22nd Congress of the European Congress on Obesity (ECO); 2015; Prague, Czech Republic. Search 2 CENTRAL 20160122: S. Karger AG. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
316 Onnerfalt J, Erlandsson LK, Orban K, . A family-based intervention targeting parents of preschool children with overweight and obesity: conceptual framework and study design of LOOPS- Lund overweight and obesity preschool study. BMC Public Health. 2012;12:879. PMID: 23072247. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23072247
317 Orban K, Ellegard K, Thorngren-Jerneck K, . Shared patterns of daily occupations among parents of children aged 4–6 years old with obesity. Journal of Occupational Science. 2012;19(3):241–57. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
318 Ordovas K, Saloner D. Cardiovascular effects of metformin on obesity. NCT01910246. https://clinicaltrials.gov/ct2/show/NCT01910246?term=metformin&age=0&rank=9. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
319 Owens S, Gutin B, Allison J, . Effect of physical training on total and visceral fat in obese children. Med Sci Sports Exerc. 1999;31(1):143–8. PMID: 9927022. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.9927022
320 Owens SG, Garner JC, 3rd, Loftin JM, . Changes in physical activity and fitness after 3 months of home Wii Fit use. J Strength Cond Res. 2011;25(11):3191–7. PMID: 21993031. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.21993031
321 Ozkan B, Bereket A, Turan S, . Addition of orlistat to conventional treatment in adolescents with severe obesity. Eur J Pediatr. 2004;163(12):738–41. PMID: 15378354. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.15378354
322 Page a. The effect of a multidimensional weight management program for children. Salt Lake City, UT: The University of Utah; 1985. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.
323 Parks EP, Zemel B, Moore RH, . Change in body composition during a weight loss trial in obese adolescents. Pediatr Obes. 2014;9(1):26–35. PMID: 23382092. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.23382092
324 Parra-Medina D, Mojica C, Liang Y, . Promoting weight maintenance among overweight and obese hispanic children in a rural practice. Child Obes. 2015;11(4):355–63. PMID: 25950140. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.25950140
325 Pasquali R, Gambineri A, Biscotti D, . Effect of long-term treatment with metformin added to hypocaloric diet on body composition, fat distribution, and androgen and insulin levels in abdominally obese women with and without the polycystic ovary syndrome. J Clin Endocrinol Metab. 2000;85(8):2767–74. PMID: 10946879. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E5b.10946879
326 Patrick K, Calfas KJ, Norman GJ, . Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Pediatr Adolesc Med. 2006;160(2):128–36. PMID: 16461867. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.16461867
327 Patrick K, Norman GJ, Davila EP, . Outcomes of a 12-month technology-based intervention to promote weight loss in adolescents at risk for type 2 diabetes. J Diabetes Sci Technol. 2013;7(3):759–70. PMID: 23759410. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E4.23759410
328 Pbert L, Druker S, Gapinski MA, ., editors. School nurse-delivered intervention for overweight and obese adolescents: Outcomes from a randomized controlled trial. 28th Annual Scientific Meeting of the Obesity Society; 2010; San Diego, CA. Search 2 CENTRAL 20160122: Blackwell Publishing Inc. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
329 Pbert L, Druker S, Gapinski MA, . A school nurse-delivered intervention for overweight and obese adolescents. J Sch Health. 2013;83(3):182–93. PMID: 23343319. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23343319
330 Pettman T, Magarey A, Mastersson N, . Improving weight status in childhood: results from the eat well be active community programs. Int J Public Health. 2014;59(1):43–50. PMID: 23529384. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.23529384
331 Quattrin T, Roemmich JN, Paluch R, . Efficacy of family-based weight control program for preschool children in primary care. Pediatrics. 2012;130(4):660–6. PMID: 22987879. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22987879
332 Quattrin T, Roemmich JN, Paluch R, . Treatment outcomes of overweight children and parents in the medical home. Pediatrics. 2014;134(2):290–7. PMID: 25049340. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25049340
333 Raynor HA, Osterholt KM, Hart CN, . Efficacy of U.S. paediatric obesity primary care guidelines: two randomized trials. Pediatr Obes. 2012;7(1):28–38. PMID: 22434737. KQ1E1, KQ2E1, KQ3E4.22434737
334 Reinehr T, de SG, Toschke AM, . Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 2006;84(3):490–6. PMID: 16960161. KQ1E1, KQ2E1, KQ3E4, KQ5E4.16960161
335 Reinehr T, Kleber M, Toschke AM. Lifestyle intervention in obese children is associated with a decrease of the metabolic syndrome prevalence. Atherosclerosis. 2009;207(1):174–80. PMID: 19442975. KQ1E1, KQ2E1, KQ3E4, KQ5E4.19442975
336 Reinehr T, Schaefer A, Winkel K, . Development and evaluation of the lifestyle intervention “obeldicks light” for overweight children and adolescents. J Public Health (Oxf). 2011;19(4):377–84. PMID: None. KQ1E1, KQ2E1, KQ3E4.
337 Reinehr T, Schaefer A, Winkel K, . An effective lifestyle intervention in overweight children: findings from a randomized controlled trial on “Obeldicks light”. Clin Nutr. 2010;29(3):331–6. PMID: 20106567. KQ1E1, KQ2E1, KQ3E4.20106567
338 Reinehr T, Temmesfeld M, Kersting M, . Four-year follow-up of children and adolescents participating in an obesity intervention program. Int J Obes (Lond). 2007;31(7):1074–7. PMID: 17471300. KQ1E1, KQ2E1, KQ3E4, KQ5E4.17471300
339 Resnicow K, McMaster F, Bocian A, . Motivational interviewing and dietary counseling for obesity in primary care: an RCT. Pediatrics. 2015;135(4):649–57. PMID: 25825539. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25825539
340 Resnicow K, McMaster F, Woolford S, . Study design and baseline description of the BMI2 trial: reducing paediatric obesity in primary care practices. Pediatr Obes. 2012;7(1):3–15. PMID: 22434735. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22434735
341 Rezvanian H, Hashemipour M, Kelishadi R, . A randomized, triple masked, placebo-controlled clinical trial for controlling childhood obesity. World J Pediatr. 2010;6(4):317–22. PMID: 21080144. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.21080144
342 Rhee KE, Phan TL, Barnes RF, . A delayed-control trial examining the impact of body mass index recognition on obesity-related counseling. Clin Pediatr (Phila). 2013;52(9):836–44. PMID: 23754841. KQ1E4, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23754841
343 Rhodes RE, Naylor PJ, McKay HA. Pilot study of a family physical activity planning intervention among parents and their children. J Behav Med. 2010;33(2):91–100. PMID: 19937106. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.19937106
344 Richmond SA, Emery CA, Doyle-Baker T, . Examining a sport injury and obesity intervention program in junior high school. Clin J Sport Med. 2012;22(3):304–5. PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
345 Riddiford-Harland DL, Steele JR, Cliff DP, . Does participation in a physical activity program impact upon the feet of overweight and obese children? J Sci Med Sport. 2016;19(1):51–5. PMID: 25499915. KQ1E1, KQ2E1, KQ3E4, KQ4E3, KQ5E4.25499915
346 Robertson W, Friede T, Blissett J, . Pilot of “Families for Health”: community-based family intervention for obesity. Arch Dis Child. 2008;93(11):921–6. PMID: 18463121. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.18463121
347 Robinson TN, Killen JD, Kraemer HC, . Dance and reducing television viewing to prevent weight gain in African-American girls: the Stanford GEMS pilot study. Ethn Dis. 2003;13(1 Suppl 1):S65–77. PMID: 12713212. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.12713212
348 Robinson TN, Kraemer HC, Matheson DM, . Stanford GEMS phase 2 obesity prevention trial for low-income African-American girls: design and sample baseline characteristics. Contemp Clin Trials. 2008;29(1):56–69. PMID: 17600772. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.17600772
349 Robinson TN, Matheson DM, Kraemer HC, . A randomized controlled trial of culturally tailored dance and reducing screen time to prevent weight gain in low-income African American girls: Stanford GEMS. Arch Pediatr Adolesc Med. 2010;164(11):995–1004. PMID: 21041592. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.21041592
350 Rocchini AP, Katch V, Anderson J, . Blood pressure in obese adolescents: effect of weight loss. Pediatrics. 1988;82(1):16–23. PMID: 2668763. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.3288957
351 Rocchini AP, Katch V, Schork A, . Insulin and blood pressure during weight loss in obese adolescents. Hypertension. 1987;10(3):267–73. PMID: 3305355. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.3305355
352 Roemmich JN, Gurgol CM, Epstein LH. Open-loop feedback increases physical activity of youth. Med Sci Sports Exerc. 2004;36(4):668–73. PMID: 15064595. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.15064595
353 Rooney BL, Gritt LR, Havens SJ, . Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104(5):54–60. PMID: 16138517. KQ1E1, KQ2E1, KQ3E4, KQ4E2b, KQ5E4.16138517
354 Rosado JL, del RAM, Montemayor K, . An increase of cereal intake as an approach to weight reduction in children is effective only when accompanied by nutrition education: a randomized controlled trial. Nutr J. 2008;7:28. PMID: 18783622. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.18783622
355 Rudolf M, Christie D, McElhone S, . WATCH IT: a community based programme for obese children and adolescents. Arch Dis Child. 2006;91(9):736–9. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ5E4.16531453
356 Ruotsalainen H, Kaariainen M, Tammelin T, ., editors. Facebook-delivered physical activity promotion intervention for overweight and obese adolescents. 21st European Congress on Obesity (ECO); 2014 May 28–31; Sofia, Bulgaria. Search 2 CENTRAL 20160122. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
357 Rynders C, Weltman A, Delgiorno C, . Lifestyle intervention improves fitness independent of metformin in obese adolescents. Med Sci Sports Exerc. 2012;44(5):786–92. PMID: 22015710. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.22015710
358 Saakslahti A, Numminen P, Salo P, . Effects of a three-year intervention on children’s physical activity from age 4 to 7. Pediatr Exerc Sci. 2004;16(2):167–80. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
359 Sacher PM, Kolotourou M, Chadwick PM, . Randomized controlled trial of the MEND program: a family-based community intervention for childhood obesity. Obesity (Silver Spring). 2010;18 Suppl 1. PMID: 20107463. KQ1E1, KQ2E1.20107463
360 Saelens BE, Sallis JF, Wilfley DE, . Behavioral weight control for overweight adolescents initiated in primary care. Obes Res. 2002;10(1):22–32. PMID: 11786598. KQ1E1, KQ2E1, KQ3E4.11786598
361 Sanders MR. Triple P-Positive Parenting Program: towards an empirically validated multilevel parenting and family support strategy for the prevention of behavior and emotional problems in children. Clin Child Fam Psychol Rev. 1999;2(2):71–90. PMID: 11225933. KQ1E1, KQ2E1, KQ3E4, KQ5E4.11225933
362 Savoye M, Caprio S, Dziura J, . Reversal of early abnormalities in glucose metabolism in obese youth: results of an intensive lifestyle randomized controlled trial. Diabetes Care. 2014;37(2):317–24. PMID: 24062325. KQ1E1, KQ2E1, KQ3E4, KQ5E4.24062325
363 Savoye M, Caprio S, Dziura J, . A community-based intervention for diabetes risk reduction in innercity obese adolescents. Diabetologia. 2013;56:S342. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ5E4.
364 Savoye M, Nowicka P, Shaw M, . Long-term results of an obesity program in an ethnically diverse pediatric population. Pediatrics. 2011;127(3):402–10. PMID: 21300674. KQ1E1, KQ2E1, KQ3E4, KQ5E4.21300674
365 Savoye M, Shaw M, Dziura J, . Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697–704. PMID: 17595270. KQ1E1, KQ2E1, KQ3E4, KQ5E4.17595270
366 Schaefer A, Winkel K, Finne E, . An effective lifestyle intervention in overweight children: one-year follow-up after the randomized controlled trial on “Obeldicks light”. Clin Nutr. 2011;30(5):629–33. PMID: 21514017. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.21514017
367 Schranz N, Tomkinson G, Parletta N, . Can resistance training change the strength, body composition and self-concept of overweight and obese adolescent males? A randomised controlled trial. BJSM online. 2014;48(20):1482–8. PMID: 23945035. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.23945035
368 Schwartz RP, Hamre R, Dietz WH, . Office-based motivational interviewing to prevent childhood obesity: a feasibility study. Arch Pediatr Adolesc Med. 2007;161(5):495–501. PMID: 17485627. KQ1E1, KQ2E1, KQ3E4, KQ4E8a, KQ5E4.17485627
369 Schwingshandl J, Sudi K, Eibl B, . Effect of an individualised training programme during weight reduction on body composition: a randomised trial. Arch Dis Child. 1999;81(5):426–8. PMID: 10519718. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.10519718
370 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behav Psychother. 1985;13(4):287. PMID: None. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.
371 Serra-Paya N, Ensenyat A, Castro-Vinuales I, . Effectiveness of a multi-component intervention for overweight and obese children (Nereu Program): a randomized controlled trial. PLoS ONE. 2015;10(12):e0144502. PMID: 26658988. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.26658988
372 Shaikh U, Berrong J, Nettiksimmons J, . Impact of Electronic Health Record Clinical Decision Support on the Management of Pediatric Obesity. Am J Med Qual. 2014. PMID: 24418755. KQ1E7, KQ2E7, KQ3E1, KQ4E1, KQ5E1.24418755
373 Sharma S, Fleming SE. One-year change in energy and macronutrient intakes of overweight and obese inner-city African American children: effect of community-based Taking Action Together type 2 diabetes prevention program. Eat Behav. 2012;13(3):271–4. PMID: 22664410. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.22664410
374 Shaw M, Savoye M, Cali A, . Effect of a successful intensive lifestyle program on insulin sensitivity and glucose tolerance in obese youth. Diabetes Care. 2009;32(1):45–7. PMID: 18840769. KQ1E4, KQ2E4, KQ3E4, KQ5E4.18840769
375 Sherwood NE, JaKa MM, Crain AL, . Pediatric primary care-based obesity prevention for parents of preschool children: a pilot study. Child Obes. 2015;11(6):674–82. PMID: 26478951. KQ1E1, KQ2E1, KQ3E4, KQ5E4.26478951
376 Siegrist M, Hanssen H, Lammel C, . Effects of the school-based intervention programme JuvenTUM 3 on physical fitness, physical activity, and the prevalence of overweight. Eur J Prev Cardiol. 2012;19(Suppl 1):S2. PMID: None. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
377 Sigal RJ, Alberga AS, Goldfield GS, . Effects of aerobic training, resistance training, or both on percentage body fat and cardiometabolic risk markers in obese adolescents: the healthy eating aerobic and resistance training in youth randomized clinical trial. JAMA Pediatr. 2014;168(11):1006–14. PMID: 25243536. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.25243536
378 Simons M, Chinapaw MJ, van de Bovenkamp M, . Active video games as a tool to prevent excessive weight gain in adolescents: rationale, design and methods of a randomized controlled trial. BMC Public Health. 2014;14:275. PMID: 24661535. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.24661535
379 Skelton JA. Erratum: randomised controlled trial: family intervention focused on effective parenting is associated with decreased child obesity prevalence 3–5 years later. Evid Based Med. 2015;20(1):34. PMID: None. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.
380 Skouteris H, Hill B, McCabe M, . Recruitment evaluation of a preschooler obesity-prevention intervention. Early Child Development and Care. 2014;184(5):649–57. PMID: None. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.
381 Slusser W, Frankel F, Robison K, . Pediatric overweight prevention through a parent training program for 2–4 year old Latino children. Child Obes. 2012;8(1):52–9. PMID: 22799481. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.22799481
382 Small L, Bonds-McClain D, Melnyk B, . The preliminary effects of a primary care-based randomized treatment trial with overweight and obese young children and their parents. J Pediatr Health Care. 2014;28(3):198–207. PMID: 23511090. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.23511090
383 Smith KL, Kerr DA, Howie EK, . Do overweight adolescents adhere to dietary intervention messages? Twelve-month detailed dietary outcomes from Curtin University’s activity, food and attitudes program. Nutrients. 2015;7(6):4363–82. PMID: 26043035. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.26043035
384 Solis L, Ponte L, Martinez D, . Effects of telephone intervention on inflammatory cytokines following summer lifestyle intervention program. Exp Biol. 2015;29. PMID: None. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.
385 Sonneville KR, Rifas-Shiman SL, Kleinman KP, . Associations of obesogenic behaviors in mothers and obese children participating in a randomized trial. Obesity (Silver Spring). 2012;20(7):1449–54. PMID: 22349735. KQ1E1, KQ2E1, KQ3E4, KQ5E4.22349735
386 Sothern MS, Loftin JM, Udall JN, . Safety, feasibility, and efficacy of a resistance training program in preadolescent obese children. Am J Med Sci. 2000;319(6):370–5. PMID: 10875292. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.10875292
387 Sousa P, Fonseca H, Gaspar P, . Controlled trial of an Internet-based intervention for overweight teens (Next.Step): effectiveness analysis. Eur J Pediatr. 2015;174(9):1143–57. PMID: 25772743. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E4.25772743
388 Spriet SW, Davis KL. Diet-induced weight loss in obese children with asthma: a randomized controlled trial. Pediatrics. 2014;134 Suppl 3:S170. PMID: 25363970. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.25363970
389 Spurrier NJ, Bell L, Wilson A, . Minimal change in children’s lifestyle behaviours and adiposity following a home-based obesity intervention: results from a pilot study. BMC Res Notes. 2016;9(1):26. PMID: 26758057. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.26758057
390 Srinivasan S, Ambler GR, Baur LA, . Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006;91(6):2074–80. PMID: 16595599. KQ1E1, KQ2E1, KQ3E4.16595599
391 Stark LJ, Clifford LM, Towner EK, . A pilot randomized controlled trial of a behavioral family-based intervention with and without home visits to decrease obesity in preschoolers. J Pediatr Psychol. 2014;39(9):1001–12. PMID: 25080605. KQ1E1, KQ2E1, KQ3E4, , KQ5E4.25080605
392 Stark LJ, Spear S, Boles R, . A pilot randomized controlled trial of a clinic and home-based behavioral intervention to decrease obesity in preschoolers. Obesity (Silver Spring). 2011;19(1):134–41. PMID: 20395948. KQ1E1, KQ2E1, KQ5E4.20395948
393 Steele RG, Aylward BS, Jensen CD, . Comparison of a family-based group intervention for youths with obesity to a brief individual family intervention: a practical clinical trial of positively fit. J Pediatr Psychol. 2012;37(1):53–63. PMID: 21852343. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.21852343
394 Steele RG, Jensen CD, Gayes LA, . Medium is the message: moderate parental control of feeding correlates with improved weight outcome in a pediatric obesity intervention. J Pediatr Psychol. 2014;39(7):708–17. PMID: 24914085. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24914085
395 Stettler N, Wrotniak BH, Hill DL, . Prevention of excess weight gain in paediatric primary care: beverages only or multiple lifestyle factors. The Smart Step Study, a cluster-randomized clinical trial. Pediatr Obes. 2014. PMID: 25251166. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25251166
396 Stewart L, Houghton J, Hughes AR, . Dietetic management of pediatric overweight: development and description of a practical and evidence-based behavioral approach. J Am Diet Assoc. 2005;105(11):1810–5. PMID: 16256768. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.16256768
397 Stice E, Yokum S, Burger K, . A pilot randomized trial of a cognitive reappraisal obesity prevention program. Physiol Behav. 2015;138:124–32. PMID: 25447334. KQ1E1, KQ2E1, KQ3E5a, KQ4E5a, KQ5E5a.25447334
398 Stolmaker L. Parent training as a component of behavioral program for the treatment of childhood obesity. Albany, NY: State University of New York at Albany; 1986. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.
399 Stone S, Raman A, Fleming S. Behavioral characteristics among obese/overweight inner-city African American children: A secondary analysis of participants in a community-based type 2 diabetes risk reduction program. Child Youth Serv Rev. 2010;32(6):833–9. PMID: None. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E6.
400 St-Onge MP, Goree LL, Gower B. High-milk supplementation with healthy diet counseling does not affect weight loss but ameliorates insulin action compared with low-milk supplementation in overweight children. J Nutr. 2009;139(5):933–8. PMID: 19321584. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.19321584
401 Straker L, Howie E, McVeigh J, . Changing the sedentary time and physical activity trajectories of obese adolescents: Results from the CAFAP controlled clinical trial. J Sci Med Sport. 2014;18(Suppl 1):e121. PMID: None. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.
402 Straker LM, Smith KL, Fenner AA, . Rationale, design and methods for a staggered-entry, waitlist controlled clinical trial of the impact of a community-based, family-centred, multidisciplinary program focussed on activity, food and attitude habits (Curtin University’s Activity, Food and Attitudes Program--CAFAP) among overweight adolescents. BMC Public Health. 2012;12:471. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.22721261
403 Sung RY, Yu CW, Chang SK, . Effects of dietary intervention and strength training on blood lipid level in obese children. Arch Dis Child. 2002;86(6):407–10. PMID: 12023168. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.12023168
404 Sze YY, Daniel TO, Kilanowski CK, . Web-based and mobile delivery of an episodic future thinking intervention for overweight and obese families: a feasibility study. JMIR Mhealth Uhealth. 2015;3(4):e97. PMID: 26678959. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.26678959
405 Tanofsky-Kraff M, Shomaker LB, Wilfley DE, . Targeted prevention of excess weight gain and eating disorders in high-risk adolescent girls: a randomized controlled trial. Am J Clin Nutr. 2014;100(4):1010–8. PMID: 25240070. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E2b.25240070
406 Tanofsky-Kraff M, Wilfley DE, Young JF, . A pilot study of interpersonal psychotherapy for preventing excess weight gain in adolescent girls at-risk for obesity. Int J Eat Disord. 2010;43(8):701–6. PMID: 19882739. KQ1E1, KQ2E1, KQ3E4.19882739
407 Taveras EM, Gortmaker SL, Hohman KH, . Randomized controlled trial to improve primary care to prevent and manage childhood obesity: the High Five for Kids study. Arch Pediatr Adolesc Med. 2011;165(8):714–22. PMID: 21464376. KQ1E1, KQ2E1, KQ3E4, KQ5E4.21464376
408 Taveras EM, Hohman KH, Price SN, . Correlates of participation in a pediatric primary care-based obesity prevention intervention. Obesity (Silver Spring). 2011;19(2):449–52. PMID: 20847735. KQ1E1, KQ2E1, KQ3E4, KQ5E4.20847735
409 Taveras EM, Marshall R, Horan CM, . Improving children’s obesity-related health care quality: process outcomes of a cluster-randomized controlled trial. Obesity (Silver Spring). 2014;22(1):27–31. PMID: 23983130. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23983130
410 Taveras EM, Marshall R, Horan CM, . Rationale and design of the STAR randomized controlled trial to accelerate adoption of childhood obesity comparative effectiveness research. Contemp Clin Trials. 2013;34(1):101–8. PMID: 23099100. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23099100
411 Taveras EM, Marshall R, Kleinman KP, . Comparative effectiveness of childhood obesity interventions in pediatric primary care: a cluster-randomized clinical trial. JAMA Pediatr. 2015;169(6):535–42. PMID: 25895016. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25895016
412 Taylor RW, Brown D, Dawson AM, . Motivational interviewing for screening and feedback and encouraging lifestyle changes to reduce relative weight in 4–8 year old children: design of the MInT study. BMC Public Health. 2010;10:271. PMID: 20497522. KQ1E1, KQ2E1, KQ5E4.20497522
413 Taylor RW, Cox A, Knight L, . A tailored family-based obesity intervention: a randomized trial. Pediatrics. 2015;136(2):281–9. PMID: 26195541. KQ1E1, KQ2E1, KQ5E4.26195541
414 Tock L, Damaso AR, de Piano A, . Long-term effects of metformin and lifestyle modification on nonalcoholic Fatty liver disease obese adolescents. J Obes. 2010. PMID: 20798858. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.20798858
415 Today Study Group. Design of a family-based lifestyle intervention for youth with type 2 diabetes: the TODAY study. Int J Obes (Lond). 2010;34(2):217–26. PMID: 19823189. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.19823189
416 Togashi K, Masuda H, Rankinen T, . A 12-year follow-up study of treated obese children in Japan. Int J Obes Relat Metab Disord. 2002;26(6):770–7. PMID: 12037646. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.12037646
417 Tsang TW, Kohn M, Chow CM, . A randomized controlled trial of Kung Fu training for metabolic health in overweight/obese adolescents: the “martial fitness” study. J Pediatr Endocrinol Metab. 2009;22(7):595–607. PMID: 19774841. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.19774841
418 Tsang TW, Kohn M, Chow CM, . A randomised placebo-exercise controlled trial of Kung Fu training for improvements in body composition in overweight/obese adolescents: the “Martial Fitness” study. J Sports Sci Med. 2009;8(1):97–106. PMID: 24150562. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.24150562
419 Tucker S, Lanningham-Foster LM. Nurse-led school-based child obesity prevention. J School Nurs. 2015;31(6):450–66. PMID: None. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.
420 Uysal Y, Wolters B, Knop C, . Components of the metabolic syndrome are negative predictors of weight loss in obese children with lifestyle intervention. Clin Nutr. 2014;33(4):620–5. PMID: 24075648. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.24075648
421 Van Allen J, Kuhl ES, Filigno SS, . Changes in parent motivation predicts changes in body mass index z-score (zBMI) and dietary intake among preschoolers enrolled in a family-based obesity intervention. J Pediatr Psychol. 2014;39(9):1028–37. PMID: 25016604. KQ1E1, KQ2E1, KQ3E4, KQ5E4.25016604
422 van Grieken A, Renders CM, Veldhuis L, . Promotion of a healthy lifestyle among 5-year-old overweight children: health behavior outcomes of the ‘Be active, eat right’ study. BMC Public Health. 2014;14:59. PMID: 24447459. KQ1E1, KQ2E1, KQ3E4, KQ5E4.24447459
423 van Grieken A, Veldhuis L, Renders CM, . Population-based childhood overweight prevention: outcomes of the ‘Be active, eat right’ study. PLoS ONE. 2013;8(5):e65376. PMID: 23741491. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23741491
424 Van Mil EG, Westerterp KR, Kester AD, . The effect of sibutramine on energy expenditure and body composition in obese adolescents. J Clin Endocrinol Metab. 2007;92(4):1409–14. PMID: 17264187. KQ1E1, KQ2E1, KQ3E6f, KQ4E6f, KQ5E6f.17264187
425 Vanhelst J, Mikulovic J, Fardy P, . Effects of a multidisciplinary rehabilitation program on pediatric obesity: the CEMHaVi program. Int J Rehabil Res. 2011;34(2):110–4. PMID: 21317789. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E7.21317789
426 Vann LH, Stanford FC, Durkin MW, . “Moving and losing”: A pilot study incorporating physical activity to decrease obesity in the pediatric population. J S C Med Assoc”. 2013;109(4):116–20. PMID: 24908910. KQ1E1, KQ2E1, KQ3E4, KQ4E3, KQ5E4.24908910
427 Vay RA, Kulendran M, Sides N, ., editors. The effect of an interactive short messaging service in paediatric weight loss maintenance: A randomised control trial. 20th European Congress on Obesity; 2013 May 12–15; Liverpool, UK. Search 2 CENTRAL 20160122: S. Karger AG. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.
428 Veldhuis L, Struijk MK, Kroeze W, . ‘Be active, eat right’, evaluation of an overweight prevention protocol among 5-year-old children: design of a cluster randomised controlled trial. BMC Public Health. 2009;9:177. PMID: 19505297. KQ1E1, KQ2E1, KQ3E4, KQ5E4.19505297
429 Verkauskiene R. Obesity in children and adolescents: associated risks and early intervention (OCA). NCT01677923. https://clinicaltrials.gov/ct2/show/NCT01677923?term=metformin&age=0&rank=68. Accessed 2/17/2016, PMID: None. KQ1E1, KQ2E1, KQ3E2a, KQ4E2a, KQ5E2a.
430 Vos RC, Huisman SD, Houdijk EC, . The effect of family-based multidisciplinary cognitive behavioral treatment on health-related quality of life in childhood obesity. Qual Life Res. 2012;21(9):1587–94. PMID: 22161746. KQ1E1, KQ2E1, KQ5E4.22161746
431 Vos RC, Wit JM, Pijl H, . Long-term effect of lifestyle intervention on adiposity, metabolic parameters, inflammation and physical fitness in obese children: a randomized controlled trial. Nutr Diabetes. 2011;1:e9. PMID: 23455021. KQ1E1, KQ2E1, KQ5E4.23455021
432 Vos RC, Wit JM, Pijl H, . The effect of family-based multidisciplinary cognitive behavioral treatment in children with obesity: study protocol for a randomized controlled trial. Trials. 2011;12:110. PMID: 21548919. KQ1E1, KQ2E1, KQ5E4.21548919
433 Wadden TA, Stunkard AJ, Rich L, . Obesity in black adolescent girls: a controlled clinical trial of treatment by diet, behavior modification, and parental support. Pediatrics. 1990;85(3):345–52. PMID: 2304788. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.2304788
434 Wake M, Baur LA, Gerner B, . Outcomes and costs of primary care surveillance and intervention for overweight or obese children: the LEAP 2 randomised controlled trial. BMJ. 2009;339:b3308. PMID: 19729418. KQ1E1, KQ2E1.19729418
435 Wake M, Gold L, McCallum Z, . Economic evaluation of a primary care trial to reduce weight gain in overweight/obese children: the LEAP trial. Ambul Pediatr. 2008;8(5):336–41. PMID: 18922508. KQ1E1, KQ2E1.18922508
436 Wake M, Lycett K, Clifford SA, . Shared care obesity management in 3–10 year old children: 12 month outcomes of HopSCOTCH randomised trial. BMJ. 2013;346:f3092. PMID: 23751902. KQ1E1, KQ2E1.23751902
437 Wake M, Lycett K, Sabin MA, . A shared-care model of obesity treatment for 3–10 year old children: protocol for the HopSCOTCH randomised controlled trial. BMC Pediatrics. 2012;12:39. PMID: 22455381. KQ1E1, KQ2E1.22455381
438 Waling M, Backlund C, Lind T, . Effects on metabolic health after a 1-year-lifestyle intervention in overweight and obese children: a randomized controlled trial. J Nutr Metab. 2012;2012:913965. PMID: 21941639. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.21941639
439 Waling M, Larsson C. Improved dietary intake among overweight and obese children followed from 8 to 12 years of age in a randomised controlled trial. J Nutr Sci. 2012;1:e16. PMID: 25191545. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.25191545
440 Waling M, Lind T, Hernell O, . A one-year intervention has modest effects on energy and macronutrient intakes of overweight and obese Swedish children. J Nutr. 2010;140(10):1793–8. PMID: 20739446. KQ1E1, KQ2E1, KQ3E4, KQ4E8b, KQ5E4.20739446
441 Walpole B, Dettmer E, Morrongiello B, . Motivational interviewing as an intervention to increase adolescent self-efficacy and promote weight loss: methodology and design. BMC Public Health. 2011;11:459. PMID: 21663597. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.21663597
442 Walpole B, Dettmer E, Morrongiello BA, . Motivational interviewing to enhance self-efficacy and promote weight loss in overweight and obese adolescents: a randomized controlled trial. J Pediatr Psychol. 2013;38(9):944–53. PMID: 23671058. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.23671058
443 Warschburger P, Fromme C, Petermann F, . Conceptualisation and evaluation of a cognitive-behavioural training programme for children and adolescents with obesity. Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S93–5. PMID: 11466598. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.11466598
444 Warschburger P, Kroller K, Unverzagt S, ., editors. What is the parents’ part in long-term weight management of their obese child? Results from the EPOC study. 20th European Congress on Obesity (ECO); 2013 May 12–15; Liverpool, UK. Search 2 CENTRAL 20160122: S. Karger AG. KQ1E1, KQ2E1, KQ3E2, KQ4E2, KQ5E2.
445 Watson P, Wiers RW, Hommel B, . An associative account of how the obesogenic environment biases adolescents’ food choices. Appetite. 2016;96:560–71. PMID: None. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E6a.26482282
446 Wattigney WA, Webber LS, Srinivasan SR, . The emergence of clinically abnormal levels of cardiovascular disease risk factor variables among young adults: the Bogalusa Heart Study. Prev Med. 1995;24(6):617–26. PMID: 8610086. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.8610086
447 Weigel C, Kokocinski K, Lederer P, . Childhood obesity: concept, feasibility, and interim results of a local group-based, long-term treatment program. J Nutr Educ Behav. 2008;40(6):369–73. PMID: 18984493. KQ1E1, KQ2E1, KQ3E4, KQ5E4.18984493
448 Weijs PJ, Hofsteenge AG, Chinapaw M, . Long-term effect of the Go4it group treatment for obese adolescents: A randomised controlled trial. Clinical Nutrition. 2012;7(1 Suppl):130. PMID: 23810626. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23810626
449 West F, Sanders MR, Cleghorn GJ, . Randomised clinical trial of a family-based lifestyle intervention for childhood obesity involving parents as the exclusive agents of change. Behav Res Ther. 2010;48(12):1170–9. PMID: 20883981. KQ1E1, KQ2E1, KQ3E4b, KQ4E4b, KQ5E4b.20883981
450 Wiegand S, Bau AM, Ernert A, . Maintain: An intervention study of weight regain after weight loss in adolescents and children reveals an only minor role of leptin in weight regain. Horm Res Paediatr. 2014;82:221. PMID: None. KQ1E1, KQ2E1, KQ3E8b, KQ4E8b, KQ5E8b.
451 Wiegand S, l’Allemand D, Hubel H, . Metformin and placebo therapy both improve weight management and fasting insulin in obese insulin-resistant adolescents: a prospective, placebo-controlled, randomized study. Eur J Endocrinol. 2010;163(4):585–92. PMID: 20639355. KQ1E1, KQ2E1, KQ3E4.20639355
452 Wildes JE, Marcus MD, Kalarchian MA, . Self-reported binge eating in severe pediatric obesity: impact on weight change in a randomized controlled trial of family-based treatment. Int J Obes (Lond). 2010;34(7):1143–8. PMID: 20157322. KQ1E1, KQ2E1, KQ5E4.20157322
453 Wilfley DE, Stein RI, Saelens BE, . Efficacy of maintenance treatment approaches for childhood overweight: a randomized controlled trial. JAMA. 2007;298(14):1661–73. PMID: 17925518. KQ1E1, KQ2E1, KQ3E2b, KQ4E2b, KQ5E4.17925518
454 Williamson DA, Martin PD, White MA, . Efficacy of an internet-based behavioral weight loss program for overweight adolescent African-American girls. Eat Weight Disord. 2005;10(3):193–203. PMID: 16277142. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.16277142
455 Williamson DA, Walden HM, White MA, . Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231–43. PMID: 16899804. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.16899804
456 Wilson AJ, Prapavessis H, Jung ME, . Lifestyle modification and metformin as long-term treatment options for obese adolescents: study protocol. BMC Public Health. 2009;9:434. KQ1E1, KQ2E1, KQ3E4, KQ5E4.19943971
457 Wilson DM, Abrams SH, Aye T, . Metformin extended release treatment of adolescent obesity: a 48-week randomized, double-blind, placebo-controlled trial with 48-week follow-up. Arch Pediatr Adolesc Med. 2010;164(2):116–23. PMID: 20124139. KQ1E1, KQ2E1, KQ3E4.20124139
458 Woo Baidal JA, Price SN, Gonzalez-Suarez E, . Parental perceptions of a motivational interviewing-based pediatric obesity prevention intervention. Clin Pediatr (Phila). 2013;52(6):540–8. PMID: 23564304. KQ1E1, KQ2E1, KQ3E4, KQ5E4.23564304
459 Woo KS, Chook P, Yu CW, . Effects of diet and exercise on obesity-related vascular dysfunction in children. Circulation. 2004;109(16):1981–6. PMID: 15066949. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.15066949
460 Wright DR, Taveras EM, Gillman MW, . The cost of a primary care-based childhood obesity prevention intervention. BMC Health Serv Res. 2014;14:44. PMID: 24472122. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.24472122
461 Wylie-Rosett J, Isasi C, Soroudi N, . KidWAVE: Get Healthy Game--promoting a more healthful lifestyle in overweight children. J Nutr Educ Behav. 2010;42(3):210–2. PMID: 20434077. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20434077
462 Yanovski J. Safety and efficacy of xenical in children and adolescents with obesity-related diseases. NCT00001723. https://clinicaltrials.gov/ct2/show/NCT00001723. Accessed 02/05/2016, PMID: None. KQ1E1, KQ2E1, KQ3E4.
463 Yanovski JA, Krakoff J, Salaita CG, . Effects of metformin on body weight and body composition in obese insulin-resistant children: a randomized clinical trial. Diabetes. 2011;60(2):477–85. PMID: 21228310. KQ1E1, KQ2E1, KQ3E4.21228310
464 Yoshinaga M, Sameshima K, Miyata K, . Prevention of mildly overweight children from development of more overweight condition. Prev Med. 2004;38(2):172–4. PMID: 14715208. KQ1E1, KQ2E1, KQ3E3, KQ4E3, KQ5E3.14715208
465 Yun L, Boles RE, Haemer MA, . A randomized, home-based, childhood obesity intervention delivered by patient navigators. BMC Public Health. 2015;15:506. PMID: 26002612. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E4.26002612