# Appendix B Detailed Methods

## Literature Search Strategies

### CENTRAL

Issue 1 of 12, January 2015

#1 | (obese or obesity or overweight or “over weight”):ti,ab,kw
#2 | screen*:ti,ab,kw
#3 | (body next mass next ind*):ti,ab,kw
#4 | (body next mass next abdominal next ind*):ti,ab,kw
#5 | (body next adiposity next ind*):ti,ab,kw
#6 | (bmi or bmai):ti,ab,kw
#7 | (skinfold or “skin fold”):ti,ab,kw
#8 | (waist next circumference*):ti,ab,kw
#9 | (waist near/3 ratio*):ti,ab,kw
#10 | “weight for height”:ti,ab,kw
#11 | “weight for age”:ti,ab,kw
#12 | “weight stature”:ti,ab,kw
#13 | (adipos* near/2 measur*):ti,ab,kw
#14 | anthropometr*:ti,ab,kw
#15 | (#2–‘#14)
#16 | (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or (young next adult*) or pediatric* or paediatric* or schoolchildren or school children or preschool* or (pre next school*) or toddler*):ti,ab,kw
#17 | #1 and #15 and #16 Publication Year from 2005 to 2015, in Trials
#18 | (obese or obesity or overweight or “over weight”):ti,ab,kw
#19 | (weight next gain*):ti,ab,kw or (weight next loss*):ti,ab,kw
#20 | (weight next change*):ti,ab,kw
#21 | (bmi or body mass index):ti,ab,kw near/2 (gain* or loss* or change*):ti,ab,kw
#22 | “weight maintenance”:ti,ab,kw
#23 | “weight control”:ti,ab,kw
#24 | “weight management”:ti,ab,kw
#25 | (or #18–#24)
#26 | (psychological or behavior* or behaviour*):ti,ab,kw next (therap* or modif* or chang* or strateg* or intervention*):ti,ab,kw
#27 | (group or family or cognitive):ti,ab,kw next therap*:ti,ab,kw
#28 | cbt:ti,ab,kw
#29 | (lifestyle or “life style”):ti,ab,kw next (chang* or interven* or modif*):ti,ab,kw
#30 | counsel*:ti,ab,kw
#31 | (social* next support*):ti,ab,kw
#32 | (peer* near/2 support*):ti,ab,kw
#33 | (child* near/3 parent*):ti,ab,kw and therap*:ti,ab,kw
#34 | (family or parent*):ti,ab,kw next intervention*:ti,ab,kw
#35 | parent*:ti,ab,kw near/2 (behavior* or behaviour* or involv* or control* or attitude* or educat*):ti,ab,kw
#36 | health:ti,ab,kw next (education or promotion):ti,ab,kw
#37 | “patient education”:ti,ab,kw
#38 | (nonpharmacologic or “non pharmacologic”):ti,ab,kw next intervention*:ti,ab,kw
#39 | (self next regulat*):ti,ab,kw
#40 | school*:ti,ab,kw near/5 (intervention* or program*):ti,ab,kw
#41 | ( #26–‘#40)
#42 | (exercise or “physical activity”):ti
#43 | fitness:ti,ab,kw next (class* or regime* or program*):ti
#44 | (“physical training” or “physical education”):ti
#45 | (sedentary next (behavior* or behaviour*)):ti,ab,kw near/3 (reduc* or mimim* or less*):ti,ab,kw
#46 | (exercise or “physical activity”):ti,ab,kw near/5 (intervention* or promot*):ti,ab,kw 4814
#47 | (or #42–#46)
#48 | (diet or diets or dieting or dietary):ti
#49 | diet*:ti,ab,kw next (modif* or therap* or intervention* or strateg*):ti,ab,kw
#50 | (“low calorie” or (calorie next control*) or “healthy eating”):ti,ab,kw
#51 | (formula next diet*):ti,ab,kw
#52 | weightwatcher*:ti,ab,kw or (weight next watcher*):ti,ab,kw
#53 | ( #48–#52)
#54 | collaborat*:ti,ab,kw
#55 | (interdisciplinary or “inter disciplinary”):ti,ab,kw
#56 | (multidisciplinary or multi-disciplinary):ti,ab,kw
#57 | integrated:ti,ab,kw near/5 (healthcare or care):ti,ab,kw
#58 | (care or case):ti,ab,kw next manag*:ti,ab,kw
#59 | “cooperative care”:ti,ab,kw
#60 | “patient centered care”:ti,ab,kw
#61 | “stepped care”:ti,ab,kw
#62 | “coordinated care”:ti,ab,kw
#63 | (or #54–#62)
#64 | Orlistat:ti,ab,kw
#65 | tetrahydrolipstatin:ti,ab,kw
#66 | Xenical:ti,ab,kw
#67 | Alli:ti,ab,kw
#68 | metformin:ti,ab,kw
#69 | Glucophage:ti,ab,kw
#70 | dimethylbiguanidine:ti,ab,kw
#71 | dimethylguanylguanidine:ti,ab,kw
#72 | (dimethylbiguanide or dimethyl-biguanide):ti,ab,kw
#73 | (or #64–#72)
#74 | #41 or #47 or #53 or #63 or #73
#75 | #16 and #25 and #74 Publication Year from 2010 to 2015, in Trials
#76 | #17 or #75

### ERIC

# | Query | Limiters/Expanders
S17 | S5 AND S16 | Limiters - Date Published: 20050101-20151231 Search modes - Find all my search terms
S16 | (S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15)
S15 | TI child* OR TI student* OR TI school*
S14 | DE “Nutrition Instruction”
S13 | DE “Child Caregivers” OR DE “Child Development Specialists” OR DE “Caregiver Role”
S12 | DE “Interdisciplinary Approach”
S11 | DE “Lesson Plans” OR DE “Integrated Curriculum” OR DE “Curriculum Implementation”
S10 | DE “School Policy” OR DE “School Role” OR DE “School Community Relationship” OR DE “School Involvement” OR DE “School Responsibility” OR DE “Teacher Role” OR DE “Teacher Responsibility”
S9 | DE “High School Freshmen” OR DE “High School Seniors” OR DE “High School Students” OR DE “High Schools” OR DE “Secondary School Teachers” OR DE “Secondary Schools”
S8 | DE “Middle School Students” OR DE “Middle School Teachers” OR DE “Middle Schools”
S7 | DE “Primary Education” OR DE “Kindergarten” OR DE “Grade 1” OR DE “Grade 2” OR DE “Grade 3” OR OR DE “Grade 4” OR DE “Grade 5” OR DE “Grade 6” OR DE “Grade 7” OR DE “Grade 8” OR DE “Grade 9” OR DE “Grade 10” OR DE “Grade 11” OR DE “Grade 12”
S6 | DE “Elementary School Students” OR DE “Elementary School Teachers” OR DE “Elementary Schools” OR DE “Elementary Secondary Education” OR DE “Elementary School Curriculum”
S5 | S1 OR S2 OR S3 OR S4
S4 | TI obesity OR TI obese OR TI overweight OR TI over weight
S3 | DE “Body Weight”
S2 | DE “Body Composition”
S1 | DE “Obesity”

### Ovid Medline Screening

Database: Ovid MEDLINE(R) <1946 to February Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <February 09, 2015>, Ovid MEDLINE(R) Daily Update <February 09, 2015>
Search Strategy:
1. Obesity/; 2. Obesity, Morbid/; 3. Obesity, Abdominal/; 4. Overweight/; 5. Weight Gain/; 6. obesity.ti,ab.; 7. obese.ti,ab.; 8. overweight.ti,ab.; 9. over weight.ti,ab.; 10. or/1–9; 11. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/; 12. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti.; 13. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab.; 14. limit 13 to (“in data review” or in process or “pubmed not medline”); 15. 10 and (11 or 12 or 14); 16. Pediatric Obesity/; 17. 15 or 16; 18. Mass screening/; 19. Body constitution/; 20. “Body Weights and Measures”/; 21. Body Fat Distribution/; 22. Adiposity/; 23. Body Mass Index/; 24. Skinfold thickness/; 25. Body height/ and Body weight/; 26. Waist circumference/; 27. Waist-height ratio/; 28. Anthropometry/; 29. screen$.ti,ab.; 30. body mass index$.ti,ab.; 31. body mass indices.ti,ab.; 32. bmi.ti,ab.; 33. body mass abdominal index$.ti,ab.; 34. body mass abdominal indices.ti,ab.; 35. bmai.ti,ab.; 36. body adiposity index$.ti,ab.; 37. body adiposity indices.ti,ab.; 38. (skinfold or skin fold).ti,ab.; 39. waist circumference$.ti,ab.; 40. waist to height ratio$.ti,ab.; 41. waist height ratio$.ti,ab.; 42. waist to hip ratio$.ti,ab.; 43. waist hip ratio$.ti,ab.; 44. weight for height.ti,ab.; 45. height for weight.ti,ab.; 46. weight for age.ti,ab.; 47. weight stature.ti,ab.; 48. (adiposity adj2 measur$).ti,ab.; 49. anthropometr$.ti,ab.; 50. or/18–49; 51. 17 and 50; 52. Pediatric Obesity/di [Diagnosis]; 53. Obesity/di; 54. Obesity, Morbid/di; 55. Obesity, Abdominal/di; 56. Overweight/di; 57. 53 or 54 or 55 or 56; 58. 57 and (11 or 12 or 14); 59. 51 or 52 or 58; 60. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/; 61. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.; 62. Random$.ti,ab.; 63. control groups/ or double-blind method/ or single-blind method/; 64. clinical trial$.ti,ab.; 65. controlled trial$.ti,ab.; 66. meta analy$.ti,ab.; 67. or/60–66; 68. 59 and 67; 69. limit 68 to (english language and yr=“2005 -Current”); 70. remove duplicates from 69

### Ovid Medline Treatment trials

Database: Ovid MEDLINE(R) <1946 to February Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <February 09, 2015>, Ovid MEDLINE(R) Daily Update <February 09, 2015>
Search Strategy:
1. Obesity/; 2. Obesity, Morbid/; 3. Obesity, Abdominal/; 4. Overweight/; 5. Weight Gain/; 6. Weight Loss/; 7. obesity.ti,ab.; 8. obese.ti,ab.; 9. overweight.ti,ab.; 10. over weight.ti,ab.; 11. (weight gain$ or weight loss$).ti,ab.; 12. weight change$.ti,ab.; 13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$)).ti,ab.; 14. weight maintenance.ti,ab.; 15. weight control.ti,ab.; 16. weight manag$.ti,ab.; 17. or/1–16; 18. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/; 19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti.; 20. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab.; 21. limit 20 to (“in data review” or in process or “pubmed not medline”); 22. 17 and (18 or 19 or 21); 23. Pediatric Obesity/ (; 24. 22 or 23; 25. Counseling/; 26. Directive Counseling/; 27. Behavior therapy/; 28. Aversive therapy/; 29. Biofeedback, Psychology/; 30. Feedback, Psychological/; 31. Cognitive therapy/; 32. “Acceptance and commitment therapy”/; 33. Mindfulness/; 34. Desensitization, psychologic/; 35. Relaxation therapy/; 36. Meditation/; 37. Social Support/; 38. Psychotherapy, Group/; 39. Family Therapy/; 40. Persuasive Communication/; 41. Risk Reduction Behavior/; 42. Health Education/; 43. Health Promotion/; 44. Patient Education as Topic/; 45. “Early Intervention (Education)”/; 46. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab.; 47. (group therap$ or family therap$ or cognitive therap$).ti,ab.; 48. cbt.ti,ab.; 49. ((lifestyle or life style) adj (chang$ or interven$ or modif$)).ti,ab.; 50. counsel?ing.ti,ab.; 51. social$ support$.ti,ab.; 52. (peer$ adj2 support$).ti,ab.; 53. ((child$ adj3 parent$) and therap$).ti,ab.; 54. (family intervention$ or parent$ intervention$).ti,ab.; 55. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab.; 56. health education.ti,ab.; 57. health promotion.ti,ab.; 58. patient education.ti,ab.; 59. nonpharmacologic intervention$.ti,ab.; 60. non pharmacologic intervention$.ti,ab.; 61. self regulat$.ti,ab.; 62. (school$ adj5 (intervention$ or program$)).ti,ab.; 63. or/25–62; 64. Exercise/; 65. Physical Conditioning, Human/; 66. (exercise or physical activity).ti.; 67. aerobic$.ti.; 68. (fitness adj (class$ or regime$ or program$)).ti.; 69. (physical training or physical education).ti.; 70. (sedentary behavio?r$ adj3 reduc$).ti,ab.; 71. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab.; 72. or/64–71; 73. Diet-Fat-Restricted/; 74. Diet-Reducing/; 75. Diet, Carbohydrate-Restricted/; 76. Diet-Therapy/; 77. Caloric Restriction/; 78. Food Habits/; 79. (diet or diets or dieting or dietary).ti.; 80. (diet$ adj (modif$ or therap$ or intervention$ or strateg$)).ti,ab.; 81. (low calorie or calorie control$ or healthy eating).ti,ab.; 82. formula diet$.ti,ab.; 83. (weightwatcher$ or weight watcher$).ti,ab.; 84. or/73–83; 85. Case management/; 86. Patient care team/; 87. Cooperative behavior/; 88. Interprofessional Relations/; 89. Continuity of patient care/; 90. Patient-centered care/; 91. Patient care management/; 92. Delivery of Health Care, Integrated/; 93. collaborat$.ti,ab.; 94. (interdisciplinary or inter disciplinary).ti,ab.; 95. (multidisciplinary or multi disciplinary).ti,ab.; 96. (integrated adj5 (healthcare or care)).ti,ab.; 97. care manag$.ti,ab.; 98. case manag$.ti,ab.; 99. cooperative care.ti,ab.; 100. coordinated care.ti,ab.; 101. patient centered care.ti,ab.; 102. stepped care.ti,ab.; 103. or/85–102; 104. Anti-Obesity Agents/; 105. Metformin/; 106. Lactones/; 107. Orlistat.ti,ab.; 108. tetrahydrolipstatin.ti,ab.; 109. Xenical.ti,ab.; 110. Alli.ti,ab.; 111. metformin.ti,ab.; 112. Glucophage.ti,ab.; 113. dimethylbiguanidine.ti,ab.; 114. dimethylguanylguanidine.ti,ab.; 115. (dimethylbiguanide or dimethyl-biguanide).ti,ab.; 116. or/104–115; 117. Weight Reduction Programs/; 118. ((weight loss or weight reduction) adj3 (intervention$ or promot$)).ti,ab.; 119. 24 and (63 or 72 or 84 or 103 or 116 or 117 or 118); 120. Pediatric Obesity/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]; 121. Obesity/dh, dt, pc, rh, th; 122. Obesity, Morbid/dh, dt, pc, rh, th; 123. Obesity, Abdominal/dh, dt, pc, rh, th; 124. Overweight/dh, dt, pc, rh, th; 125. or/121–124; 126. 125 and (18 or 19 or 21); 127. 119 or 120 or 126; 128. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/; 129. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.; 130. Random$.ti,ab.; 131. control groups/ or double-blind method/ or single-blind method/; 132. clinical trial$.ti,ab.; 133. controlled trial$.ti,ab.; 134. meta analy$.ti,ab.; 135. or/128–134; 136. 127 and 135; 137. limit 136 to (english language and yr=“2010 -Current”); 138. remove duplicates from 137

### Ovid Medline Drug Treatment Harms

Database: Ovid MEDLINE(R) <1946 to February Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <February 09, 2015>, Ovid MEDLINE(R) Daily Update <February 09, 2015>
Search Strategy:
1. Obesity/; 2. Obesity, Morbid/; 3. Obesity, Abdominal/; 4. Overweight/; 5. Weight Gain/; 6. Weight Loss/; 7. obesity.ti,ab.; 8. obese.ti,ab.; 9. overweight.ti,ab.; 10. over weight.ti,ab.; 11. (weight gain$ or weight loss$).ti,ab.; 12. weight change$.ti,ab.; 13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$)).ti,ab.; 14. weight maintenance.ti,ab.; 15. weight control.ti,ab.; 16. weight manag$.ti,ab.; 17. or/1–16; 18. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/; 19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti.; 20. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab.; 21. limit 20 to (“in data review” or in process or “pubmed not medline”); 22. 17 and (18 or 19 or 21); 23. Pediatric Obesity/; 24. 22 or 23; 25. Anti-Obesity Agents/; 26. Metformin/; 27. Lactones/; 28. Orlistat.ti,ab.; 29. tetrahydrolipstatin.ti,ab.; 30. Xenical.ti,ab.; 31. Alli.ti,ab.; 32. metformin.ti,ab.; 33. Glucophage.ti,ab.; 34. dimethylbiguanidine.ti,ab.; 35. dimethylguanylguanidine.ti,ab.; 36. (dimethylbiguanide or dimethyl-biguanide).ti,ab.; 37. or/25–36; 38. 24 and 37; 39. Pediatric Obesity/dt; 40. Obesity/dt; 41. Obesity, Morbid/dt; 42. Obesity, Abdominal/dt; 43. Overweight/dt; 44. 40 or 41 or 42 or 43; 45. 44 and (18 or 19 or 21); 46. 38 or 39 or 45; 47. “Drug-Related Side Effects and Adverse Reactions”/; 48. safety.ti,ab.; 49. harm$.ti,ab.; 50. mortality.ti,ab.; 51. toxicity.ti,ab.; 52. complication$.ti,ab.; 53. (death or deaths).ti,ab.; 54. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.; 55. adverse effects.fs.; 56. toxicity.fs.; 57. mortality.fs.; 58. poisoning.fs.; 59. quality of life/; 60. depression/; 61. depressive disorder; 62. (depression or depressed).ti,ab.; 63. stress, psychological/; 64. adaptation, psychological/; 65. anxiety/; 66. (anxiety or anxious).ti,ab.; 67. suicide/; 68. (suicide$ or suicidal).ti,ab.; 69. self concept/; 70. self esteem.ti,ab.; 71. body image/; 72. social isolation/; 73. False Positive Reactions/; 74. Social stigma/; 75. stigma$.ti,ab.; 76. (label or labeled or labeling).ti,ab.; 77. Patient Compliance/; 78. Patient Acceptance of Health Care/; 79. Patient Participation/; 80. Treatment Refusal/; 81. Patient Dropouts/; 82. Eating Disorders/; 83. Anorexia/; 84. Anorexia Nervosa/; 85. Bulimia/; 86. Bulimia Nervosa/; 87. eating disorder$.ti,ab.; 88. disordered eating.ti,ab.; 89. (anorexic or anorexia).ti,ab.; 90. (bulimic or bulimia).ti,ab.; 91. weight cycling.ti,ab.; 92. weight fluctuat$.ti,ab.; 93. fasting/; 94. laxative$.ti,ab.; 95. (overweight adj4 concern$).ti,ab.; 96. (weight adj4 concern$).ti,ab.; 97. ((stunt$ or suppress$) adj2 growth).ti,ab.; 98. Nausea/; 99. Vomiting/; 100. (nausea$ or nauseous or vomit$).ti,ab.; 101. Diarrhea/; 102. diarrh?ea.ti,ab.; 103. Malnutrition/; 104. (malnourished or malnutrition).ti,ab.; 105. nutritional defici$.ti,ab.; 106. or/47–105; 107. 46 and 106; 108. limit 107 to (english language and yr=“2010 -Current”); 109. remove duplicates from 108

### PsycInfo Screening

Database: PsycINFO <1806 to February Week 1 2015>
Search Strategy:
1. Obesity/; 2. Overweight/; 3. Weight gain/; 4. obesity.ti,ab,id.; 5. obese.ti,ab,id.; 6. overweight.ti,ab,id.; 7. over weight.ti,ab,id.; 8. weight gain.ti,ab,id.; 9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8; 10. limit 9 to (100 childhood <birth to age 12 yrs> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>); 11. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,id.; 12. 9 and 11; 13. 10 or 12; 14. Screening/; 15. Health screening/; 16. Body mass index/; 17. Body fat/; 18. Body weight/; 19. Anthropometry/; 20. screen$.ti,ab,id.; 21. body mass index$.ti,ab,id.; 22. body mass indices.ti,ab,id.; 23. bmi.ti,ab,id.; 24. body mass abdominal index$.ti,ab,id.; 25. body mass abdominal indices.ti,ab,id.; 26. bmai.ti,ab,id.; 27. body adiposity index$.ti,ab,id.; 28. body adiposity indices.ti,ab,id.; 29. (skinfold or skin fold).ti,ab,id.; 30. waist circumference$.ti,ab,id.; 31. waist to height ratio$.ti,ab,id.; 32. waist height ratio$.ti,ab,id.; 33. waist to hip ratio$.ti,ab,id.; 34. waist hip ratio$.ti,ab,id.; 35. weight for height.ti,ab,id.; 36. height for weight.ti,ab,id.; 37. weight for age.ti,ab,id.; 38. weight stature.ti,ab,id.; 39. (adiposity adj2 measur$).ti,ab,id.; 40. anthropometr$.ti,ab,id.; 41. or/14–40; 42. 13 and 41; 43. random$.ti,ab,id,hw.; 44. placebo$.ti,ab,hw,id.; 45. controlled trial$.ti,ab,id,hw.; 46. clinical trial$.ti,ab,id,hw.; 47. meta analy$.ti,ab,hw,id.; 48. treatment outcome clinical trial.md.; 49. 43 or 44 or 45 or 46 or 47 or 48; 50. 42 and 49; 51. limit 50 to (english language and yr=“2005 -Current”)

### PsycInfo Treatment

Database: PsycINFO <1806 to February Week 1 2015>
Search Strategy:
1. Obesity/; 2. Overweight/; 3. Weight gain/; 4. Weight Control/; 5. Weight Loss/; 6. obesity.ti,ab,id.; 7. obese.ti,ab,id.; 8. overweight.ti,ab,id.; 9. over weight.ti,ab,id.; 10. weight gain.ti,ab,id.; 11. weight loss.ti,ab,id.; 12. weight maintenance.ti,ab,id.; 13. weight control.ti,ab,id.; 14. (weight adj3 manag$).ti,ab,id.; 15. weight change$.ti,ab,id.; 16. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$)).ti,ab,id.; 17. or/1–16; 18. limit 17 to (100 childhood <birth to age 12 yrs> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>); 19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,id.; 20. 17 and 19; 21. 18 or 20; 22. Counseling/; 23. Behavior Therapy/; 24. Cognitive Behavior Therapy/; 25. Cognitive Therapy/; 26. Cognitive Techniques/; 27. Behavior Modification/; 28. Behavior Change/; 29. Lifestyle Changes/; 30. Lifestyle/; 31. School Counseling/; 32. Psychotherapeutic Counseling/; 33. Peer Counseling/; 34. Group Counseling/; 35. Community Counseling/; 36. School Counseling/; 37. Motivational Interviewing/; 38. Feedback/; 39. Biofeedback/; 40. Health Education/; 41. Health Promotion/; 42. Client Education/; 43. Self Regulation/; 44. Intervention/; 45. School Based Intervention/; 46. Family Intervention/; 47. Early Intervention/; 48. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,id.; 49. (group therap$ or family therap$ or cognitive therap$).ti,ab,id.; 50. cbt.ti,ab,id.; 51. ((lifestyle or life style) adj (chang$ or interven$ or modifi$)).ti,ab,id.; 52. counsel$.ti,ab,id.; 53. social$ support$.ti,ab,id.; 54. (peer adj2 support).ti,ab,id.; 55. ((child$ adj3 parent$) and therapy).ti,ab,id.; 56. (family intervention$ or parent$ intervention$).ti,ab,id.; 57. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab.; 58. health education.ti,ab,id.; 59. health promotion.ti,ab,id.; 60. patient education.ti,ab,id.; 61. nonpharmacologic intervention$.ti,ab,id.; 62. non pharmacologic intervention$.ti,ab,id.; 63. self regulat$.ti,ab,id.; 64. (school$ adj5 (intervention$ or program$)).ti,ab,id.; 65. or/22–64; 66. Physical Activity/; 67. Physical Fitness/; 68. Exercise/; 69. Aerobic Exercise/; 70. Active Living/; 71. (exercise or physical activity).ti.; 72. aerobic$.ti.; 73. (fitness adj (class$ or regime$ or program$)).ti.; 74. (physical training or physical education).ti.; 75. (sedentary behavio?r$ adj3 reduc$).ti,ab,id.; 76. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,id.; 77. or/66–76; 78. Diets/; 79. Dietary Restraint/; 80. Food Intake/; 81. Eating Behavior/; 82. (diet or diets or dieting or dietary).ti.; 83. (diet$ adj (modif$ or therapy or intervention$ or strateg$)).ti,ab,id.; 84. (low calorie or calorie control$ or healthy eating).ti,ab,id.; 85. formula diet$.ti,ab,id.; 86. (weightwatcher$ or weight watcher$).ti,ab,id.; 87. or/78–86; 88. Interdisciplinary Treatment Approach/; 89. Collaboration/; 90. Cooperation/; 91. Case Management/; 92. Work Teams/; 93. Community Mental Health Services/; 94. Health Care Delivery/; 95. Community Psychology/; 96. Community Psychiatry/; 97. collaborat$.ti,ab,id.; 98. (interdisciplinary or inter disciplinary).ti,ab,id.; 99. (multidisciplinary or multi disciplinary).ti,ab,id.; 100. (integrated adj5 (healthcare or care)).ti,ab,id.; 101. care manag$.ti,ab,id.; 102. case manag$.ti,ab,id.; 103. cooperative care.ti,ab,id.; 104. coordinated care.ti,ab,id.; 105. patient centered care.ti,ab,id.; 106. or/88–105; 107. ((weight loss or weight reduction or weight control or weight maintenance or weight managment) adj3 (intervention$ or promot$)).ti,ab,id.; 108. 21 and (65 or 77 or 87 or 106 or 107); 109. random$.ti,ab,id,hw.; 110. placebo$.ti,ab,hw,id.; 111. controlled trial$.ti,ab,id,hw.; 112. clinical trial$.ti,ab,id,hw.; 113. meta analy$.ti,ab,hw,id.; 114. treatment outcome clinical trial.md.; 115. or/109–114; 116. 108 and 115; 117. Orlistat.ti,ab,id.; 118. tetrahydrolipstatin.ti,ab,id.; 119. Xenical.ti,ab,id.; 120. Alli.ti,ab,id.; 121. metformin.ti,ab,id.; 122. Glucophage.ti,ab,id.; 123. dimethylbiguanidine.ti,ab,id.; 124. dimethylguanylguanidine.ti,ab,id.; 125. (dimethylbiguanide or dimethyl-biguanide).ti,ab,id.; 126. or/117–125; 127. 21 and 126; 128. 116 or 127; 129. limit 128 to (english language and yr=“2010 -Current”)

### Pubmed, publisher-supplied

Search | Query
[underlined: #7] | #4 OR #6
[underlined: #6] | #1 AND #2 AND #5 AND publisher[sb] AND English[Language]) AND (“2010”[Date - Publication] : “3000”[Date - Publication])))
[underlined: #5] | Orlistat[tiab] OR tetrahydrolipstatin[tiab] OR Xenical[tiab] OR Alli[tiab] OR metformin[tiab] OR Glucophage[tiab] OR dimethylbiguanidine[tiab] OR dimethylguanylguanidine[tiab] OR dimethylbiguanide[tiab] OR dimethyl-biguanide[tiab]
[underlined: #4] | #1 AND #2 AND #3 AND publisher[sb] AND English[Language] AND (“2005”[Date - Publication] : “3000”[Date - Publication])
[underlined: #3] | (random*[tiab] OR trial*[tiab])
[underlined: #2] | (child*[title] OR adolescen*[title] OR teen*[title] OR boy*[title] OR girl*[title] OR youth*[title] OR young[title] OR school*[title] preschool*[title] OR OR pediatric*[title] OR paediatric*[title] OR toddler*[title])
[underlined: #1] | obese[title] OR obesity[title] OR overweight[title] OR weight[title] OR bmi[title] OR body mass index[title]

Appendix B Figure 1 Literature Flow Diagram

Abbreviation: CE=comparative effectiveness.

This figure is a flow chart that summarizes the search and selection of articles. There were 9,216 citations identified through literature databases. An additional 275 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 9,491 unique citations were screened at the title/abstract stage. The full text of 464 citations were examined for inclusion for one or more of the five Key Questions. The following number of articles were included for Key Question 1 (n=0), Key Question 2 (n=0), Key Question 3 (n=26), Key Question 4 (n=98), and Key Question 5 (n=33). Reasons for excluding the other articles are available in Appendix C.

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Condition definition | Studies identifying children who are overweight or have obesity using methods such as BMI, BMI percentile, BMI z-score, percent overweight, waist circumference, or a similar measure
Aim | KQs 1, 2 (screening): Studies of programs that systematically screen children and adolescents to identify those who are overweight or have obesity KQs 3–5 (interventions): Studies with a primary aim of weight management (including weight loss and weight gain prevention) | KQs 1, 2 (screening): Intervention programs for diet or physical activity without a weight-related measure KQs 3–5 (interventions): healthy lifestyle counseling with no weight-related aim
Population | All KQs: Children and adolescents ages 2 to 18 years. Studies that substantially overlap this age range (e.g., ages 14–65 years) will be included if results for younger participants are reported separately. KQs 1, 2 (screening): General primary care or comparable populations KQs 3–5 (interventions): Either:; - The entire sample has an age- and sex-specific BMI ≥85th percentile or meets other similar criteria for overweight based on ideal body weight; - The entire sample previously had excess weight and is now engaged in maintenance of weight loss/improved weight trajectory; or; - ≥50% of the sample has an age- and sex-specific BMI ≥85th percentile and ≥80% have risk factors for overweight (e.g., overweight parents; Hispanic, black, or American Indian/Alaska Native ethnicity) or obesity-related medical problems (e.g., diabetes, metabolic syndrome, hypertension, lipid abnormalities, or other cardiovascular-related disorders) | - Studies with an average age younger than 2 or older than 18 years; - Populations limited exclusively to youth who:; ○ Have an eating disorder; ○ Are pregnant or postpartum; ○ Are overweight or have obesity secondary to a genetic or medical condition, such as polycystic ovarian syndrome, hypothyroidism, Cushing’s syndrome, growth hormone deficiency, insulinoma, hypothalamic disorders (e.g., Froelich syndrome, Bardet-Biedl syndrome, Prader-Willi syndrome), or medication use (e.g., antipsychotics); ○ Are in college
Intervention | KQs 1, 2 (screening): Screening involving BMI or other primary care–feasible anthropometric measure; may also involve treatment or referral after screening KQs 3–5 (interventions):; - Designed to promote weight reduction or stabilization, or maintenance of previous weight reduction or stabilizabtion; - May include the following, alone or in combination:; ○ Behavioral-based interventions; ○ Pharmacological (i.e., orlistat, metformin) interventions; ○ Health system–level interventions (e.g., stepped care, collaborative care); - Must be either conducted in a primary care setting, or feasible in “usual” primary care, or referable from primary care. Must at least involve the health care system in some way (may be limited to recruitment) | KQs 3–5 (interventions):; - Primary prevention in children who are normal weight; - Surgical interventions; - Studies that include elements that cannot be implemented in the health care setting (e.g., changes in the physical/built environment, legislation); - Complementary and alternative medicine approaches (e.g., herbal supplements, acupuncture, Chinese medicine, yoga); - Studies that provide all or most of participants’ food
Comparator | KQs 1, 2 (screening): Usual care, no obesity screening KQs 3–5 (interventions): Control groups with no intervention (e.g., wait-list control, usual care), minimal intervention (e.g., pamphlets, single annual session presenting information similar to what intervention groups receive through usual care in a primary care setting), or attention control (e.g., similar format and intensity of intervention on a different content area) | Comparative effectiveness studies; the following components are too intensive to be considered usual care, so would be considered active comparators, including:; - Personalized prescription for weight loss and exercise based on standardized dietary assessment; - Homework, such as study-provided self-help workbooks; - More than a single annual brief intervention contact (unless content not related to weight loss); Comparator cannot be focused on healthy lifestyle, as this is too similar to intervention programs for weight loss
Outcomes | Child health outcomes:; - Reduced asthma or sleep apnea; - Decreased morbidity from diabetes mellitus or hypertension; - Improved depression or quality of life (including psychosocial distress and functioning); - Physical fitness capacity or performance (not behavioral); - Physical functioning (scores on physical subscales of quality of life measures); - Disability (global measures of disability, such as activities of daily living); Adult health outcomes: Obesity Intermediate outcomes:; - Reduction or appropriate maintenance of weight or adiposity (required outcome). Acceptable measures include weight (kilograms or pounds), age- and sex-normative weight (BMI percentile or z-score for age and sex), relative weight (BMI, percent overweight), total adiposity (e.g., dual-energy x-ray absorptiometry, underwater weight, or comparable), other similar measures, or change in any of these measures; - Weight maintenance after an intervention has ended; - Cardiometabolic measures (only when weight-related measures are also reported): insulin resistance/blood glucose/diabetes, blood pressure/hypertension, lipid levels/dyslipidemia, metabolic syndrome, and polycystic ovarian syndrome; - Liver dysfunction/nonalcoholic fatty liver disease; Adverse effects:; - Labeling; - Stigma or increased body image concerns; - Eating disorder; - Suppressed growth; - Exercise-induced injury; - Serious treatment-related harms at any time after initiation of intervention (i.e., death, medical issue requiring hospitalization or urgent medical treatment) or other treatment-related harms reported in trials meeting inclusion criteria for intermediate or health outcomes | Behavioral outcomes (diet, physical activity)
Timing of outcome assessment | All KQs (except serious harms of pharmacotherapy): ≥6 months after baseline KQ 5 (serious harms of pharmacotherapy): No minimum followup. Serious harms are events resulting in death, hospitalization, or the need for urgent medical treatment
Setting | All KQs: Primary care settings (e.g., pediatrics, internal medicine, family medicine, obstetrics/gynecology, family planning, military health clinics) KQs 3–5 (interventions):; - Other outpatient health care settings; - Phone, mobile, or virtual settings (e.g., online intervention, if there is some connection to a health setting, such as recruitment from a health care setting); - Community or research settings, if there is some connection to a health setting (e.g., recruitment from a health care setting) | - Community/university research laboratories or other nonmedical centers; - College settings; - Mental health clinics (unless recruitment is through primary care screening); - Correctional facilities; - School classrooms; - Worksites; - Inpatient/residential facilities; - Emergency departments
Study design | All KQs: Randomized, controlled trials; controlled clinical trials KQ 5 (harms of weight loss medications): Large comparative cohort or case-control studies with appropriate comparison group; large case-series; large event monitoring studies | All other study designs
Country | Economically developed countries (i.e., countries that are a member of the Organisation for Economic Co-Operation and Development): Australia, Austria, Belgium, Canada, Chile, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Mexico, The Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, United Kingdom, and United States | Countries that are not a member of the Organisation for Economic Co-Operation and Development
Language | English | Languages other than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Abbreviations: BMI=body mass index; KQ=Key Question; USPSTF=U.S. Preventive Services Task Force.

Appendix B Table 2 Quality Assessment

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^110^ | - Valid random assignment? (NA for non-randomized controlled trials); - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?; - Was there risk of contamination?

Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.