# Future Research

Screening for breast cancer has been studied extensively among thousands of women in North America and Europe and as a generalization, has been shown to save lives among women screened. However, mammography is imperfect with known and potential harms resulting from false negative and false positive exams, cumulative radiation exposure and possibly the over-diagnosis and over-treatment of DCIS. Future research should be directed towards developing new screening modalities with better sensitivity and specificity, as well as methods of improving the performance of mammography. Further study of methods to reduce surgical biopsy rates should also be conducted in an effort to reduce invasive workups of positive examinations (including many false positives) with their attendant risks and costs to women. Some of this work has been done in Sweden where combining diagnostic modalities has been shown to reduce biopsy rates. Future research communicating the risks and benefits associated with screening to patients should also be conducted given the mix of each and the individual values involved in weighing the benefits and harms associated with screening.

The issue of whether screening women younger than age 50 with mammography is effective and cost-effective needs further evaluation. The weight of evidence suggests it is beneficial in reducing breast cancer deaths, but at a significant cost in terms of false positive examination evaluation. Two trials are currently underway in Europe designed specifically to evaluate screening among women younger than age 50. Since hormonal milieu seems clearly associated with the occurrence of breast cancer, as well as the test performance of mammography, future research efforts should also involve close evaluation of women's menopausal status as well as exposure to hormone therapy. It is likely that rather than an arbitrary age of 50 for beginning mammography, a biological age associated with hormonal milieu will be the important variable in breast cancer screening with mammography. Further work should be conducted to identify women older than age 70 who do not need further screening as well as those who might benefit. Modeling studies including measures of comorbidity, breast cancer risk factors, and prior screening history, may be useful.

BSE has been studied in three population-based trials, and none have shown benefit. However, 1 trial was conducted in a region with relatively low rates of breast cancer and 2 conducted in areas of relatively poor medical care compared to North America and Europe. Thus, the role of BSE in preventing breast cancer deaths remains uncertain. The theoretical reasoning behind BSE is logical, and further research in its performance in populations with access to other types of screening can be justified, particularly since current screening methods are only associated with mortality reductions in the range of 20% to 30%.

Finally, efforts to identify breast cancer risk factors with high attributable risk, and appropriate prevention strategies, should continue, since currently, even in the best screening settings, the majority of breast cancer deaths are not prevented.