# Summary

- Mammography sensitivity ranges between 77% and 95% and specificity between 94% and 97%. Mammography sensitivity and specificity are reduced among younger women and women with more dense breasts. The positive predictive value of mammograms requiring any further evaluation is 2% to 22% and of mammograms requiring biopsy is 12% to 78%.
- Clinical breast exam sensitivity ranges from 40% to 69% and specificity between 88% and 99%.
- Our meta-analysis pooling all fair-quality studies involving women aged 40 to 74 showed a relative risk of breast cancer mortality of 0.84 (95% CrI, 0.77–0.91) using the most recent trial results.
- Among women younger than age 50, four of the six fair-quality studies evaluating breast cancer screening have suggested or shown benefit, with relative risks ranging from 0.58 to 0.87, one statistically significant. The Canadian trial of 40- to 49-year-old women showed no benefit of mammography plus CBE compared to usual care.
- Our meta-analysis of the 6 fair-quality studies contributing data among women less than age 50 identified a summary relative risk of 0.85 (95% CrI, 0.73–0.99).
- The number needed to invite for screening to prevent one breast cancer death after approximately 14 years of observation is 1,792 among women younger than age 50, 1,224 among women in all age groups, and 838 among women aged 50 to 74.
- None of the trials conducted to date has directly addressed the issue of the appropriate screening interval among any age group. Based on trials to date, it appears mortality reductions among women older than age 50 occur in programs with screening intervals ranging from 12 to 33 months. As discussed above, data from epidemiologic models of tumor growth suggest that breast cancer is more aggressive in women younger than age 50 and thus screening intervals should be shorter if this age group is screened. Among the four trials showing or suggesting a screening benefit in this age group, screening intervals have ranged from 12 to 24 months.
- Mammography performance among older women generally is good, with two studies suggesting benefit up to ages 70 and 74. Although there are no trial data evaluating screening in women older than age 74, based on trial findings up to that age and studies of mammography accuracy, the benefit of mammography in women older than age 74 could be significant, but its impact depends on the women's number of comorbid conditions as well as potentially on their past mammographic history.
- The adverse consequences of screening include false negative results and false reassurance, false positive results with significant numbers of women requiring further evaluation of false positive exams, the small but real risk for radiation induced breast cancer, and the possibility of over-diagnosis and over-treatment of some cases of DCIS.
- BSE has not been shown to reduce breast cancer mortality in the best studies to date.
- There are no direct data supporting the use of CBE in reducing breast cancer mortality.