# Results

## A. What are the Test Characteristics of Mammography?

Several limitations of the literature make it difficult to compare (or combine) estimates of mammography accuracy from different studies. ^36^ First, the definition of breast cancer varies within studies. For example, in situ cancers are considered positive in most studies and are excluded from others. ^61^ Second, studies handle uninterpretable or unsatisfactory mammograms differently, making it difficult to determine whether a result leads to biopsy (which would be counted as a false positive test result) or to a repeat mammogram (which might not). Third, biopsies are not done when the mammogram is normal, so the reported sensitivity of an exam depends on the length and intensity of follow-up, which differs among the studies. Fourth, age and other factors affecting test performance differ among studies. For these reasons, estimates of sensitivity and specificity can vary significantly among studies as well as within the studies, depending on the methods of evaluation and definitions used.

### Sensitivity

The sensitivity of mammography is generally estimated by comparing the number of breast cancers detected on mammography (the numerator) to the total number of breast cancers present (the true positive plus false negative exams) in the denominator. Since no “gold standard” can be applied to the entire screened population for breast cancer screening, generally the number of breast cancers detected by mammogram are compared to those detected using concurrent CBE, plus those which emerge over a period of time, typically 1 to 2 years (interval cancers). Thus, sensitivity will be less when a screening interval is longer as more interval cancers will develop and increase the denominator.

The results of recent, good-quality systematic reviews of the accuracy of mammography in the screening trials are summarized in Table 2. ^36, ^ ^37^ The overall sensitivity for all rounds of screening was lowest in the HIP trial. Otherwise, one study was not clearly better or worse than another. For a 1-year screening interval, the overall sensitivity of first mammography ranged from 77% to 95%. For a 2-year interval, sensitivity was 56% to 86%. The first round screening sensitivity was lowest in the Canadian trials, which used a different criterion for follow-up of abnormal mammograms than the other studies. ^36^ Sensitivity was substantially lower for women in their 40s than for older women.

Table 2. Sensitivity of mammography*

| ALL ROUNDS | | | | FIRST ROUND ONLY
Study | Cases of cancer detected by screening | Total cases of cancer | Per Cent | Estimated sensitivity of mammography (no. of rounds)† | Sensitivity of screening at 1-year intervals | Sensitivity of screening at 2-year intervals
HIP (ages 40–64) | 73 | 173 | 0.42 | 0.39 (4)
Malmo (ages 45–69) | 176 | 227 | 0.78 | 0.61 (2) | .92
45–49 | | | | | .73
50–59 | | | | | .71
60–69 | | | | | .85
70–74 | | | | | .81
Swedish Two-County Trial (ages 40–74) | | | | | .95 | .86
40–49 | 39 | 82 | 0.48 | | .81
50–59 | 102 | 137 | 0.74 | | .96
60–69 | 184 | 220 | 0.84 | | .95
70–74 | 101 | 112 | 0.90 | | .98
Edinburgh (ages 45–64) | 214 | 247 | 0.87 | 0.63 (6 rounds) | .88‡ | .58‡
Stockholm (ages 40–64) | | | | | .86 | .68
40–49 | 24 | 45 | 0.53 | 0.64 | | .53
50–59 | 71 | 95 | 0.75 | 0.89 | | .75
60–64 | 33 | 48 | 0.69 | | | .69
CNBSS-1 (ages 40–49) | 162 | 286 | 0.57 | 0.61 (4) | .77 | 0.56
CNBSS-2 (ages 50–59) | 243 | 347 | 0.70 | 0.66 (4) | .88 | .56

* Gothenburg is not listed because of insufficient data; the Edinburgh tial is excluded. Empty cells also indicate lack of sufficient data. All data are taken from reference 36, using the “detection” method, unless otherwise noted.

† Data taken from reference 37.

Note: CNBSS indicates Canadian National Breast Screening Study; HIP, Health Insurance Plan of Greater New York.

The data in Table 2 cannot be applied to individual patients because they are not adjusted for several factors that are known to affect sensitivity. These include patient factors (use of hormone replacement therapy, mammographic breast density), technical factors (the quality of mammograms, the number of mammographic views), and provider factors (the experience of radiologists and their propensity to label an exam abnormal, and the choice of follow-up evaluation for abnormal mammograms). ^36, ^ ^62–65^

### Specificity

Specificity of mammography can be calculated using the workup method where mammograms are considered positive if the patient is referred for further evaluation. ^36^ Typically, this involves a CBE or an extra mammographic view and/or ultrasound. Another method of evaluating specificity is the biopsy method in which mammograms are considered positive if the woman is referred for biopsy, a more invasive outcome of a positive exam. In the randomized trials, the specificity of a single mammographic examination was 94% to 97% using the workup method. ^35, ^ ^36, ^ ^66, ^ ^67^ This indicates that 3% to 6% of women who did not have cancer underwent further diagnostic evaluation, typically a clinical examination, more mammographic views, or ultrasound. Using the biopsy method, the specificity in the randomized trials was 93.5% to 99.1%. ^35, ^ ^36, ^ ^66, ^ ^67^

Specificity is generally substantially lower in prevalent (baseline) screens than in incident (repeat) screens. ^66^ Other program factors that affect specificity are the screening interval ^68–70^ and the availability of prior mammograms for comparison. ^71^ Shorter screening intervals and review of prior mammograms have been shown to increase specificity. The sensitivity and specificity of mammography also vary with the number of mammographic views used. When the sensitivity of 1-view mammography has been compared to 2-view, sensitivity has been shown to be 7% to 24% higher with 2-view mammography. ^70, ^ ^72, ^ ^73^ Computer-aided detection also has been shown to decrease false negative rates significantly without reducing specificity. ^70, ^ ^72, ^ ^73^ One study suggests that 50% of false positive mammograms could be eliminated by performing 2 view studies. ^74^

For an individual undergoing regular mammograms, the cumulative specificity of mammography may be more relevant than the single-study specificity. A study conducted in a large health maintenance organization (HMO) setting evaluated mammography experience among 2,400 women aged 40 to 69 randomly selected from the HMO population. ^75^ On average, these women underwent mammography screening every 2 years and approximately 9,762 mammograms were obtained for 2,227 women over 10 years. In this community setting, the false positive rate of mammograms using the workup method was 6.5% for a specificity of 93.5%. When evaluated by the individual, however, approximately 24% of women had at least 1 false positive mammogram requiring further workup during 10 years of screening. Factors associated with decreased specificity included family history of breast cancer, estrogen use, number of prior breast biopsies, lack of comparison with previous mammogram, greater time between mammograms, and radiologist's tendency to label a mammogram abnormal. ^76^ For example, the range of false positive mammograms was 2.6% to 24.4% among the 35 radiologists reading at least 25 mammograms in this study. In this study, the radiologist's tendency to read a mammogram as abnormal had the largest effect on a woman's risk for experiencing a false positive exam.

### Predictive Value

Data derived from RCTs of mammography show positive predictive values of 2% to 22% for abnormal mammograms requiring further evaluation, typically a clinical examination, more mammographic views, or ultrasound. ^35^ Among the trials, the positive predictive value, or ratio of cancer cases to all cases requiring biopsy, ranged from 12% to 78%, indicating marked variation in propensity to biopsy among the studies (Table 3). ^35, ^ ^36^ Positive predictive value increases with increasing prevalence of breast cancer and therefore, increases with age. ^77^ Estimates from community settings suggest a graded, continuous increase in predictive value with age. For example, among 31,814 average-risk women screened in California from 1985 to 1992, the positive predictive value for further evaluation was 1% to 4% among women aged 40 to 49, 4% to 9% among women aged 50 to 59, 10% to 19% among women aged 60 to 69, and 18% to 20% among women aged 70 and older. ^77^

Table 3. Specificity and positive predictive value*

Study | Specificity(%) | Positive Predictive Value (%)
| [underlined: work-up method] | [underlined: work-up method] | [underlined: biopsy method]
HIP | NR
Malmo | 97.4 | 10–22 | 33–61
Swedish Two-County Trial | 95.6 | 12 | 50–75
Stockholm | 95.1 | 8–10 | 62–78
CNBSS-1 | 93.5 | 2 | 12
CNBSS-2 | | 4–6 | 20
Gothenburg | | 3–7 (complete mammography) 12–18 (CBE and FNA biopsy)
| | 12–18 (CBE and FNA biopsy)

* Adapted from references 36 and 45. Work-up method, a mammogram requiring further evaluation; biopsy method, a mammogram resulting in biopsy.

Note: CBE indicates clinical breast examination; CNBSS, Canadian National Breast Screening Study; FNA, fine-needle aspiration; HIP, Health Insurance Plan of Greater New York; NR, not reported.

In some community practices, two levels of positive mammograms are reported: “additional evaluation needed” or “suspicious for malignancy.” In a series of 26,057 women from Northern California, 92.9% of abnormal first mammograms were reported as “additional evaluation needed.” The positive predictive values of these mammograms (that is, the risk for breast cancer) were 1% for women aged 30 to 39, 2% for women aged 40 to 49, 5% for women aged 50 to 59, and 7% for women aged 60 and older. Mammograms that were read as “suspicious for malignancy” were associated with a risk for breast cancer about 10 times greater than when mammography was reported as “additional evaluation needed.” ^78^

### How do Age and Other Factors Affect Test Performance?

Sensitivity tends to be lower among women younger than 50, ranging from 43% to 87% in the randomized trials ^36, ^ ^79^ and in good cohort studies. ^65, ^ ^78^ There is indirect evidence that, among younger women, a higher proportion of cancers are fast-growing, resulting in more incident breast cancers presenting between screening periods (interval cancers), which also decreases the sensitivity of the test. ^65^ Thus, sensitivity varies with screening interval. Sensitivity may be higher in older women because the growth rate of breast cancer tends to be slower. ^80, ^ ^81^

Specificity is lower among younger women. ^77, ^ ^82, ^ ^83^ In the HMO study described above, the rate of false positive exams using the workup method was 7.8% among women aged 40 to 49, 7.4% among women aged 50 to 59, 5.3% among women aged 60 to 69, and 4.4% among women aged 70 to 79. ^75^ These data suggest that there are not abrupt changes in specificity with age, rather, a graded relationship.

Although age has been considered an important variable in mammography performance, another important parameter is mammographic breast density. ^65, ^ ^84, ^ ^85^ Younger women tend to have greater breast density which may reflect hormonal milieu, specifically exposure to estrogen and progesterone. ^64, ^ ^65^ After menopause, fatty tissue replaces fibroglandular breast tissue, resulting in increased radiographic transparency. ^86^ Higher breast density, which is more common in premenopausal women, can cause false negative test results. ^87^ In one recent study of 536 breast cancer cases from a large HMO, the sensitivity of mammography was 80% among women with predominantly fatty breasts but only 30% in women with extremely dense breasts. ^85^ However, the association between higher breast density and lower sensitivity was only statistically significant among women older than age 50, though the point estimates (RR~6) were similar among women younger than age 50. Two other studies have shown lower sensitivity among women younger than age 50 with higher breast density, ^88, ^ ^89^ and one has not. ^65^ The Canadian trial of mammography showed that rates of false negative mammograms increase during the luteal phase of the menstrual cycle when estrogen levels are typically higher and breast density may be higher ^90^ ; sensitivity was 59% during the follicular phase and 49% during the luteal phase of the menstrual cycle among women aged 40 to 44 at the onset of screening.

The sensitivity of mammography is decreased in women who take postmenopausal progesterone and/or estrogen, which may be associated with breast density. ^63, ^ ^64, ^ ^91^ In the Postmenopausal Estrogen/Progestin Interventions (PEPI) trial, ^63^ for example, breast density increased in about a third of women in the estrogen plus progesterone arm. The use of hormone replacement therapy (HRT) reduces the accuracy of mammography. In one retrospective cohort study of 8,779 women enrolled in an HMO, mammography sensitivity was 94% among those who had never used HRT and 69% among those who were using HRT at the time of assessment. ^62^ Similar data come from a review of over 100,000 screening mammograms, which showed sensitivity of 81% in non-users and 74% among estrogen users. ^89^ HRT also decreases the specificity of mammography. In the HMO study, ^62^ the specificity of mammography was 86% among those who had never used HRT and those who used HRT prior to, but not during, assessment. However, the specificity decreased to 82% among women who were using HRT at the time of assessment. In the other HMO study described above, specificity also was decreased among those who were using estrogen at the time of assessment. ^76^

Mammographic performance among women with a family history of breast cancer has been evaluated in three studies. In one study involving 31,814 women aged 30 and older, mammograms from women with a family history of breast cancer were found to have higher positive predictive values for cancer (13% among women aged 40 to 49 and 22% among women aged 50 to 59). ^77^ Another study among 389,533 women also suggested higher predictive values among women with a positive family history of breast cancer. ^92^ In contrast, in the larger HMO study described above, specificity was decreased among women with a positive family history of breast cancer. ^76^ Other data from multiple mammography registries indicates that sensitivity was decreased slightly, but not significantly, among women with a positive family history of breast cancer. ^92^ Thus, although age has been used as a method for evaluating mammography performance and outcome, it is a relatively arbitrary parameter and it is likely that other parameters such as hormonal milieu, which correlates with age and might be characterized by menopausal status and/or exogenous hormone exposure, are also important.

## B. What are the Test Characteristics of Clinical Breast Exam?

The sensitivity of CBE in a clinical setting can be evaluated in two ways. The first involves direct comparison with another screening modality. The second involves comparing cancers detected using CBE with those detected by mammography plus those detected in the interval after the screening clinical breast exam, interval cancers. The second method is the more common method for determining the sensitivity of an exam in breast cancer screening trials since no “gold standard” is applied to the entire screened population. In essence, concurrent mammography and/or time become the gold standard to which clinical breast exam is compared.

A recent review evaluated the sensitivity of CBE, as defined by the second method, and found sensitivity to range from 40% to 69% among various screening studies with a summary sensitivity of 54.1%. ^93^ This represents sensitivity estimates from trials designed specifically for breast cancer screening. Recent data from a community program evaluating 752,081 clinical breast exams showed sensitivity of 58.8% among all women screened. ^94^ The highest reported sensitivity (68%) comes from the Canadian National Breast Screening Studies where skilled examiners took between 10 and 15 minutes to complete examination of both breasts. ^95^

The sensitivity and specificity of CBE also vary by age. In the CNBSS-1 women aged 40 to 49 were randomized after a prescreening CBE to either CBE plus mammography at the first exam or usual care; the sensitivity of clinical breast exam was 68%. ^96^ In the CNBSS-2, involving women aged 50 to 59, the sensitivity of clinical breast exam was 63%. Sensitivity was also higher among younger women in the community study described above, ^94^ ranging from 71% (among women aged 40 to 49) to 57% (among women aged 50 to 59) to 38% (among women older than 70). The reason(s) for these differences in test performance by age are uncertain but may include hormonal milieu, breast density, body size, or other age-associated changes.

Specificity in a study setting ranges between 88% and 99%, with an average of 94% after pooling trial data. ^93^ Recent data from community settings involving CBE and a population specifically seeking CBE identified a specificity of 93.4%. ^94^ In 1998, data were published evaluating false positive CBEs in a large HMO in Boston involving 2,400 women between ages 40 and 69. ^44^ False positive results using the workup method occurred in 3.7% of all CBEs, indicating a specificity of 96.3%, consistent with the results obtained in study settings. Over 10 years of biennial CBE, 13.4% of women had at least one false positive CBE. The false positive rate also varied by age. Women aged 40 to 49 had false positive rates of 6.0% and women aged 70 to 79 had false positive rates of 2.2%. The cumulative risk for a false positive CBE in this study after 10 years was 22.3% for CBE. However, after five examinations, the cumulative risk was higher in women younger than age 50 (20.8%) than among women older than age 50 (11.1%). ^75^

The positive predictive value of CBE reflects the likelihood that an abnormal CBE indicates cancer. Among multiple studies evaluating CBE, the positive predictive value ranged from 4% to 50%. ^93^ In the community study described above, the positive predictive value of an abnormal CBE was 4.3%, ^94^ indicating that 95.7% of all abnormal CBEs (and requiring further evaluation) were not associated with a diagnosis of breast cancer. Predictive value is significantly affected by the prevalence of the disorder in the screened population and by the propensity to label an exam abnormal. Predictive value will consistently be lower among younger women than among older women because rates of breast cancer are lower among younger women. Thus, in a study with volunteers, where individuals with symptoms may seek care disproportionately to those without symptoms, the predictive value may be inflated artificially when compared to a totally asymptomatic population. In addition, in a population-based setting as opposed to a study setting, rates of positive exams (the numerator), while less standardized than in a study setting, may better reflect community practice than those of studies where very experienced examiners conduct CBEs.

Because mammography is a more sensitive breast cancer detection tool than CBE, the question arises as to the marginal contribution of CBE to breast cancer screening. As shown in Table 4, the contribution of CBE has varied significantly by study, which likely reflects both mammography and breast exam quality. Among studies that have included CBE in breast cancer screening programs, the contribution of CBE alone to breast cancer detection has ranged from 3% to 45%. ^93^ In study and community settings, the proportion of all breast cancer detected by CBE is higher in younger women compared to older (>50 years) women. ^58, ^ ^59, ^ ^94, ^ ^97^

Table 4. Proportion of breast cancer detected by clinical examination and mammography in randomized trials*

| | | Method of Detection
Study | Years | Number of Cancers | Both | Mammography | CBE only
| | | | %
HIP | 1963-1966 | 132 | 22 | 33 | 45
Edinburgh† | 1978-1981 | 88 | 71 | 26 | 3
CNBSS-1 | 1980-1988 | 255 | 36 | 40 | 24
CNBSS-2 | 1980-1988 | 325 | 35 | 53 | 12
BCDDP‡ | 1973-1980 | 4,051 | 45.5 | 43.7 | 10.8
Ages 40–49 | | | 45.2 | 49.6 | 5.2
Ages 50–59

* Adapted and modified from Barton, 1999, 93

† Roberts MM, Alexander FE, Anderson TJ, et al. Edinburgh trial of screening for breast cancer: mortality at seven years. Lancet. 1990;335(8684):241–246.

‡ Smart CR, Byrne C, Smith RA, et al. Twenty-year follow-up of the breast cancers diagnosed during the Breast Cancer Detection Demonstration Project.

CA Cancer J Clin. 1997;47(3):134–149.

Note: BCDDP indicates Breast Cancer Detection Demonstration Project; CBE, clincial breast examination.

## C. What are the Test Characteristics of Breast Self-Examination?

Although there have been many observational studies of breast self-examination, the accuracy of BSE is largely unknown, due to limited formal evaluation. In the Breast Cancer Detection Demonstration Project, the sensitivity of BSE alone was 26% when compared with CBE and mammography. In this study, sensitivity also decreased with age. BSE had a sensitivity of 41% in women aged 35 to 39 and 21% among women aged 60 to 74. ^98^ Another study found the sensitivity of BSE to range between 12% and 25%. ^35^ Some studies have shown that the sensitivity of the BSE improves with training. ^99, ^ ^100^ The specificity of the BSE remains uncertain, though as will be discussed below, recommendations for BSE have been shown to increase physician visits. ^44^

## D. Is Mammography Effective in Reducing Mortality and Morbidity from Breast Cancer in Women Aged 39 and Older?

Eight randomized controlled trials of breast cancer screening have been conducted. ^30, ^ ^56, ^ ^58, ^ ^59, ^ ^101–110, ^ ^111^ The trials varied in recruitment of subjects, mammography protocol, control arms, and size (Table 1). Six trials examined the effectiveness of screening among women between the ages of 40 and 74; one trial enrolled women in their 40s, and one enrolled only women in their 50s. The 4 trials from Sweden tested mammography only, ^30, ^ ^101–103, ^ ^105, ^ ^111, ^ ^112^ and the other 4 tested mammography and CBE. ^58, ^ ^59, ^ ^106–109, ^ ^113^

All trials compared breast cancer mortality in the screening and control groups on an intention-to-treat basis. Six studies randomized women to an invitation-to-screening or a control group who received “usual care” at the time the study was conducted. Two trials enrolled volunteers who underwent a pre-examination with CBE before they were randomized to the intervention or control group. ^58, ^ ^59^

### Assessment of Study Quality

We found important methodologic limitations in all the trials and rated all but one as fair quality using USPSTF criteria. ^45^ Table 1 lists the flaws of each trial and indicates how these influenced the overall ratings. The two reviewers rated the Swedish and Canadian trials fair or fair plus. Their initial ratings for Edinburgh and the Health Insurance Plan of Greater New York study (HIP) differed. After extensive peer review, and detailed review of these trials' associated publications, the consensus was that HIP should be rated fair and Edinburgh should be rated poor.

The HIP trial (conducted from 1963 to 1966) was the first trial of breast cancer screening. It is difficult to critically appraise because publications describing it differ in detail from more recent publications. We found several limitations of this trial, including inadequate description of allocation concealment and poor reporting of intervention and control group numbers. In addition, we found better ascertainment of clinical parameters (including prior mastectomy) among the invitation-to-screening cohort than among the passively followed control group. However, we viewed this as an expected consequence of the study design in which a control group receives “usual care” and is not contacted. The screening and control groups differed from each other slightly in education, menopausal status and prior breast lumps, but not in a systematic manner favoring one group over the other. The strengths of the trial included intention-to-treat analysis, little contamination, and blind review of deaths. We did not find the faults great enough to rate the study poor in quality and rated it fair, signifying that the results were probably valid at the time the study was conducted.

Based on the USPSTF criteria, the Canadian trials met all of the standards for a rating of good quality except for adequacy of allocation concealment. The Canadian trials differed from the other trials in that all participants had their history taken and a physical examination prior to randomization. This design permitted exclusion of patients who had a prior history of breast cancer before randomization and extensive examination of the baseline differences between groups.

The Swedish trials all had limitations that resulted in a rating of fair rather than good. The Stockholm and Malmo trials, which were individually randomized, did not report whether allocation was concealed. The Gothenburg and Swedish Two-County studies, which were cluster-randomized, had small differences in mean age between the invited and control groups. Such differences are expected to occur in a cluster-randomized trial, do not necessarily indicate that randomization failed or that there was a problem in the execution of the trial, and can be adjusted for in statistical analyses. ^114^ Both trials provided insufficient data to determine whether randomization distributed other important confounders equally among the groups, but comparison of overall mortality rates in the invited and control groups does not suggest that a major imbalance occurred. ^115^

As originally conducted, the Swedish trials had important flaws related to measurement of the primary outcome measure, breast cancer death. In the Two-County, Gothenburg, and Stockholm trials, review of deaths was unblinded and criteria for the assignment of cause of death were unclear. Another concern about the Swedish trials as a group related to screening of the control groups. Originally, the Swedish trials used the “evaluation” method of analysis, in which mortality in the screened population is calculated only for cancers diagnosed between the time of randomization and the last mammographic examination. When the evaluation method of analysis is used, screening the control group can introduce bias unless it is performed concurrently with the last mammogram in the screened group. ^34, ^ ^116^ This method is inferior to the “follow-up” method of analysis, in which all deaths that occur after randomization are included in the analysis. The follow-up method of analysis has the effect of diluting relative benefit over time, particularly in studies that offered screening to the control group and in areas where widespread screening was adopted. It has the advantage, however, of providing a method for identifying any late harms associated with screening and/or the treatment of the disease.

We considered these flaws to be adequately corrected in subsequent analyses by the trialists. Blind assessment of cause of death was conducted by an independent endpoint committee using an explicit protocol in a 1993 overview of the trials. ^17^ Subjects were linked to an external cancer registry and excluded from the analysis if breast cancer had been diagnosed before the trial began. For the Swedish trials as a whole, mortality from every cause except breast cancer was similar in the compared groups. ^30, ^ ^117^ In the Two-County study, the reduction in rates of advanced breast cancer, ^118^ which are not related to judgments about the causes of death, was similar to the reduction in breast cancer mortality. ^119^ The 1993 overview also re-analyzed the data using the follow-up method of analysis; there was very little difference between the recalculated and original relative risk values. A recent review ^24^ critical of the Swedish studies raised concern about bias in post-randomization exclusions, as evidenced by variation in the reported number of subjects. This concern was effectively addressed in a recent update of these trials, which explained that this variation was due to the use of different methods for estimating the number of women in each birth cohort, rather than to manipulation after randomization. ^30^ The update also reported more recent results of the Swedish trials using the follow-up method of analysis, which showed some dilution of screening benefit when compared to the evaluation method.

We rated the Edinburgh study poor quality because of a serious imbalance between the control and screened groups. General practitioners' practices were randomized in clusters without matching for socioeconomic factors. The result was that socioeconomic status, a predictor of stage at diagnosis, as well as breast cancer mortality, was significantly lower in the control group than in the mammography group. In addition, all-cause mortality was dramatically higher in the control group than in the screened group—20.1 more deaths per 10,000 person-years (95% confidence interval [CI], 13.3 to 26.9). ^115^ This difference is close to 25 times larger than the difference in breast cancer mortality between the groups and confirms our assessment that the trial was fatally flawed.

### Results of Trials

Table 5 (top panel) shows the most recent results of the four trials that compared mammography alone to usual care. In the four Swedish trials, ^17, ^ ^30,^ ^101, ^ ^105, ^ ^112^ mammography alone was associated with a reduced relative risk for breast cancer death in all of the studies (range, 0.68 to 0.91). However, only the Swedish Two-County study showed a statistically significant reduced relative risk (RR, 0.68; 95% CI, 0.59–0.80). In these studies, two to six rounds of mammography prevented one breast cancer death for approximately every 1,000 (range 553 to 3,468) women screened. All-cause mortality was not an endpoint in any of these studies. Study characteristics, such as the number or frequency of mammograms, did not explain the variation among the Swedish studies. Two-view mammography did not seem to give better mortality reductions than one view. Also, the best mortality reduction (among all women) was seen in the Swedish Two-County study, which had the longest screening interval (24–33 months). ^112^ A previous meta-analysis found little change in the results when the individual trial results were adjusted for the type of randomization and degree of compliance. ^54^

Table 5. Randomized controlled trials of mammography among women aged 39–74

Study (reference) | Ages | Median follow-up (years) | Number of breast cancer deaths/ total number of women | | Breast cancer death rate per 1,000 women | | | Relative risk for breast cancer death (95% Confidence Interval) | Absolute risk reduction per 1,000 women | Number needed to invite*
| | | [underlined: Screened] | [underlined: Control] | [underlined: Screened] | [underlined: Control]
Studies of mammography alone
Stockholm (30) | 40–64 | 13.8 | 82/39,139 | 50/20,978 | 2.10 | 2.38 | 0.91 (0.65–1.27) | 0.288 | 3,468
Gothenburg (30) | 39–59 | 12.8 | 62/20,724 | 113/29,200 | 2.99 | 3.87 | 0.76 (0.56–1.04) | 0.878 | 1,139
Malmo (30) | 45–70 | 17.1 | 161/21,088 | 198/21,195 | 7.63 | 9.35 | 0.82 (0.67–1.00) | 1.712 | 584
Swedish Two-County Trial (112) | 40–74 | 17 | 319/77,080 | 333/55,985 | 4.14 | 5.95 | 0.68 (0.59–0.80) | 1.809 | 553
Studies of mammography plus CBE
CNBSS-1 (56) | 40–49 | 13 | 105/25,214 | 108/25,216 | 4.16 | 4.28 | 0.97 (0.74–1.27) | 0.12
CNBSS-2 (108) | 50–59 | 13 | 107/19,711 | 105/19,694 | 5.43 | 5.33 | 1.02 (0.78–1.33) | -0.097
HIP (107) | 40–64 | 16 | 232/30,239 | 281/30,256 | 5.46 | 6.89 | 0.79 | 1.438 | 883
Edinburgh (106) | 45–64 | 13 | 156/22,926 | 167/21,342 | 6.80 | 7.82 | 0.79 (0.60–1.02) | 1.02 | 980

* Number needed to invite for screening to prevent one death from breast cancer 13–20 years after randomization.

Note: CBE indicates clinical breast examination; CNBSS, Canadian National Breast Screening Study; HIP, Health Insurance Plan of Greater New York.

Four studies including women aged 50 years and older have evaluated breast cancer screening with mammography and CBE (Table 5, bottom panel) ^56, ^ ^58, ^ ^59, ^ ^106, ^ ^108, ^ ^120^ ; two were rated fair quality and one poor quality. In the CNBSS-2, women aged 50 to 59 were recruited using mass media and, after a pre-examination with CBE, randomized to either annual CBE or annual CBE plus mammography. The CBEs were quite systematic and were conducted by either physicians or highly trained nurses and ranged in duration from 10 to 15 minutes. ^121^ In addition, all women were instructed in BSE, which was reinforced at each annual visit. In the HIP and Edinburgh studies, the control group received usual care. (The CNBSS-1 was specifically designed to evaluate screening among women aged 40 to 49 and its results will be discussed in that section of this review.)

The HIP Study began in 1963 and involved randomization of approximately 62,000 women to screening with mammography and CBE every year for 4 consecutive years or to usual care. ^113, ^ ^120^ Among those invited, 67% of women were screened at least once during the study. After 10 to 14 years of follow-up, screened women aged 40 to 64 had a mortality reduction of 22% (95% CI, 4%-37%). ^113^ At 18 years of follow-up, this mortality reduction persisted at 23.7% (95% CI not reported). ^113^

In the Edinburgh Study, general practices (rather than individual patients) were randomized. Women (n=22,926) aged 45 to 64 in half of the practices were invited for mammography, while in control practices they continued usual care (n=21,342). Apparently as a result of this method of randomization, women in the screened group had higher socioeconomic status and lower all-cause mortality than those in the control group. ^106^ After 10 years there was a relative risk reduction of 0.82 (95% CI, 0.61–1.11). After 14 years of follow-up and an analysis involving a statistical adjustment for differences in socioeconomic status, the adjusted relative risk for breast cancer for the entire population invited to screening was 0.79 (95% CI, 0.60–1.02). As noted above, the method of randomization in this study resulted in a marked disparity in the two groups' socioeconomic status and high potential for bias in the results. Thus, this study is rated poor quality and its results are excluded from all meta-analyses.

In our meta-analysis of results from all age groups combined, we excluded Edinburgh and used the results from both Canadian trials. The summary relative risk was 0.84 (95% CrI, 0.77 – 0.91), equivalent to a number needed to screen of 1,224 (95% CrI, 665–2564) an average of 14 years after study entry. To estimate the effectiveness of an invitation to screen compared with usual care, we also excluded the Canadian trials, which recruited volunteers. The relative risk reduction was 0.81 (95% CrI, 0.73–0.89) and the number needed to invite to screen was 1,008 (95% CrI, 531–2128) The relative risks by year of observation (including trial plus follow-up time) are shown in Figure 3, which suggests a gradual decrease in screening benefit with longer observation time.

Figure 3. Relative risks by average follow-up years for all age cohorts

Among women aged 50 or older, the summary relative risk was 0.78 (95% CrI, 0.70–0.87) after 14 years of observation, with a number needed to screen of 838 (95% CrI, 494–1676) to prevent one death from breast cancer. As shown in Figure 4, the screening benefit has decreased with longer duration of follow-up.

Figure 4. Relative risks by average follow-up years for women ages 50–74

## E. Is Breast Cancer Screening Effective Among Women Aged 40 to 49?

### Issues Underlying the Controversy

Breast cancer occurring in women aged 40 to 49 is an important cause of morbidity and mortality and is the single leading cause of death for women aged 40 to 49 in the U.S. ^122–124^ Approximately 20% of new cases and deaths occur in this age group. Among women aged 50 or younger, breast cancer accounts for approximately 41% of the years of potential life loss before age 80. ^125^ Since the risk for breast cancer increases with age and there is a continuum of risk, an arbitrary cutoff such as age 50 is an artificial parameter. However, because the effectiveness of screening has been evaluated using age 50 as a cutoff, we report our findings similarly. We believe that hormonal milieu, breast density, and increasing age, all inter-related to a variable extent, are the most important individual factors influencing the effectiveness of breast cancer screening with mammography.

There are several potential reasons why breast cancer screening benefits might differ among younger versus older women. First, the risk for breast cancer is lower among younger women; for every 1,000 women who turn 40, 16 will develop breast cancer within a decade. ^122,^ ^126^ Second, the risk of dying from breast cancer is lower among younger women. Based on results in the control group of the HIP study, more than half (58%) of women would be expected to survive 18 years regardless of screening. For women aged 40 to 44, the risk of dying of breast cancer in the next 10 years is 3 per 1,000. Thus, identifying a mortality benefit among women aged 40 to 49 will require longer follow-up. Third, as discussed earlier, the sensitivity, specificity, and predictive value of mammography are lower in younger women ^77^ (there does not, however, seem to be an abrupt change at age 50). Fourth, some indirect evidence from mathematical models of cancer growth indicate that the detectable preclinical phase of breast cancer (sojourn time) increases with patient age. Data from the Swedish Two-County trial have been used to estimate a mean sojourn time for women aged 40 to 49 of 1.7 to 2.5 years (95% CI, 1.4–2.1) ^127^ and for women aged 50 to 69, between 3.3 and 3.8 years. ^128, ^ ^129^ Among women aged 40 to 49 the rate of interval cancers in the first year after screening was 40% of the control rate and in the second year, 70%. ^130^ For women aged 50 and older, interval cancers were seen less often in the first 2 years after screening, but were 50% of the control rate in the third year. ^130^ This suggests that the period of time in which breast cancer can be detected, but is preclinical, is significantly shorter among younger women. Data from the Swedish Two-County study have been used in a Markov model to evaluate breast cancer progression, and these data have suggested that tumor progression is more rapid among women younger than age 50 than among older women, with estimates of tumor doubling time among women aged 40 to 49 of 80 days compared with 157 days for women aged 50 to 70. ^131^ The shorter doubling time among younger women suggests that yearly or biennial mammograms might fail to diagnose as many cancers among younger women (compared to women older than age 50) while they are still in a curable stage. Finally, an analysis of the Swedish Two-County study indicated that deterioration of tumor malignancy grade occurs more rapidly among younger women as compared to older women, even when matched by tumor size. ^128^ Thus, results from screening trials where length of time between screening intervals is longer may result in decreased effectiveness among women in this age group.

### Recent Results of Randomized Trials

Beginning in 1963, seven RCTs that included about 200,000 women between ages 40 and 49 have been conducted. With the exception of the CNBSS-1 study, none of the trials were planned to evaluate breast cancer screening in this age subgroup and none of the studies, including the CNBSS-1, were designed with sufficient power to evaluate the question. This is particularly true when contamination among the controls and non-compliance of the screening groups is considered.

Table 6 summarizes results of these studies, and details of each study are provided in Appendix 2. Two trials, Stockholm and CNBSS-1, showed no benefit for this age group even with longer follow-up. The other five trials suggest a benefit (risk reduction, 13%-42%), one (Gothenburg) statistically significant. These findings reflect results after 11 to 19 years of observation, of which the median period of active screening was 6 years (range 4–15 years). Of the two studies showing no benefit, the Stockholm trial compared one-view mammography (n~15,000) over two screens at a 24- to 28-month interval to usual care (n~7,000). In the Stockholm study, after 14.3 years of follow-up, no mortality reduction was shown among the screened women (RR, 1.52; 95% CI, 0.80–2.88). ^30, ^ ^105^ The other (CNBSS-1) compared CBE and five rounds of annual two-view mammography to baseline screening with CBE, followed by usual care (n~25,000 in each group). In the Canadian study, after 13 years of follow-up, no mortality benefit was shown among the screened population (RR, 0.97; 95% CI, 0.74–1.27). ^56, ^ ^59, ^ ^109^ Notably, the lack of benefit applies to the combination of mammography with fairly diligent clinical breast exam, suggesting no benefit of CBE as well in this age group. As discussed, the Canadian trials have been criticized extensively because of concerns about randomization and significant concern from the radiology community about mammographic quality, some of which were raised prior to publication of the findings from the study. These concerns have been reviewed at length without resolution. ^132–138^

Table 6. Results of mammography trials among women younger than 50 years of age

Study (reference) | Ages | Median follow-up (years) | Number of Breast Cancer Deaths/Total Number of Women | | Breast Cancer Death Rate per 1000 women | | Relative Risk for Cancer Death (95% Credible Interval) | Absolute Risk Reduction per 1,000 women | Number needed to invite* | Follow-up year controls screened
| | | [underlined: Screened] | [underlined: Control] | [underlined: Screened] | [underlined: Control]
Studies of mammography alone
Stockholm (30,105) | 40–49 | 14.3 | 34/14,842 | 13/7,103 | 2.29 | 1.83 | 1.52 (0.8–2.88) | No reduction | | 5
Gothenburg (30,101) | 39–49 | 12.7 | 22/11,724 | 46/14,217 | 1.88 | 3.24 | 0.58 (0.35–0.96) | 1.36 | 736 | 7
Malmo (30) | 45–50 | 13.3 | 53/13,568 | 66/12,279 | 3.91 | 5.38 | 0.73 (0.51–1.04) | 1.47 | 681 | 4
Swedish Two-County Trial (104) | 40–49 | 13 | 45/19,844 | 39/15,604 | 2.27 | 2.50 | 0.87 (0.54–1.41) | 0.23 | 4316 | 7–8
Studies of mammography plus CBE
CNBSS-1 (56) | 40–49 | 13 | 105/25,214 | 108/25,216 | 4.16 | 4.28 | 0.97 (0.74–1.27) | 0.12
HIP (107,113) | 40–49 | 14 | 64/13,740 | 82/13,740 | 4.66 | 5.97 | 0.78 (0.56–1.08) | 1.31 | 763
Edinburgh (106) | 45–49 | 13 | 49/11,749 | 53/10,267 | 4.17 | 5.16 | 0.75 (0.48–1.18) | 0.99 | 1008 | 6–10

* Number needed to invite for screening to prevent one breast cancer death after 11–16 years.

Note: CBE indicates clinical breast examination; CNBSS, Canadian National Breast Screening Study; HIP, Health Insurance Plan of Greater New York.

Among studies showing or suggesting benefit, the mortality curves for the screening and control groups began to diverge 5 to 7 years after randomization. ^102, ^ ^112, ^ ^113, ^ ^120^ The mortality curves continued to diverge for an additional 5 to 10 years of follow-up.

In the Malmo study, after approximately 15 years of observation, the risk for breast cancer was decreased by 27% among screened women (RR, 0.73; 95% CI, 0.51–1.04), ^30^ with the survival difference beginning to emerge at approximately year 5. ^103^ Similar findings come from the Gothenburg study; after 5 rounds of screening and approximately 13 years of observation, breast cancer mortality was decreased by 45% among women invited for screening (RR, 0.58; 95% CI, 0.35–0.96). ^30, ^ ^101, ^ ^102^ These 2 studies had shorter screening intervals (18–24 months), more screening rounds, and longer follow-up than many of the other studies.

Two other fair-quality studies also have relative risk reductions lower than 1, but the findings are not statistically significant. The HIP trial involved approximately 27,000 women aged 40 to 49 randomized to either usual care or 4 annual breast cancer screens with clinical breast exam and mammography. ^113^ After 14 years of follow-up, the relative risk of breast cancer mortality was 0.78 (95% CI, 0.56–1.08). For women aged 40 to 45 at entry, the mortality reduction began to emerge at approximately year 7; for women aged 45 to 49, it began at approximately year 5. Another analysis of this study considering only breast cancer deaths among breast cancer cases diagnosed within 6 years of randomization identified a statistically significant mortality reduction (RR, 24% decrease; 95% CI, 3%-41%). These results were significant 9 years after entry. ^139^

The Swedish Two-County trial, beginning in 1977, also included women aged 40 to 49. In this trial, approximately 20,000 women were randomized to 1 view mammography only every 24 months and 15,000 were randomized to usual care. After 5 to 6 rounds and 13 years of follow-up, the relative risk for breast cancer among screened women was 0.87 (95% CI, 0.54–1.41), with mortality curves diverging at approximately year 7. ^104^

In our meta-analysis, excluding the Edinburgh trial, the summary relative risk was 0.85 (95% CrI, 0.73–0.99) after 14 years of observation, with a number needed to screen of 1,792 (95% CrI, 1,528–21,080) to prevent one death from breast cancer. Some might argue that the Canadian study should be excluded in calculating the number needed to invite to screening, because its subjects were pre-screened volunteers who may have differed from the general population. Excluding the Canadian study, the summary relative risk was 0.80 (95% CrI, 0.67–0.96) and the number needed to invite for screening was 1,385 (95% CrI, 1,318–12,120). Figure 5 shows an increasing screening benefit among this age group with a longer period of observation.

Figure 5. Relative risks by average follow-up years for women ages 40–49

We identified eight meta-analyses of the effectiveness of mammography in women aged 40 to 49 (Table 7). ^15, ^ ^17, ^ ^18, ^ ^20, ^ ^22, ^ ^24, ^ ^30–34, ^ ^54, ^ ^140, ^ ^141^ Our results, which reflect exclusion of one flawed trial, longer follow-up in six of the trials, and recent results for the Swedish trials, were consistent with those of most previous meta-analyses. Two meta-analyses, ^24, ^ ^31^ including one from the Cochrane Collaboration, ^24^ produced results that differed substantially from ours. The Cochrane review reported a summary relative risk of 1.03 (95% CI, 0.77–1.38) but based this on only two trials.

Table 7. Meta-analyses of randomized trials of screening mammography among women aged 40–49

Study (reference), Year | Assessed Quality? | Included Trials | Methods | Years of Follow-up | Relative Risk (95% Confidence Interval) | Number Needed to Screen
Larsson et al (20), 1997; Nystrom et al (17), 1993 | No | 5 Swedish trials | Weighted relative risks | 12.8 | 0.77 (0.59–1.01)
Nystrom (30), 2002 | No. | 4 Swedish Trials | Weighted relative risk | 14.7 | Evaluation Method: 0.80 (0.63–1.01); Follow-up method: 0.91 (0.76–1.09)
Cox (31), 1997 | No | All 8 trials | Fixed effects | 10 | 0.93 (0.77–1.11)
Elwood (32), 1993
Glasziou and Irwig (15), 1997 | Yes. All studies were “good.” Rated Malmo and CNBSS highest and Two-County trial and Gothenburg lowest | All 8 trials | Variance-weighted | 13.13 | 0.85 (0.71–1.01)
Hendrick et al (22), 1997; Smart et al (18), 1995 | No | All 8 trials* | Fixed effects | 12.7 | 0.82 (0.71–0.95) | 1,540
Kerlikowske (33,141), 1995,1997 | No | All 8 trials | Fixed effects | Approximately 12 | .84 (0.71–0.99) | 2,500
Berry (34), 1998 | No | All 8 trials | Random effects† | 12 –15 | .82 (0.49–1.17)
Olsen and Gotzsche (24), 2001 | Yes. Excluded 6 trials rated “flawed” or “poor” | Canadian, Malmo | Fixed Effects | 13 | 1.03 (0.77–1.38)
Current study, 2002 | Yes. Rated Edinburgh “poor” and others fair or better | 7 trials, excluding Edinburgh | Random effects | Approximately 14 | 0.85 (0.73–0.99) | 1,792

* Included an additional 17 000 subjects from the Malmo II trial.

† Hierarchical Bayes model; estimates are for the “next trial” analysis.

Note: For multiple publications, data from the most recent update are recorded in the table.

CNBSS indicates Canadian National Breast Screening Study; NR, not reported.

### Analyses of the Timing of Mammography

To explain why it has taken longer for a benefit to be shown with screening women younger than age 50, several possibilities have been proposed. One possibility is that women in the screened group continued to obtain mammograms after the end of the active study period, while those in the control group were less likely to undergo mammography in their fifties and sixties. While there are no data to exclude this possibility, it is worth noting that, in all of the Swedish studies, mammography was offered to the control groups 5 to 14 years after randomization and from 13% to 25% of the women in the control group already had a mammogram when first invited (Table 1).

Another possibility is that women entering a trial in their late forties might have undergone several screens in their early fifties during the active study period. Since the mid-1990s, several analyses have investigated this issue. These analyses report deaths from breast cancer among women randomized before age 50 who were also diagnosed before age 50, so that screening could only have occurred before age 50.

### HIP

The HIP trial included women who were aged 40 to 64. ^113^ Among women who were aged 40 to 49 and who were diagnosed before age 50, there were 18 deaths out of 13,740 women in the intervention group and 28 deaths out of 13,740 women in the control group. There were 13 deaths in the intervention group and 23 deaths in the control group among women who were enrolled before age 50 but diagnosed after age 50. Based on these data, the HIP investigators attributed much of the benefit of screening women aged 40 to 49 to screening women who had diagnostic mammograms after they had moved into their fifties, although their data clearly suggest benefit among the 40- to 44-year-old cohort at diagnosis as well. ^113, ^ ^139^

### UK Trial

In the non-randomized controlled United Kingdom trial, mortality rates were decreased among women aged 40 to 49 (RR, 0.70; 95% CI, 0.57–0.86) and tests for heterogeneity by age were non-significant. Among women aged 45 to 49 at entry, the relative risk for breast cancer death was 0.65 (95% CI, 0.50–0.86). This benefit began after approximately 3 to 4 years, indicating that it was not from screening the 45- to 49-year-old cohort in their fifties. ^44^

### Swedish Trials

In 1997, an overview of the Swedish studies ^20^ analyzed results for two subgroups of women: those who were randomized when they were aged 40 to 44, and those who were randomized when they were aged 45 to 49. In the 40- to 44-year-old group, 94% (195/208) of included breast cancer cases in the invited group, and 89% in the control group, were diagnosed before age 50. When measured at age 50 to 54, the incidence of breast cancer death was already lower in the intervention group, and the relative risk reduction was 0.51. At the end of the follow-up period (up to age 60 to 64), the relative risk reduction was 0.74. Because the relative risk was lower at age 50 to 54 than it was at the end of the follow-up period, the data also suggest that most of the benefit was attributable to screening that occurred before age 50. The results do not exclude the possibility that the benefit in screening women aged 40 to 44 came from screening them when they were aged 45 to 49. In the subgroup that was aged 45 to 49 at the time of randomization, two-thirds of cancers in the screening group were detected after age 50. Therefore, screening before age 50 could have accounted for no more than one-third of the total benefit.

In interpreting all these analyses, the limitations of this type of analysis should be noted. First, there are potential biases with either a short- or long-term follow-up period to ascertain breast cancer deaths. If the follow-up period is long, the results could be due to screening that occurred after the end of the study period. In addition, benefit, if it exists, may be diluted by screening occurring in the controls. On the other hand, if the follow-up period is short enough to exclude such an effect, the number of eligible breast cancer deaths may be very small. As shown in Figure 6, before approximately 8 years of follow-up, death rates from breast cancer among controls aged 40 to 49 are very low. With low numbers of deaths, the power to detect a benefit is low, and the effect of methodologic flaws on the results may be large. This is a major problem in all of the trials evaluating screening among women younger than 50, where none were designed with sufficient power to evaluate this study group.

Figure 6. Control group death rate from breast cancer by age and length of followup

Second, analyzing mortality data by age at diagnosis will bias findings against a benefit from screening. In the intervention group, screening will result in diagnosis of some breast cancers that would not be diagnosed before age 50 in the control group. Therefore, even if screening has no (true) effect on mortality, the apparent death rate for cancers diagnosed before age 50 would be higher in the screened group than in the control group (since deaths among those diagnosed with breast cancer comprise the numerator). Thus, even if screening women in their forties reduced the relative risk for breast cancer death, the effect might be obscured because of lead-time bias. ^48^

In summary, the only randomized trial designed to test whether mammography and CBE were beneficial in women aged 40 to 49 had negative results. However, it differed from all of the other studies by enrolling volunteers and by prescreening. Thus, there was no unscreened group. Subgroup analyses in four of six fair-quality trials now have relative risk reductions of 0.87 or less, one (Gothenburg) ^102, ^ ^111^ statistically significant after 13 years of follow-up. Among the studies showing or suggesting benefit from screening, benefit among this age group appears to begin approximately 2 to 8 years after the trials began.

### Marginal Mortality Reduction of Screening at Age 40 versus 50

While the evidence about timing is mixed, it does suggest that most or all of the benefit in women aged 40 to 44 at entry, and an indeterminate proportion of the benefit in women aged 45 to 49, accrues from screening before age 50. Because it is difficult to determine how much mortality reduction can be attributed to screening before age 50, it is also difficult to estimate the additional mortality reduction from starting screening at age 40 instead of age 50. However, it is possible to place some bounds on this value. If all the benefit is due to screening before age 50, beginning at age 40 instead of 50 would prevent one breast cancer death for every 1,792 women invited for screening (or, if the Canadian study is excluded, 1,385 [95% CI, 659–6,060]) after 14 years of observation. If half of the cancers would have been diagnosed by screening after age 50, beginning at age 40 instead of 50 would prevent 1 additional death from breast cancer over 14 years for every 2,160 to 2,996 invited to screen. If the Canadian trial is excluded in calculating the risk reduction, screening 1,402 to 1,945 women beginning at age 40 instead of 50 would prevent one additional death.

## F. How Effective is Screening in Women Who are Older than Age 70?

The incidence of breast cancer increases dramatically from age 30 until at least age 84, and half of breast cancers occur in women older than age 65. Breast cancer mortality rates also increase with age; it is the leading cause of cancer mortality among older women. ^142^ However, older women significantly underestimate their risk for breast cancer and some studies suggest breast cancer tends to be diagnosed at a more advanced stage in the elderly. ^142, ^ ^143^ Among elderly women (as well as younger women), those who are socioeconomically disadvantaged and/or who are minorities are most likely to develop or die of breast cancer.

Direct evidence of effectiveness among older women is limited to two trials that included women older than age 65, both of which reported relative risk reductions among women aged 65 to 74. The relative risk was 0.68 (95% CI, 0.51–0.89) in Malmo ^111^ and 0.79 (NS) among women aged 70 to 74 in Two-County. ^104^ Recent data from the Swedish overview ^30^ identified a relative risk associated with screening of 0.78 (95% CI, 0.62–0.99) among women aged 65 to 74 using the follow-up method of analysis.

Results from observational studies are mixed. One case-control study found a reduced risk for breast cancer death among women older than age 60 who had been screened within 1 year (Odds ratio [OR], 0.73; 95% CI, 0.19–2.64) and 0.84 (95% CI, 0.44–1.63) for those screened at an interval of greater than 1 year. ^144^ The study lacked power because screening rates were only 6% among the controls. Another case control study that evaluated breast cancer mortality among women aged 65 and older found a relative risk of 0.45 (95% CI, 0.20–1.02) among women aged 65 to 74 and 1.05 for women older than age 75. ^61, ^ ^145^ However, this study had no adjustment for important breast cancer risk factors, particularly socioeconomic status. Recently, a cohort study of 690,993 California Medicare beneficiaries found that older women who had mammograms were significantly less likely to be diagnosed with metastatic breast cancer (RR, 0.57, 95% CI, 0.45–0.72). ^146^

There are no data from RCTs to determine whether mortality among women older than age 74 is reduced. As for women younger than 50, several issues should be considered in deciding whether to extrapolate results from randomized trials to older patients. Unlike women younger than age 50, in women older than age 70, the incidence of breast cancer is higher, and test performance appears to be as good, than in women aged 50 to 70 (Tables 2 and 3). However, two other factors—screening history and competing mortality—are relevant.

### Screening History

While rates of mammography are lower in the elderly, many women who are age 70 or older have had many rounds of mammography when they were in their fifties and sixties. Randomized trials assessed the benefits of one to six rounds of mammography over 2 to 10 years, mostly in women who had never undergone mammography before. These trials did not assess the marginal benefit of mammography in women who have had mammograms for many years and have not been found to have cancer. The value of varying the screening interval based on previous mammographic history has not been assessed.

### Competing Mortality

At ages 65, 75, and 85, a woman's average life expectancy is 19, 12 and 7 years, respectively, though the range varies significantly. For example, although the median life expectancy for a 75-year-old woman is 12 years, the top 25^th^ percentile life expectancy is 17 years and the lowest 25^th^ percentile is 6.8. ^147^ Even at age 85, the top 25^th^ percentile life expectancy is 9.6 years. Thus, healthy women could have a significant mortality benefit from mammography at these ages. However, comorbidities are common in the elderly and may drastically alter life expectancy. One study of elderly women found that those with three or more comorbid conditions, such as hypertension, diabetes, arthritis, stroke, respiratory disease, history of myocardial infarction, or other cancer, were 20-fold more likely to die of causes other than breast cancer, regardless of the stage of breast cancer at diagnosis. ^148^ However, since mortality benefits in older women accrue relatively quickly (3–4 years), older women might be able to benefit from screening, given average life expectancy. Finally, since there are no data from trials among women age 74 and older, no information is available on the adverse consequences of screening in this age group, particularly complications associated with evaluation and treatment of positive (and false positive) results.

Decision analysis and cost-effectiveness analysis can be useful in assessing the benefits of screening in the face of competing risks. A decision analysis published in 1992 suggested that screening saved lives at all ages. ^149^ Assuming a sensitivity of 75% and a specificity of 90%, both potentially less than achievable in many programs, and a perioperative mortality rate of 2%, the authors evaluated outcomes in several different types of populations. For individual women aged 65 to 69 or age 85 or older diagnosed to have breast cancer, screening increased life expectancy by 311 and 126 days, respectively. This analysis considered some comorbidities (for example, congestive heart failure), but additional analysis is needed to assess the marginal benefit in relation to decreased life expectancy associated with specific conditions. An interesting analysis utilizing measurement of bone mineral density to predict higher breast cancer risk, found that continuing biennial mammography from ages 65 to 79 among women in the top 3 quartiles of bone density would avert 9.4 deaths per 10,000 women screened. ^150^ In addition, as treatment for chronic diseases improves, screening for breast cancer among older women may yield greater benefit.

## G. What is the Effectiveness of Clinical Breast Examination in Reducing Mortality Among Women Aged 40 and Older?

No trial has compared CBE alone with no screening. However, the HIP trial, which used mammography and CBE showed a mortality reduction of 21%. ^113,^ ^120^ The Canadian NBSS-1 study, however, showed no benefit of mammography and CBE among women aged 40 to 49 compared to women receiving one CBE. ^59^ The controlled nonrandomized UK trial of CBE and mammography, showed a nonsignificant mortality reduction of 14% (RR, 0.86; 95% CI, 0.73–1.01). ^44^

What is the contribution of CBE to these reductions in mortality? Among studies showing a benefit of screening, mortality reductions in trials of CBE with mammography are similar to those in trials including mammography only. ^17, ^ ^30^ This suggests that CBE adds relatively little to mammography reducing mortality. However, complicating this issue is the Canadian NBSS-2, in which women were randomized to either annual CBE and mammogram, or annual CBE or no benefit from either screening modality. ^95^ In this study, the relative risk for death was 1.02 (95% CI, 0.78–1.33) after 13 years of observation, suggesting little additive benefit for mammography in the setting of a careful, detailed CBE. ^108^ The authors of this study have emphasized that, although mammography and CBE together detect more breast cancer than CBE alone, a well-conducted CBE contributes significantly to breast cancer detection. ^95^ This differs with their findings in the CNBSS-1 which showed no benefit for annual CBE combined with mammography among women aged 40 to 49.

## H. Is Breast Self-Examination Effective in Reducing Breast Cancer Mortality?

The effectiveness of BSE in decreasing breast cancer mortality has been controversial in the past, due to limited evidence from clinical trials and the believed proven benefit of mammography with or without CBE. BSE is easy, quick, inexpensive, and therefore an attractive modality of screening. Further, neither the clinical breast exam nor mammography is 100% sensitive. Therefore, since many women detect breast cancer themselves, for many years BSE has been advised as an important screening modality. Many observational studies evaluating breast self-exam and breast cancer stage at diagnosis or mortality have been conducted; some show benefit and some do not. ^9, ^ ^43^ The interpretation of these studies, however, is limited by concerns about bias as women who conduct BSE are different than those who do not in ways that might substantially alter their risk for higher stage breast cancer or breast cancer death. For these reasons, the first and second USPSTF gave screening with BSE a “C” recommendation. Since the last Task Force review, results have been published from 2 large randomized trials of BSE, as well as the nonrandomized controlled UK trial.

The WHO trial of BSE in St. Petersburg (formerly Leningrad) involved 120,310 women aged 40 to 64 at entry who were randomized into a BSE training group (60,221) and a control group (60,098) with no concurrent screening. ^151^ In 1985, when this study began, neither BSE nor mammography was being used routinely as a screening modality in this region. The intervention group was given personal BSE training in small groups of 5 to 20 women by nurses and physicians. Reinforcement was given through posters, broadcasts, and calendars, and at the annual exam, BSE technique was evaluated.

After 5 years, there were no significant differences in the number of breast cancers, their size, or involvement of regional lymph nodes between the breast self-exam group and the control group. Further, there were higher rates of physician visits, referrals, and benign breast biopsies in the BSE group (RR, 1.5). In addition, women in the BSE group had more physician visits (4,340 vs 2,438; P<0.05) and had more breast biopsies performed (1,138 vs 797; P<0.05) than the control group. Four hundred and ninety-three breast cancers were diagnosed in the BSE group and 446 in the control group, with 157 deaths in the BSE group and 164 in the control group. After 9 years of follow-up, a 10% non-significant survival benefit was found in the BSE group. ^41^ This study is ongoing.

The Shanghai Study is a randomized controlled trial assessing the efficacy of BSE in detecting breast cancer and reducing breast cancer mortality. ^42^ Between October 1989 and October 1991, 267,040 current and retired female textile workers in the Shanghai Textile Industry Bureau were entered into the study. The women were randomly assigned to either the BSE instruction group (133,375) or the control group (133,665), which received education on preventing lower back injury and pain. Mammography was not available for routine screening. Most of the women received medical care at their respective factory's clinic. If further care was needed, they were usually referred to 1 of 3 hospitals. All women answered a baseline questionnaire assessing risk factors for breast cancer. The BSE instruction group received training in the initial BSE class, which included proper technique, 2 reinforcement sessions, regular observed BSE by medical personnel, handouts, and posters. At 1 year, all women in the BSE group saw a reinforcement video. A second video was shown between 1993 and 1995. At the end of year 1, the control group received 1 reinforcement video session on lower back pain. An active surveillance program to detect cancer included evaluation of all asymptomatic lumps by a medical worker who could then refer the patient to a surgeon, usually at 1 of the 3 referral hospitals. The medical workers recorded all breast lumps, how they were found, and the interval between last exam and lump detection and diagnosis. There also was a hospital tumor and death registry and a Shanghai cancer registry to help detect any breast cancer that might be missed with the study's follow-up procedures.

The primary end point was breast cancer death. The control and intervention groups were quite similar with regard to breast cancer risk factors. The BSE group had an 83.6% compliance for all 3 sessions (baseline and 2 reinforcement classes) and 96.1% for 2 sessions. The control group had a compliance rate of 94.1% after 2 sessions. Expected breast cancer cases totaled 605, and 653 were detected, suggesting few cases were missed. Pathologists in China and Seattle confirmed all cases. The BSE group had 331 cases of breast cancer and 1,457 false positive tests. The control group has 322 cases and 623 false positive tests. Twenty-five breast cancer deaths occurred in each of the 2 groups. After 5 years of follow-up, the overall breast cancer mortality was similar in both groups, and there was no difference in the cumulative death rate due to breast cancer.

The UK Trial of Early Detection of Breast Cancer is a non-randomized, controlled trial, which began in 1979 to assess the impact of screening and education on breast cancer mortality. ^44^ Women were recruited between the ages of 45 and 64, and 8 centers were involved: 2 breast self-exam, 2 screening (mammography and CBE), and 4 comparison centers. Huddersfield (n=8,606) and Nottingham (n=26,055) were the 2 breast self-exam centers. All women in the desired age range in these 2 centers were sent an invitation inviting them to an education session on breast self-exam; 31% attended in Huddersfield and 53% attended in Nottingham. At entry, the education session on BSE included a short film and presentation and no individual instruction was given or physical exam performed. The Huddersfield cohort was sent yearly calendars to report monthly BSE. In both centers, women were offered access to the clinics for evaluation of abnormalities. The primary end point was breast cancer death. After mean follow-up of 14.4 years, there was no reduction in mortality in the 2 BSE centers combined when compared to the control centers (n=165,558). However, there were differences between the two BSE centers in breast cancer deaths when each community was evaluated individually and compared to the control communities; Huddersfield had a relative risk of 0.80 (95% CI, 0.69–0.94) and Nottingham had a relative risk of 1.19 (95%, CI 1.07–1.30). The reason for the differences between the 2 communities is unclear.

A cohort study ^152^ sponsored by the American Cancer Society evaluated the relationship of breast self-examination to breast cancer mortality using data between 1959 and 1972 among 594,551 women. At entry, all subjects were at least 30 years or older and completed a four-page questionnaire that assessed past medical history, present health, demographic information, personal habits, reproductive history, and family history. However, only 1 question pertained to the BSE. “Many doctors recommend that women examine their breasts monthly. Do you do so? Yes/No.” Participant status was assessed as dead, alive, or lost to follow-up in 1962, 1963, 1964, 1965, 1971, and 1972. For all deaths, a copy of the death certificate was obtained from the State Health Department. By the end of 1973, vital status had been recorded for 92.8% of the subjects. Exclusion criteria included: the questionnaire was filled out by a proxy, prevalent breast cancer, symptoms of breast lump or discharge, missing demographic information, and missing information on BSE. After exclusion criteria were assessed, 450,156 women were included in this study. BSE was performed by 176,667 (39%) women, and 2,300 (0.5%) died from breast cancer over the 13 years. No differences in breast cancer mortality were shown between the BSE group and the no BSE group after controlling for the number of pregnancies, family history of breast cancer, age of menarche, and body mass index, each of which was associated with increased risk for breast cancer in this cohort.

Finally, a nested case-control study was designed within the Canadian NBSS, an RCT of mammography and CBE involving 89,835 women aged 40 to 59. ^153^ The objective was to measure BSE technique and frequency and to evaluate its impact on breast cancer death. During the trial, BSE was taught and evaluated at every visit, and patients answered questionnaires regarding BSE frequency over the past year. The BSE instruction included 8 components. The cases consisted of 163 women dying of breast cancer and 57 women with metastatic disease. Ten controls were randomly selected (n=2,200) for each case and were matched for 5-year age group, screening center, and year of enrollment. Demographic characteristics were compared, and cases were more likely to have professional jobs, currently smoke, have later age of menopause, and a positive family history of breast cancer; these were adjusted for statistically. The frequency and proficiency of BSE was compared between the cases and controls at 1, 2,and 3 years prior to case diagnosis. No difference in BSE frequency was shown between cases and controls. However, 3 components of the BSE—visual inspection, using fingertip pads, and using the middle 3 fingers—were found to have a significant association with breast cancer diagnosis when performed 2 years prior to the diagnosis, with an odds ratio for death or distant metastases from breast cancer of 2.2 among women who omitted 1, 2,or 3 of these BSE components. These results remained significant after adjustment for known confounders.

In summary, the findings from 2 RCTs do not show a reduction in breast cancer mortality when comparing BSE instructed groups and control groups. Both studies involved a large number of participants where women were meticulously trained with proper technique and had numerous reinforcement sessions and mammography was not part of routine screening in the countries involved. It is possible that with longer follow-up benefit may be shown. Whether the findings are generalizable to the United States, where CBE and mammography are routinely used in breast cancer screening and breast cancer rates are higher, is uncertain. What is also uncertain is whether breast self-exam might be beneficial to women who are not in the ages where mammography is recommended or to those who do not avail themselves of mammography. Although there were differences between the 2 BSE cohorts in the UK Trial of Early Detection of Breast Cancer, the combined results did not show a benefit of BSE in reducing breast cancer deaths when compared to the control groups after a mean follow-up of 14.4 years. The Canadian NBSS nested case-control study suggests that more rigorous BSE might be beneficial; however, systematic differences between more compliant and less compliant subjects may bias these results toward benefit. In both trials of BSE, there were increases in physician visits and biopsy for benign breast lesions among those educated in BSE. To date, no studies have evaluated other potential adverse outcomes of breast self exam, such as anxiety and subsequent screening behavior. Finally, randomized controlled trials evaluating BSE in the setting of CBE and mammography have not been conducted, but the probability of finding a significant decrease in mortality, when it was not found in settings without CBE and mammography, is likely to be small.

## I. What are the Adverse Effects of Screening for Breast Cancer?

In weighing evidence for and against screening, known and potential harms must be considered. The most frequently discussed adverse effects of mammography are the anxiety, discomfort, increased utilization, and diagnostic procedures associated with positive test results, many of which are false positive tests. One of the known harms of screening is anxiety, both about the test and about potential results. ^154^ There is significant anxiety among women who have abnormal screening results, whether they are true or false positive results. In usual practice, all women with positive results undergo further evaluation, such as CBE, extra mammography views, ultrasound, repeat mammography, or biopsy, and waiting for further evaluation, as well as results, is associated with anxiety. Most often, further evaluation involves only extra mammographic views, ultrasound, CBE or earlier follow-up. Women with true positive results are presumed to be those who most benefit from mammography. However, this benefit only occurs among the women with the type of breast cancer that benefits from early treatment. Since 50% of women with symptom-detected breast cancer will not die of it, and the natural history of aggressive breast cancer is rarely altered by early detection, it could be argued that many women with screen-detected breast cancer do not benefit from screen detection, but live longer knowing they have breast cancer, a potential harm. ^155^

Some view overdiagnosis and treatment of ductal carcinoma in situ (DCIS) as a potential adverse consequence of mammography, although this is controversial. DCIS occurs when malignant breast epithelial cells arise and proliferate in breast ducts but do not invade the stroma. ^156^ Rates of DCIS have increased dramatically in recent years. In 1974, rates of detected DCIS among women aged 50 and older were 8 per 100,000. In 1994, rates were 60 per 100,000, an increase of nearly 750%. ^123^ A substantial proportion of this increase is believed due to screening with mammography and early detection. However, data from SEER have suggested that screening mammography alone has detected only 25% to 40% of these tumors, suggesting other factors have contributed to increasing incidence. ^156^

The natural history of DCIS is variable. In some case series, 30% to 66% of women develop ipsilateral breast cancer, of which 50% is invasive, following excision of the DCIS lesion. ^156^ However, although findings vary, a recent review of autopsy series suggests that there is a significant pool of DCIS among women without known breast cancer who die of other causes (range, 10% to 39%). ^1^ ^57^ Little is known of the natural history of mammographically-detected DCIS, which may represent a different spectrum from autopsy-detected DCIS. In addition, some pathologists who are experts in DCIS have suggested that some cases diagnosed as DCIS in autopsy series would be reclassified as atypical ductal hyperplasia using current criteria, suggesting lower autopsy rates of DCIS than described above. ^158^

Long term survival rates are high for treated DCIS, ranging from 95% to 98% 20-year survival. ^159, ^ ^160^ There are no data indicating that early treatment of DCIS (as opposed to treating later if it progresses to invasive breast cancer) reduces breast cancer morbidity and mortality. The fact that not all DCIS will progress to invasive disease has led to concerns about treatment regimens, and given the heterogeneity of DCIS lesions, concerns about overtreatment as well as undertreatment. Concern about potential over-treatment comes from 1992 data showing that 44% of women with DCIS were treated with mastectomy, 23% with lumpectomy and radiation, and 30% with lumpectomy alone. ^161, ^ ^162^ Women may not be aware of this risk, however. In one survey, only 6% of women were aware that mammography might detect non-progressive breast cancer. ^163^

A major concern with breast cancer screening is false positive results. Even in the best breast cancer screening programs, the vast majority of abnormal screening CBEs or mammograms (80%-90%), are found to be false positives which require further evaluation. There are several possible consequences of a false positive exam but most often, further evaluation involves a CBE, extra mammography views, or ultrasound. One study evaluated diagnostic testing following screening mammography in Medicare beneficiaries. ^164^ The investigators identified a cohort of 23,172 women aged 65 or older who were screened from January through April 1995 and followed for 8 months to evaluate the performance of additional procedures. Among women aged 65 to 69 and those older than age 70, subsequent diagnostic mammography was performed among 64 per 1,000 and 58 per 1,000 women screened, respectively. Follow-up ultrasound was done in 25 per 1,000 women aged 65 and older. Finally, biopsies were performed in 23 and 26 per 1,000 women undergoing screening mammography aged 65 to 69 and age 70 or older, respectively. Overall, 81 per 1,000 screened women aged 70 or older and 85 per 1,000 women aged 65 to 69, underwent further diagnostic testing. The number of cases of breast cancer among women aged 65 to 69 was 7 per 1,000 and among women 70 or older was 10 per 1,000. Therefore, the positive predictive value of an abnormal mammogram was 8% (95% CI, 6%-10%) among women 65 to 69 and 14% (95% CI, 12%-16%) for women 70 and older. Other data based on rates from a population-based mobile mammography screening program show that among women aged 40 to 49, 1,280 tests (150 biopsies) were conducted on 640 women to diagnose 30 breast cancers. Among 680 women aged 50 to 59, 1,360 tests and 188 biopsies were conducted to diagnose 60 cases of breast cancer. Finally, to diagnose breast cancer among 120 women aged 60 to 69, 800 abnormal tests were obtained, and 1,600 extra tests and 286 biopsies performed. Thus, the issue of evaluating false positive mammograms is a major one since at every age the risk for a false positive exam is significantly higher than the risk for breast cancer. ^33^ Information on false positive rates and predictive value for mammography and clinical breast exam is shown in Table 3.

Another potential concern with false positive exams is that women may have prolonged anxiety following an abnormal mammogram result. Some studies have shown that women who undergo breast biopsies may also have especially high anxiety in the months following the procedure ^165^ ^-168^; other studies have not shown this. ^154, ^ ^169^ However, some studies have shown that anxiety following evaluation of false positive results increases participation in screening. ^93, ^ ^165, ^ ^166, ^ ^170, ^ ^171^ Recent data collected among 767 women show that 99% of women understand that false positive exams may occur with screening, although they underestimate the risk. Importantly, however, 63% stated that they would accept 500 false positive exams to save 1 life. ^163^

Finally, there are significant costs associated with false positive breast cancer screening tests. A cohort study of 2,400 women who underwent 9,762 screening mammograms found that for every $100 spent on screening, $33 are spent on the evaluation of false positive exams. ^75^ In that study, the false positive rate was 5.3% among 60 to 69 year old women and 4.4% among 70 to 79 year old women. ^75^ Data such as those described above also support the significant costs of evaluating false positive exams.

One risk for screening with mammography or clinical breast exam is the risk of false reassurance associated with false negative exams. As discussed above, the sensitivity of mammography ranges between 74% and 93%, depending on the woman's age, breast density, and the quality of the mammography and its interpretation. The sensitivity of clinical breast exam is even lower. Thus, many women who receive either of these exams will have false negative exams. The potential consequence of false reassurance is that a woman may delay seeking evaluation if she develops breast symptoms or may delay rescreening. There is some evidence against this concern with data from the Swedish Two-County Study showing equivalent survival among intervention women diagnosed with interval breast cancer and control women with breast cancer, suggesting (though not proving) that false reassurance from negative mammograms did not result in important diagnostic delays. ^172^ Furthermore, the risk of false reassurance and potential delay in diagnosis is accounted for in the mortality estimates from trials. ^34^ Health care providers may also overestimate the sensitivity of mammography and over-rely on it in the setting of an abnormal breast exam or breast symptoms. For these reasons, educating the public, as well as providers, about the operating characteristics of both clinical breast exam and mammography is important if they are to be performed. In addition, a potential concern or risk is that women with true negative exams may delay rescreening after being reassured with a negative screen, though this has not been demonstrated.

Another potential risk associated with breast cancer screening with mammography is that of radiation exposure and radiation-induced breast cancer. ^173^ Although there is no direct evidence evaluating the risk for breast cancer associated with mammography, data from Japan among atomic bomb survivors, as well as studies among women who have undergone multiple chest fluoroscopies or who have been treated for benign breast conditions with radiation, have shown increased rates of breast cancer. ^174^ Thus, the concern about radiation-induced breast cancer among women undergoing mammography has been raised. This issue was reviewed in 1997 by Feig and Hendrick using risk estimates provided by the Biological Effects of Ionizing Radiation report of the National Academy of Sciences. Assuming a mean breast glandular dose of 4mgy from a 2 view per breast bilateral mammogram, these authors estimated that annual mammography of 100,000 women for 10 consecutive years beginning at age 40 would result in, at most, 8 breast cancer deaths occurring during their lifetime. They also concluded that the risk for radiation induced breast cancer was negligible compared to the benefit of screening. There is also concern that certain subpopulations of women with an inherited susceptibility to ionizing radiation damage may have higher risk for radiation-induced breast cancer from mammography, ^175, ^ ^176^ though this has not been shown in any study.