# Introduction and Background

Breast cancer is the leading cause of non-skin cancer among women and the second leading cause of cancer death among North American women. In 2002, there will be an estimated 203,500 new cases of breast cancer and approximately 39,600 U.S. women will die from the disease. ^1^ Currently it is estimated that 1 in 8.2 North American women will develop breast cancer during her lifetime and 1 in 30 will die from it. ^1^ The incidence of breast cancer increases with age. The probability of developing breast cancer over a decade is 1 in 72 for women in their forties, 1 in 36 for women in their fifties, and 1 in 29 for women in their seventies. ^1^ Although significant progress has been made in identifying epidemiologic risk factors other than age and genetic markers for breast cancer, the majority of cases occur in women without known major predictors. ^2, ^ ^3^ ^4, ^ ^5^

Between 1973 and 1994, the incidence of breast cancer increased by approximately 25% ^6^ ; in 1997, the incidence of breast cancer was 115.4 cases per 100,000 women. Since 1980, the incidence of Stage I cancer has increased about 60% in women younger than age 50 and 119% in women aged 50 and older, likely due to increased rates of screening. Rates of in situ cancer have increased by 160% in women younger than age 50 and by 315% in women aged 50 and older. Over this same time period, the incidence of Stage II-IV cancer has decreased by 10% to 15%.

For many years, in the face of increasing incidence, mortality from breast cancer remained stable. In recent years, breast cancer mortality has decreased, especially in younger women. Over the 10-year period from 1987 to 1997, in the setting of increased incidence, the annual breast cancer death rate per 100,000 women at ages 20 to 49, 50 to 69, and 70 to 79 decreased by 19% (13.3 to 10.8), 18% (79.1 to 65.0), and 9% (123.5 to 112.5), respectively, in the U.S. Some believe this decrease is due to earlier detection of breast cancer, ^7^ while others attribute it primarily to improved treatment for breast cancer. ^8^

## Prior Recommendations

Beginning in the 1960s, several randomized trials evaluating the effectiveness of screening in reducing mortality from breast cancer were conducted. In 1996, the U.S. Preventive Services Task Force (USPSTF) recommended mammography screening every 1 to 2 years for women aged 50 to 69 and gave this an “A” recommendation. ^9^ For women aged 70 or older, the USPSTF gave screening a “C” recommendation based on limited evidence for this age group (and no evidence above age 74). The USPSTF gave screening in women aged 40 to 49 a “C” recommendation, citing inadequate data to recommend for or against screening in this age group. ^9^ They noted that the sensitivity of mammography was lower in this group and that the results of randomized trials were conflicting. In addition, they noted that it was possible that the apparent benefit observed in some trials was due to screening women who had entered the trials in their forties after they reached age 50. ^9^

The USPSTF found that there was insufficient evidence to recommend clinical breast exam (CBE) alone in any age group, and gave it a “C” recommendation. ^9^ It did not recommend for or against teaching breast self-examination (BSE) in any age group and also gave this a “C” recommendation. ^9^ This recommendation was based largely on conflicting results from observational studies and preliminary results from one randomized trial.

The purpose of this systematic evidence review is to assist the current USPSTF in updating the 1996 recommendations. We focus on recent information that was not available to the previous Task Force to answer the following questions, particularly for women younger than age 50 and older than age 70:

1. What are the test characteristics of breast self-examination, clinical breast examination, and mammography?
2. Are mammography, clinical breast examination, or breast self-examination effective in reducing mortality and morbidity from breast cancer? Is screening women aged 40 to 49 effective? How effective is screening in women who are older than age 70?
3. What are the adverse effects of screening for breast cancer?

This review does not address genetic screening, surveillance of women with prior breast cancer, or formal evaluation of new screening modalities that have not been studied in the general population.

## Analytic Framework and Key Questions

In the analytic framework (Figure 1), evidence for the effectiveness of breast cancer screening is shown by the overarching arc connecting screening with the outcomes and reduced morbidity and/or mortality. Arrows 1 (screening) and 2 (early treatment) represent the intermediate steps in the causal chain linking screening with improved mortality and/or morbidity.

Figure 1. Screening for Breast Cancer Analytic Framework

Mammography is aimed at early detection of invasive cancer (Arrow 1), which is treated by major surgery (mastectomy or tumorectomy). This differs from screening for colorectal cancer and cervical cancer, for example, which is aimed at detecting and removing precancerous lesions to prevent invasive cancer and to preserve the involved organ (colon or uterine cervix). This is one reason why, although it may be reasonable to endorse one cancer screening test (eg, Papanicolaou's test) based on observational, indirect evidence, it may also be reasonable to require experimental evidence before endorsing another (eg, mammography or prostate cancer screening).

It is important to note that the mammography trials do not necessarily provide the highest level of evidence about the efficacy of early treatment. While there is no doubt that screening results in earlier diagnosis of invasive breast cancer (Arrow 1), the efficacy of earlier treatment of invasive cancer has not been established independently of the trials. ^10^ That is, there is no direct evidence from trials of surgical therapy (versus watchful waiting) that earlier treatment of either invasive or in situ cancer reduces mortality. The mammography trials do not attempt to link specific treatments, such as radical mastectomy or adjuvant radiation, to improved outcomes.

The reliance on a theory of treatment rather than on evidence about the efficacy of treatment increases the burden of proof placed on the trials of mammography. It also distinguishes breast cancer screening from other screening services considered by the USPSTF, such as chlamydia, depression, or osteoporosis screening, for which placebo-controlled randomized trials of treatment have been conducted. The threshold for sufficient evidence about efficacy also depends on the balance of benefits and harms (Arrow 3). Because mammography technology, the timing and type of information provided to patients, and treatment approaches have changed over time, the adverse consequences of screening in current practice might be very different from those in the trials, most conducted over 20 years ago. Other sources of data must be used to estimate these consequences.