# Appendix 3. Data used in meta-analysis

| | | | Intervention Group | | | | Control Group | | | | | 95% CI
Study | Ref (from main text unless otherwise noted) | Age | Mean FU | Deaths | Subjects | Life-years | Rate/10,000 | Deaths | Subjects | Life-years | Rate/10,000 | RR | Lower | Upper
CNBSS | Miller, unpublished manuscript | 40–49 | 13.0 | 105 | 25,214 | 282,606 | 3.7 | 108 | 25,216 | 282,575 | 3.8 | 0.97 | 0.74 | 1.27
| Miller et al, 1997 (109)† | 40–49 | 10.5 | 82 | 25,214 | 264,747 | 3.1 | 72 | 25,216 | 264,768 | 2.7 | 1.14 | 0.83 | 1.56
| Miller et al, 1992 (59) | 40–49 | 8.5 | 38 | 25,214 | 214,319 | 1.8 | 28 | 25,216 | 214,336 | 1.3 | 1.36 | 0.84 | 2.21
| | 40–59 | 13.0 | 212 | 44,925 | 584,025 | 3.6 | 213 | 44,910 | 583,830 | 3.6 | 1.00 | 0.82 | 1.20
| | 40–59 | 8.5 | 76 | 44,925 | 381,863 | 2.0 | 67 | 44,910 | 381,735 | 1.8 | 1.13 | 0.82 | 1.57
| Miller et al, 2000 (108) | 50–59 | 13.0 | 107 | 19,711 | 216,133 | 5.0 | 105 | 19,694 | 216,042 | 4.9 | 1.02 | 0.78 | 1.33
| Miller et al, 1992 (58) | 50–59 | 8.3 | 38 | 19,711 | 163,601 | 2.3 | 39 | 19,694 | 163,460 | 2.4 | 0.97 | 0.62 | 1.52
HIP | Shapiro, 1997 (113)† | 40–49 | 18.0 | 49 | 13,740 | 247,320 | 2.0 | 65 | 13,740 | 247,320 | 2.6 | 0.75 | 0.52 | 1.09
| Habbema et al, 1986 (Appendix 2, pg 2, ref 12) | 40–49 | 14.0 | 64 | 13,740 | 192,360 | 3.3 | 82 | 13,740 | 192,360 | 4.3 | 0.78 | 0.56 | 1.08
| Shapiro et al, 1988 (107) | 40–49 | 10.0 | 39 | 13,740 | 137,400 | 2.8 | 51 | 13,740 | 137,400 | 3.7 | 0.76 | 0.50 | 1.16
| Shapiro et al, 1988 (107) | 40–49 | 5.0 | 19 | 13,740 | 68,700 | 2.8 | 20 | 13,740 | 68,700 | 2.9 | 0.95 | 0.51 | 1.78
| Shapiro et al, 1988 (107) | 40–64 | 18.0 | 126 | 30,245 | 544,410 | 2.3 | 163 | 30,245 | 544,410 | 3.0 | 0.77 | 0.61 | 0.98
| Shapiro et al, 1985 (Appendix 2, pg 3, ref 20) | 40–64 | 16.0 | 236 | 30,239 | 483,824 | 4.9 | 281 | 30,756 | 492,096 | 5.7 | 0.85 | 0.72 | 1.02
| Habbema et al, 1986 (Appendix 2, pg 2, ref 12)) | 40–64 | 14.0 | 165 | 30,245 | 423,430 | 3.9 | 212 | 30,245 | 423,430 | 5.0 | 0.78 | 0.64 | 0.95
| Shapiro et al, 1988 (107) | 40–64 | 10.0 | 95 | 30,245 | 302,450 | 3.1 | 133 | 30,245 | 302,450 | 4.4 | 0.71 | 0.55 | 0.93
| Shapiro et al, 1988 (107) | 40–64 | 5.0 | 39 | 30,245 | 151,225 | 2.6 | 63 | 30,245 | 151,225 | 4.2 | 0.62 | 0.42 | 0.92
| Shapiro et al, 1988 (107) | 50–64 | 18.0 | 77 | 16,505 | 297,090 | 2.6 | 98 | 16,505 | 297,090 | 3.3 | 0.79 | 0.58 | 1.06
| Habbema et al, 1986 (Appendix 2, pg 2, ref 12) | 50–64 | 14.0 | 101 | 16,505 | 231,070 | 4.4 | 130 | 16,505 | 231,070 | 5.6 | 0.78 | 0.60 | 1.01
| Shapiro et al, 1988 (107) | 50–64 | 10.0 | 56 | 16,505 | 165,050 | 3.4 | 82 | 16,505 | 165,050 | 5.0 | 0.68 | 0.49 | 0.96
| Shapiro et al, 1988 (107) | 50–64 | 5.0 | 20 | 16,505 | 82,525 | 2.4 | 43 | 16,505 | 82,525 | 5.2 | 0.47 | 0.27 | 0.79
Gothenburg | Bjurstam et al, 1997 (101)† | 39–49 | 11.8 | 18 | 11,724 | 138,402 | 1.3 | 40 | 14,217 | 168,025 | 2.4 | 0.55 | 0.31 | 0.96
| Nystrom et al, 2002 (30) | 40–49 | 12.7 | 22 | 10,888 | 138,000 | 1.6 | 46 | 13,203 | 167,000 | 2.8 | 0.58 | 0.35 | 0.96
| Larsson et al, 1997 (20) | 40–49 | 9.8 | 16 | 10,821 | 106,000 | 1.5 | 33 | 13,101 | 129,000 | 2.6 | 0.59 | 0.33 | 1.06
| Nystrom et al, 2002 (30) | 40–59 | 12.8 | 62 | 21,000 | 268,000 | 2.3 | 113 | 29,200 | 373,000 | 3.0 | 0.76 | 0.56 | 1.04
| Nystrom et al, 1993 (17) | 40–59 | 6.3 | 27 | 20,724 | 129,000 | 2.1 | 47 | 28,809 | 181,000 | 2.6 | 0.86 | 0.54 | 1.37
| Nystrom et al, 2002 (30) | 50–59 | 12.9 | 40 | 10,112 | 130,000 | 3.1 | 67 | 15,997 | 206,000 | 3.3 | 0.94 | 0.62 | 1.43
Stockholm | Nystrom et al, 2002 (30) | 40–49 | 14.3 | 34 | 14,303 | 203,000 | 1.7 | 13 | 8,021 | 117,000 | 1.1 | 1.52 | 0.80 | 2.88
| Frisell and Lidbrink, 1997 (82)† | 40–49 | 11.9 | 24 | 14,842 | 173,866 | 1.4 | 12 | 7,103 | 87,826 | 1.4 | 1.08 | 0.54 | 2.17
| Larsson et al, 1997 (20) | 40–49 | 11.5 | 23 | 14,185 | 162,000 | 1.4 | 10 | 7,985 | 94,000 | 1.1 | 1.34 | 0.64 | 2.80
| Frisell et al, 1991 (Appendix 2, pg 20, ref 2) | 40–49 | 7.2 | 16 | 14,375 | 99,155 | 1.6 | 8 | 7,103 | 54,446 | 1.5 | 1.09 | 0.40 | 3.00
| Frisell et al, 1997 (105) | 40–64 | 11.8 | 66 | 40,318 | 473,153 | 1.4 | 45 | 19,943 | 239,460 | 1.9 | 0.74 | 0.50 | 1.10
| Frisell et al, 1991 (Appendix 2, pg 20, ref 2) | 40–64 | 7.1 | 39 | 39,164 | 270,247 | 1.4 | 30 | 19,943 | 147,373 | 2.0 | 0.71 | 0.40 | 1.20
| Nystrom et al, 2002 (30) | 40–65 | 13.8 | 82 | 39,139 | 535,000 | 1.5 | 50 | 20,978 | 296,000 | 1.7 | 0.91 | 0.65 | 1.27
| Nystrom et al, 1993 (17) | 40–65 | 7.6 | 53 | 38,525 | 287,000 | 1.8 | 40 | 20,651 | 164,000 | 2.4 | 0.80 | 0.53 | 1.22
| Nystrom et al, 2002 (30) | 50–59 | 13.7 | 25 | 15,946 | 217,000 | 1.2 | 24 | 8,421 | 118,000 | 2.0 | 0.56 | 0.32 | 0.97
| Frisell et al, 1997 (105) | 50–64 | 11.8 | 42 | 25,476 | 299,287 | 1.4 | 33 | 12,840 | 151,634 | 2.2 | 0.62 | 0.38 | 1.00
| Frisell et al, 1991 (Appendix 2, pg 20, ref 2) | 50–64 | 7.0 | 23 | 24,789 | 171,092 | 1.3 | 22 | 12,840 | 92,927 | 2.4 | 0.57 | 0.30 | 1.10
Malmö I + II | Nystrom et al, 2002 (30) | 43–49 | 13.3 | 53 | 13,568 | 184,000 | 2.9 | 66 | 12,279 | 160,000 | 4.1 | 0.73 | 0.51 | 1.04
| Andersson and Janzon, 1997 (103)† | 43–49 | 12.0 | 57 | 13,528 | 165,596 | 3.4 | 78 | 12,242 | 144,036 | 5.4 | 0.64 | 0.45 | 0.89
| Nystrom et al, 2002 (30) | 43–70 | 15.3 | 190 | 30,669 | 473,000 | 4.0 | 231 | 29,407 | 448,000 | 5.2 | 0.79 | 0.65 | 0.96
| Nystrom et al, 2002 (30) | 45–49 | 18.0 | 24 | 3,987 | 71,000 | 3.4 | 33 | 4,067 | 74,000 | 4.5 | 0.74 | 0.44 | 1.25
| Larsson et al, 1997 (50) | 45–49 | 15.4 | 15 | 3,945 | 61,000 | 2.5 | 23 | 4,017 | 62,000 | 3.7 | 0.67 | 0.35 | 1.27
| Nystrom et al, 2002 (30) | 45–54 | 18.2 | 71 | 8,673 | 158,000 | 4.5 | 78 | 8,311 | 151,000 | 5.2 | 0.87 | 0.63 | 1.20
| Andersson et al, 1988 (111) | 45–54 | 9.0 | 28 | 7,981 | 71,775 | 3.9 | 22 | 8,082 | 72,635 | 3.0 | 1.29 | 0.74 | 2.25
| Andersson et al, 1988 (111) | 45–69 | 8.8 | 63 | 21,088 | 186,297 | 3.4 | 66 | 21,195 | 187,016 | 3.5 | 0.96 | 0.68 | 1.35
| Nystrom et al, 2002 (30) | 45–70 | 17.1 | 161 | 21,088 | 360,000 | 4.5 | 198 | 21,195 | 362,000 | 5.5 | 0.82 | 0.67 | 1.00
| Nystrom et al, 1993 (17) | 45–70 | 11.5 | 87 | 20,695 | 239,000 | 3.6 | 108 | 20,783 | 240,000 | 4.5 | 0.81 | 0.62 | 1.07
| Nystrom et al, 2002 (30) | 50–70 | 16.9 | 137 | 17,101 | 289,000 | 4.7 | 165 | 17,128 | 288,000 | 5.7 | 0.83 | 0.66 | 1.04
| Nystrom et al, 2002 (30) | 55–64 | 17.2 | 63 | 8,194 | 141,000 | 4.5 | 83 | 8,679 | 149,000 | 5.6 | 0.80 | 0.57 | 1.12
| Andersson et al, 1988 (111) | 55–69 | 8.7 | 35 | 13,107 | 114,522 | 3.1 | 44 | 13,113 | 114,381 | 3.8 | 0.79 | 0.51 | 1.24
| Nystrom et al, 2002 (30) | 55–70 | 16.3 | 90 | 12,415 | 202,000 | 4.5 | 120 | 12,884 | 211,000 | 5.7 | 0.78 | 0.59 | 1.02
2-county, Kopparberg | Tabár et al, 2000 (112) | 40–49 | 17.3 | NR | NR | NR | NR | NR | NR | NR | NR | 0.76 | 0.42 | 1.40
| Tabár et al, 1995 (104) | 40–49 | 13.0 | 22 | 9,582 | 124,566 | 1.8 | 16 | 5,031 | 65,403 | 2.4 | 0.73 | 0.37 | 1.41
| Tabár et al, 1989 (114) | 40–49 | 7.9 | 13 | 9,582 | 75,698 | 1.7 | 9 | 5,031 | 39,745 | 2.3 | 0.76 | 0.32 | 1.77
| Tabár et al, 1985 (119) | 40–49 | 6.0 | 8 | 9,625 | 57,750 | 1.4 | 3 | 5,053 | 30,318 | 1.0 | 1.40 | 0.37 | 5.28
| Tabár et al, 2000 (112) | 40–74 | 17.3 | 152 | NR | 672,482 | 2.3 | 121 | NR | 326,091 | 3.7 | 0.61 | NR | NR
| Tabár et al, 1995 (104) | 40–74 | 13.0 | 126 | 38,589 | 501,657 | 2.5 | 104 | 18,582 | 241,566 | 4.3 | 0.60 | 0.46 | 0.79
| Tabár et al, 1989 (114) | 40–74 | 7.9 | 77 | 38,589 | 304,853 | 2.5 | 58 | 18,582 | 146,798 | 4.0 | 0.64 | 0.46 | 0.90
| Tabár et al, 1985 (119) | 40–74 | 6.0 | 51 | 39,051 | 234,306 | 2.2 | 39 | 18,846 | 113,076 | 3.4 | 0.63 | 0.42 | 0.96
| Tabár et al, 2000 (112) | 50–59 | 17.3 | NR | NR | NR | NR | NR | NR | NR | NR | 0.46 | 0.30 | 0.71
| Tabár et al, 1995 (104) | 50–59 | 13.0 | 34 | 11,728 | 152,464 | 2.2 | 34 | 5,557 | 72,241 | 4.7 | 0.48 | 0.29 | 0.77
| Tabár et al, 1989 (114) | 50–59 | 7.9 | 20 | 9,582 | 75,698 | 2.6 | 20 | 5,031 | 39,745 | 5.0 | 0.53 | 0.28 | 0.98
| Tabár et al, 1995 (104) | 50–74 | 13.0 | 104 | 29,007 | 377,091 | 2.8 | 88 | 13,551 | 176,163 | 5.0 | 0.58 | 0.43 | 0.78
| Tabár et al, 1989 (114) | 50–74 | 7.9 | 64 | 29,007 | 229,155 | 2.8 | 49 | 13,551 | 107,053 | 4.6 | 0.61 | 0.42 | 0.89
| Tabár et al, 1985 (119) | 50–74 | 6.0 | 43 | 29,426 | 176,556 | 2.4 | 36 | 13,793 | 82,758 | 4.4 | 0.56 | 0.36 | 0.87
2-county, Östergötland | Tabár et al, 2000 (112) | 40–49 | 17.3 | NR | NR | NR | NR | NR | NR | NR | NR | 1.06 | 0.65 | 1.76
| Nystrom et al, 2002 (30) | 40–49 | 16.8 | 31 | 10,285 | 172,000 | 1.8 | 30 | 10,459 | 176,000 | 1.7 | 1.05 | 0.64 | 1.71
| Tabár et al, 1995 (104) | 40–49 | 13.0 | 23 | 10,262 | 133,406 | 1.7 | 23 | 10,573 | 137,449 | 1.7 | 1.02 | 0.52 | 1.99
| Tabár et al, 1989 (114) | 40–49 | 7.9 | 15 | 10,262 | 81,070 | 1.9 | 15 | 10,573 | 83,527 | 1.8 | 1.03 | 0.50 | 2.11
| Tabár et al, 1985 (119) | 40–49 | 6.0 | 8 | 10,312 | 61,872 | 1.3 | 7 | 10,625 | 63,750 | 1.1 | 1.18 | 0.43 | 3.25
| Tabár et al, 2000 (112) | 40–74 | 17.3 | 167 | NR | 660,242 | 2.5 | 213 | NR | 643,696 | 3.3 | 0.76 | NR | NR
| Nystrom et al, 2002 (30) | 40–74 | 15.2 | 177 | 38,942 | 589,000 | 3.0 | 190 | 37,675 | 572,000 | 3.3 | 0.90 | 0.73 | 1.11
| Tabár et al, 1995 (104) | 40–74 | 13.0 | 135 | 38,491 | 500,383 | 2.7 | 173 | 37,403 | 486,239 | 3.6 | 0.78 | 0.60 | 1.01
| Tabár et al, 1989 (114) | 40–74 | 7.9 | 83 | 38,491 | 304,079 | 2.7 | 109 | 37,403 | 295,484 | 3.7 | 0.74 | 0.56 | 0.98
| Tabár et al, 1985 (119) | 40–74 | 6.0 | 36 | 39,034 | 234,204 | 1.5 | 47 | 37,936 | 227,616 | 2.1 | 0.74 | 0.48 | 1.15
| Tabár et al, 2000 (112) | 50–59 | 17.3 | NR | NR | NR | NR | NR | NR | NR | NR | 0.76 | 0.53 | 1.10
| Nystrom et al, 2002 (30) | 50–59 | 16.1 | 53 | 12,011 | 194,000 | 2.7 | 54 | 11,495 | 185,000 | 2.9 | 0.94 | 0.66 | 1.35
| Tabár et al, 1995 (104) | 50–59 | 13.0 | 44 | 11,757 | 152,841 | 2.9 | 51 | 11,248 | 146,224 | 3.5 | 0.85 | 0.52 | 1.38
| Tabár et al, 1989 (114) | 50–59 | 7.9 | 25 | 11,757 | 92,880 | 2.7 | 34 | 11,248 | 88,859 | 3.8 | 0.70 | 0.42 | 1.18
| Nystrom et al, 2002 (30) | 50–74 | 14.9 | 146 | 28,657 | 417,000 | 3.5 | 160 | 25,920 | 396,000 | 4.0 | 0.83 | 0.66 | 1.03
| Tabár et al, 1995 (104) | 50–74 | 13.0 | 112 | 28,229 | 366,977 | 3.1 | 150 | 26,830 | 348,790 | 4.3 | 0.73 | 0.56 | 0.97
| Tabár et al, 1989 (114) | 50–74 | 7.9 | 68 | 28,229 | 223,009 | 3.0 | 94 | 26,830 | 211,957 | 4.4 | 0.69 | 0.50 | 0.94
| Tabár et al, 1985 (119) | 50–74 | 6.0 | 28 | 28,722 | 172,332 | 1.6 | 40 | 27,311 | 163,866 | 2.4 | 0.67 | 0.41 | 1.08
Kopparberg +Östergötland | Tabár et al, 1995 (104) | 40–49 | 13.0 | 45 | 19,844 | 257,972 | 1.7 | 39 | 15,604 | 202,852 | 1.9 | 0.87 | 0.54 | 1.41
| Tabár et al, 1989 (114) | 40–49 | 7.9 | 28 | 19,844 | 156,768 | 1.8 | 24 | 15,604 | 123,272 | 1.9 | 0.92 | 0.52 | 1.60
| Tabár et al, 1989 (114) | 40–49 | 7.9 | 28 | 19,844 | 156,768 | 1.8 | 24 | 15,604 | 123,272 | 1.9 | 0.92 | 0.53 | 1.58
| Tabár et al, 1985 (119) | 40–49 | 6.0 | 16 | 19,937 | 119,622 | 1.3 | 10 | 15,678 | 94,068 | 1.1 | 1.26 | 0.56 | 2.84
| Tabár et al, 2000 (112) | 40–74 | 17.3 | 319 | 77,080 | 1,332,724 | 2.4 | 334 | 55,985 | 969,787 | 3.4 | 0.68 | 0.59 | 0.80
| Tabár et al, 1995 (104) | 40–74 | 12.5 | 269 | 77,080 | 965,405 | 2.8 | 277 | 55,985 | 701,207 | 4.0 | 0.69 | 0.57 | 0.84
| Tabár et al, 1989 (114) | 40–74 | 7.9 | 160 | 77,080 | 608,932 | 2.6 | 167 | 55,985 | 442,282 | 3.8 | 0.70 | 0.56 | 0.86
| Tabár et al, 1985 (119) | 40–74 | 6.0 | 87 | 78,085 | 468,510 | 1.9 | 86 | 56,782 | 340,692 | 2.5 | 0.69 | 0.51 | 0.92
| Tabár et al, 1995 (104) | 50–59 | 13.0 | 78 | 23,485 | 305,305 | 2.6 | 85 | 16,805 | 218,465 | 3.9 | 0.66 | 0.46 | 0.93
| Tabár et al, 1989 (114) | 50–59 | 7.9 | 45 | 23,485 | 185,532 | 2.4 | 54 | 16,805 | 132,760 | 4.1 | 0.60 | 0.40 | 0.89
| Tabár et al, 1995 (104) | 50–74 | 13.0 | 224 | 57,236 | 744,068 | 3.0 | 238 | 55,985 | 727,805 | 3.3 | 0.66 | 0.54 | 0.81
| Tabár et al, 1989 (114) | 50–74 | 7.9 | 132 | 57,236 | 452,164 | 2.9 | 143 | 40,381 | 319,010 | 4.5 | 0.65 | 0.51 | 0.83
| Tabár et al, 1985 (119) | 50–74 | 6.0 | 71 | 58,148 | 348,888 | 2.0 | 76 | 41,104 | 246,624 | 3.1 | 0.61 | 0.44 | 0.84
Edinburgh | Alexander et al, 1999 (106) | 45–49 | 12.2 | 47 | 11,479 | 139,868 | 3.4 | 53 | 10,267 | 126,413 | 4.2 | 0.75 | 0.48 | 1.18
| Alexander, 1997 (Appendix 2, pg 16, ref 9)† | 45–49 | 12.2 | 46 | NR | 139,871 | 3.3 | 52 | NR | 126,417 | 4.1 | 0.88 | 0.55 | 1.41
| Alexander et al, 1994 (Appendix 2, pg 16, ref 3) | 45–49 | 8.5 | 25 | 11,505 | 97,206 | 2.6 | 31 | 10,269 | 88,766 | 3.5 | 0.78 | 0.46 | 1.31
| Roberts et al, 1990 (Appendix 2, pg 16, ref 15) | 45–49 | 6.9 | 13 | 5,913 | 40,851 | 3.2 | 13 | 5,810 | 40,009 | 3.2 | 0.98 | NR | NR
| Alexander et al, 1999 (106) | 45–64 | 13.0 | 156 | 22,926 | 301,155 | 5.2 | 167 | 21,342 | 276,363 | 6.0 | 0.79 | 0.60 | 1.02
| Alexander et al, 1994 (Appendix 2, pg 16, ref 3) | 45–64 | 9.5 | 96 | 22,944 | 219,215 | 4.4 | 106 | 21,344 | 201,821 | 5.3 | 0.82 | 0.61 | 1.11
| Roberts et al, 1990 (Appendix 2, pg 16, ref 15) | 45–64 | 6.8 | 68 | 23,226 | 157,946 | 4.3 | 76 | 21,904 | 147,854 | 5.1 | 0.83 | 0.58 | 1.18
| Alexander et al, 1999 (106) | 50–64 | 12.9 | 129 | 17,149 | 222,393 | 5.8 | 134 | 15,748 | 200,637 | 6.7 | 0.87 | NR | NR
| Alexander et al, 1994 (Appendix 2, pg 16, ref 3) | 50–64 | 9.4 | 79 | 17,149 | 162,465 | 4.9 | 85 | 15,748 | 147,233 | 5.8 | 0.85 | 0.62 | 1.15
| Roberts et al, 1990 (Appendix 2, pg 16, ref 15) | 50–64 | 6.7 | 55 | 17,313 | 117,095 | 4.7 | 63 | 16,094 | 107,845 | 5.8 | 0.80 | 0.54 | 1.17

* Numbers in bold are calculated from data in the spreadsheet; all other numbers were taken from publications.

† Used in reference 30.

Note: CI indicates confidence interval; CNBSS, Canadian National Breast Screening Study; FU, follow-up; HIP, Health Insurance Plan of greater New York; NR, not reported; RR, relative risk.