# Appendix 2. Study Summaries

1) The Health Insurance Plan of Greater New York ^1–43^

The Health Insurance Plan of Greater New York (HIP) study began in December 1963, and was the first randomized controlled trial (RCT) of mammographic breast cancer screening. Women with 1 year of membership in the HIP who were not pregnant or did not have prior breast cancer were eligible for the study. Age- and family size-stratified pairs of women were individually randomized by drawing from a list to either an intervention or a control group who received usual care. The intervention consisted of two-view film mammography, a clinical breast exam (CBE) performed by a physician (usually a surgeon), and an interview to obtain relevant demographic information and health history. Independence between the 3 screening modalities was strictly maintained and screening was offered at baseline (prevalence exam) with 3 annual exams thereafter. Cases of breast cancer were ascertained using the HIP records, claims files death records, cancer registry, and the National Death Index. All causes of death were determined by record review blind to the women's study or control status and only incident breast cancers contributed to the number of cases. Analysis was intention-to-treat and all cumulative breast cancer deaths occurring among women with breast cancer diagnosed up to 7 years after beginning the study were used in the analysis.

The 2 study groups were similar in terms of age structure, religion, education, marital status, prior pregnancies, menopausal status, and history of prior abnormal breast exam. Although prior breast cancer was an exclusion for entry, prior mastectomy status was more completely ascertained for the study group than the control group, resulting in differences in the groups' sizes (30,239 versus 30,756). ^21^ However, when breast cancer deaths were evaluated, only deaths occurring among incident breast cancer cases developing within the study period or in a defined period of observation were considered. ^22^ Breast cancer rates after 10 years of follow-up, as well as mortality from all causes except breast cancer, were similar in the study and control groups. Compliance with the initial exam was 67% and only these women were offered subsequent screening. When evaluating the characteristics of the women invited for screening who were screened and those who refused, women who refused screening had higher general mortality than those who were not screened for breast cancer, but lower breast cancer mortality. Because of these differences, all analyses are intention to treat. The prevalence screen of this study detected 2.73 malignancies per 1,000 women screened and subsequent (incidence) screens detected approximately 1.49 malignancies per 1,000. Diagnoses of breast cancer outside of screening (interval cancers) accounted for 0.92 malignancies per 1,000 detected in the study group. The malignancy rate among the control group was 1.87 out of 1,000 women. The incidence rate of breast cancer among women who refused screening was 1.45 out of 1,000. After 5 years of follow-up (approximately 1.5 years after the last screen), 304 breast malignancies were detected in the study group and 295 in the control group.

The sensitivity of screening with mammography and CBE in this study was estimated at approximately 75% using 1 year of followup and breast cancer detected on clinical breast exam in the denominator. However, sensitivity and the contribution of mammography varied by age. Among women aged 40 to 49, 25% of malignancies were detected by mammography alone, and 57.5% by clinical breast exam only. Both clinical breast exam and mammography detected 17.5% of malignancies in this age group. Among women aged 50 to 59, mammography alone detected approximately 39% of malignancies, clinical breast exam detected 40%, and both combined detected 21%. Among women aged 60 to 64, mammography detected 32% of malignancies, clinical breast exam 36%, and both modalities combined detected 32%.

In this study, when screening led to a biopsy, 1 in 5, or 21%, of the biopsies were positive for breast cancer. Among women younger than age 50, 1 out of 10 biopsies resulted in a confirmation of breast cancer. For women older than age 50, the malignancy to biopsy ratio was 1 to 4. The authors make an important point in this regard, that the false positive rate should also be considered in light of what the false positive rate under nonscreening conditions might be in the setting of usual clinical care.

Nine years after study entry, the cumulative number of breast cancer deaths was 128 in the control group and 91 in the intervention group. After 10 years of follow-up, the risk of breast cancer mortality among the entire study group (screened and unscreened) was reduced by 30%. After 18 years of follow-up, the risk was reduced by 25%. A controversial area in this study has been the group aged 40 to 49, which demonstrated a 23.5% reduction in breast cancer mortality 10 years from entry and a 24.6% decrease in mortality 18 years from entry. ^44^ Neither finding was statistically significant, however. Results were also not significant when evaluated by decade for other ages. Data among 40- to 49-year-old women were re-analyzed by Chu et al in 1988 and a statistically significant decrease in breast cancer mortality was identified considering all cases of breast cancer diagnosed within 6 years of randomization. ^3^ In reviewing the survival curves, the difference in breast cancer mortality among women aged 40 to 44 at entry emerged at approximately year 7 of the study; among women aged 45 to 49, it emerged at approximately year 5. Some analyses of the breast cancer deaths among the 40- to 49-year-old group have suggested that, to a large extent, the difference in death rates is due to the diagnosis of breast cancer after study women passed their fiftieth birthdays. However, when these data are analyzed by age at diagnosis of breast cancer, among women who were aged 40 to 49 at the time of breast cancer diagnosis, there were 18 deaths in the study group and 28 in the control group 18 years after entering the study, suggesting benefit.

2) Canadian National Breast Screening Study—1 ^45–123^

The CNBSS-1 was conducted from January 1980 to March 1985, at 15 centers in Canada. ^112^ Volunteers aged 40 to 49 without prior breast cancer or a mammogram in the prior 12 months were recruited to the study using mass media, and after a CBE, 25,214 women were randomized to receive mammography plus clinical breast examination for 4 to 5 annual screens. The control group of 25,216 women received a single CBE followed by usual care. All women were taught breast self-exam (BSE) and for those returning to the clinical center, breast self-exam was reinforced. The CBEs were provided by nurses and physicians and if an abnormal screen was detected, the woman was referred to the NBSS review clinic, where the study surgeon reviewed the case and mammogram with the study radiologist and recommendations were made to the participant's physician to decide on follow-up. Interval cancer was breast cancer occurring less than 12 months after screening exam.

Seven-year follow-up was reported in 1992. The control and study groups were similar in demographic characteristics and breast cancer risk factors. Compliance with the screening was 100% for the first round (by definition) and 86.5% for the fifth. At the initial screen, the prevalence of breast cancer was 3.89 our of 1,000 in the study group and 2.46 out of 1,000 in the usual care group. For screens 2 through 5, the incidence rates ranged from 1.74 to 2.38 out of 1,000 among the women screened. The observed rates of breast cancer were 1.26 in the study group and 1.02 in the usual care group when compared to the expected rates in the population. A finding that has caused a great deal of concern about the randomization process was an excess number of breast cancer cases with 4 or more positive lymph nodes identified in the first screen of the study among women randomized to CBE plus mammography (17 versus 5). After 5 years of screening and 7 years of follow-up, the excess number of women with 4 or more positive lymph nodes in the mammography/CBE group was 24. ^123^ However, the randomization process was formally reviewed and no evidence of subversion was identified. ^45^ After 7 years of follow-up, there were 29 breast cancer deaths in the study group and 18 in the usual care group, suggesting no benefit of screening. ^112^ An update of this study, published in 1997 with 10.5 years of follow-up, reported 82 breast cancer deaths in the study group and 72 in the control group, with a rate ratio of 1.14 (95% CI, 0.83–1.56).

Results from this study reflecting 13 years of follow-up continue to show no benefit of screening in this age group. In addition, because of concern about the excess number of women with positive lymph nodes in the intervention arm of this study, the results were reanalyzed excluding women with positive nodes at the first screen and the findings of no benefit persisted.

3) Canadian National Breast Screening Study—2 ^45–123^

This study was designed to determine the incremental benefit of adding mammography to annual clinical breast exam and breast self-exam instruction in reducing breast cancer mortality among women aged 50 to 59. ^111,^ ^117^ The participants were recruited through mass media advertising and randomized after a CBE to either annual CBE (n=19,694) or annual CBE plus mammography (n=19,711) for 5 consecutive screens. Two-view mammography was used and very complete CBEs were conducted by nurses or physicians. In addition, breast self-exam was taught at the first visit and reinforced at each screening visit. Compliance with the study was 100% by definition for the first screen and 86.5% at the fifth screen. Biopsy rates for CBE-only women ranged from 8.7 out of 1,000 at screen 1 to 2.7 out of 1,000 at screen 5. Among women receiving both mammography and CBE, the biopsy rates were 24.3 out of 1,000 and 7.1 out of 1,000 at the first and fifth screen, respectively.

The prevalence of cancer at the first screen was 7.2 out of 1,000 in the CBE plus mammography group and 3.45 out of 1,000 in the CBE group. Interval cancers occurred in 50 women in the dual-screen group and 88 women in the CBE-only group and many more in situ (38.3 versus 8.6 out of 1,000) cancers were detected in the dual screen group. In the dual-screen group 267 invasive breast cancers were detected, compared with 148 in the CBE group. At year 5, the totals were 349 and 283, respectively, with equal numbers of cases occurring after approximately 12 years of follow-up. Screening ended in 1988 and the first results after 8.3 years of observation showed a relative risk (RR) of 0.97 (95% CI, 0.62–1.52), suggesting no incremental benefit of mammography. After 13 years of follow-up, 107 women had died of breast cancer in the CBE plus mammography group, and 105 in the CBE group, with a cumulative rate ratio of 1.02 (95% CI, 0.78–1.33).

The study has been highly criticized for many reasons, the most important of which is that the mammography performed has been considered to be of poor quality by outside investigators. ^78,^ ^124^ However, several other factors argue against poor-quality mammography in this study. In particular, the number of malignancies detected at both prevalence and incidence screens has been similar or higher than found in other studies. However, this may be because women included in this study were volunteers, who may have had higher than average risks for breast cancer than women (need to complete sentence). This issue was evaluated with the finding that incidence was increased and mortality decreased among both groups when compared to the Canadian population in general, suggesting benefit in both screening arms of the study. However, since this study relied on volunteers who may differ from the general Canadian population, it is difficult to interpret these findings.

4) Edinburgh ^125–139^

Edinburgh was one of the screening centers enrolled in the non-randomized UK Trial of the Early Detection of Breast Cancer. ^139^ In 1978, while planning the trial, the investigators added a randomization component to the study so that women aged 45 to 64 could be randomized to either an invitation to screening or to a control group continuing to receive usual care. The only exclusion was prior breast cancer, but this was normally ascertained after randomization. Eighty-four general practices contributed the names of all women aged 45 to 64 and after stratification by number of practice partners, women were cluster randomized. There were 23,226 women randomized to the study group receiving baseline CBE and two-view mammogram with annual CBE and biennial one-view mammogram for 7 years. The control population of 21,904 continued to receive usual care. Compliance with the initial screen was 61.3% on average, with lower compliance with follow-up screening. Compliance with screening also was lower among women of lower socioeconomic status. All trial women aged ≤65 were eligible for screening in 1988, 6, 8, and 10 years following entry.

Breast cancer death was defined as death of a woman with breast cancer defined as the primary or secondary cause of death. Mortality was first analyzed after 7 years of follow-up and was conducted with modified logistic regression, which deals with cluster randomization and adjusted for socioeconomic status.

After 7 years of follow-up, 245 breast cancer cases had been detected with screening and 34 interval cases diagnosed. Sensitivity of screening was 91% to 97% during years 1, 3, 5, and 7 when both CBE and mammogram were done. Sensitivity during years 2, 4, and 6 when only CBE was done ranged from 63% to 72%.

Further analysis of this study at 10 years identified 250 breast cancer deaths and an overall relative risk of 0.82 (95% CI, 0.61–1.11) among study women. Among women aged 45 to 49, the relative risk was 0.78 (95% CI, 0.46–1.31) and among women aged 50 to 60 it was 0.85 (95% CI, 0.62–1.15). More interval breast cancer occurred in this study than the Swedish studies. The proportion of the control incidence was 0.12 during year 1, 0.42 during year 2, and 0.67 between years 2 and 3. These data suggest that an interval of 2 years may be too long or that screening lacked sensitivity. ^129^

After 14 years of follow-up and adjustment for socioeconomic status, the rate ratio was reduced by 21% (RR, 0.79; 95% CI, 0.60–1.02) among all women. If deaths occurring among women diagnosed with breast cancer 3 years after the end of the study were excluded, the reduction was 29% (RR, 0.71; 95% CI, 0.53–0.95). Among women aged 45 to 49, the relative risk was 0.75 (95% CI, 0.48–1.18); however, none of these mortality benefits occurred in women diagnosed with breast cancer before age 50. ^133^ All-cause mortality was significantly higher in the control group than in the screened group (20.1 more deaths per 10,000 person-years; 95% CI, 13.3–26.9). ^140^

5) Malmo ^141–158^

The Malmo trial began in 1976 when a 50% random sample of women aged 44 to 68 identified in the Malmo population registry were individually randomized by birth cohort to invitation to screening or usual care. ^149^ There were 21,088 women invited to screening with two-view mammography at an interval of 18 to 24 months for 2 rounds, then either two- or one-view mammography thereafter; 21,195 received usual care. The trial ended in December 1986 after 5 completed screening rounds. Fourteen years after the trial began, screening was offered to women in the control group. Women previously treated for breast cancer were included in the numerator only if a new breast cancer was diagnosed. The outcome of interest was breast cancer as the underlying cause of death, and an end point committee determined cause of death by record and post-mortem review, blind to trial status. During this trial, mammography was available outside the screening program. A sample of 500 control women showed that 25% of controls underwent mammography and most only once. The control mammography rate ranged from 13% among women aged 60 to 69, to 35% among women aged 45 to 49.

After mean observation of 8.8 years, 588 study and 447 control women had developed breast cancer. During the study period, 99 study women and 94 controls died of all causes; 63 versus 64 died of breast cancer (RR, 0.96; 95% CI, 0.65–1.35). More women in the study group died of breast cancer in the first 6 years of the study after which the trend reversed. This was partially attributed to an increased risk for breast cancer death among younger study group women. Among women younger than age 55, 28 died in the study group and 22 in the control group (RR, 1.29; 95% CI, 0.74–2.25). For women age 55 or above, the relative risk of breast cancer was 0.79 95% CI, 0.51–1.24) with 35 study group and 44 control deaths.

A 1993 overview of all Swedish studies reviewed the Malmo trial in 1993 with follow-up until 1989. At that time there had been 87 deaths in the study group and 108 in the control group. The relative risk of breast cancer was 0.81 (95% CI, 0.62–1.07).

Another update evaluating women aged 45 to 49 was published in 1997. ^152^ This involved evaluation of 2 cohorts of women aged 45 to 50: cohort 1, entered in 1976, and cohort 2, entered in 1978. After 15.5 years of follow-up for the first cohort and 10 years of follow-up for the second, the relative risk of breast cancer death was 0.64 (95% CI, 0.45–0.89). Lower mortality in this age group began to emerge at approximately 6 years. ^152^ An update of this trial in 2002 reflecting approximately 19 years of observation ^159^ showed a relative risk of breast cancer mortality among screened women of 0.82 (95% CI 0.67–1.00) using the evaluation method of analysis. Among intervention women in both cohorts aged 45 to 49, the relative risk of breast cancer death compared to controls was 0.73 (95% CI 0.51–1.04) using the evaluation method.

6) The Stockholm Trial ^160–171^

The Stockholm Trial began in March 1981, and involved women aged 40 to 64 in Stockholm. There were 40,318 women invited to screening by one-view mammography alone versus usual care in a control group of 19,943 women. ^164^ Individual randomization was conducted by birth date. After the second screen in 1985, the control design of the study was broken and during 1986, the control women were invited for screening mammography. After December 1986, no more breast cancer cases were followed for breast cancer death in the original trial publications (evaluation method of analysis). Compliance with the first screening was approximately 81%. The second screening occurred 28 months later and the compliance was approximately 81%. The control population was screened after the second screening and had a compliance rate of 77%.

Follow-up to January 31, 1989, with a mean follow-up of 7.4 years was reported in 1991. ^164^ The detection rate of breast cancer in the first round of screening was 4.0 out of 1,000 women screened. The detection rate at the second screening approximately 28 months later was 3.1 out of 1,000 women screened. The end point in the trial was breast cancer death, but this early trial report differs from many of the others by defining breast cancer death as breast cancer present at death, rather than breast cancer as the underlying cause of death. Using this definition, 52 patients in the study population and 36 in the control population died with breast cancer diagnosed during the study. Breast cancer was the underlying cause of death in 39 patients in the study population and 30 in the control population. The relative risk of death among the entire group was 0.71 (95% CI, 0.4–1.2). Among women older than age 50, the relative risk was 0.57 (95% CI, 0.3–1.1). Among women younger than age 50, the relative risk was 1.09 (95% CI, 0.4–3.0). Of the 39 breast cancer deaths in the study population, 44% resulted from interval cancers, 36% occurred in women refusing screening, and 20% occurred in the screened population. Analysis of this study was intention to treat and follow-up was relatively complete.

Further data from this trial were published in 1993. ^172^ This report uses different denominators than prior and subsequent publications from this study, and does not report a mean length of follow-up, only that the women were followed to December 31, 1989. In addition, all deaths were blindly reviewed by an independent endpoint committee. At that time, breast cancer death (underlying cause) had occurred in 53 study group women and 40 control group women, with a relative risk of 0.80 (95% CI, 0.53–1.22). ^172^

These numbers are based on a “follow-up” model in which breast cancer deaths among women with a primary diagnosis of breast cancer after the date of randomization and before the study end point are considered. Another method of reporting death rates in this population involves use of the “evaluation method,” which excluded breast cancer deaths in women whose breast cancer was detected after the completion of the screening of the controls. ^172^ Using this model, 32 deaths occurred in the control group and 40 in the intervention group with a relative risk of 0.72 (95% CI, 0.45–1.16). Reanalysis of this trial in 2002 with an average observation time of 14.7 years and using the evaluation method of follow-up showed a relative risk of 0.91 (95% CI 0.65–1.27) among all women and 1.52 (95% CI 0.80–2.88) among women aged 40 to 49. ^159^

Another analysis of this study, published in 1997, specifically evaluated the relative risk of breast cancer death in screened and non-screened women in the 40- to 49-year-old group. ^166^ After 11.4 years of follow-up, there were 24 breast cancer deaths in the study group and 12 in the control group with a relative risk of 1.08 (95% CI, 0.54–2.17). The authors of this analysis reported that the recall rate among study women for clinical exam, fine needle biopsy, or additional x-rays, after a complete mammogram, was 0.8% in all subjects and 1% in the 40- to 49-year-old group. The proportion of false positive cases was 242 per 100,000 women-years in women older than age 50 compared to 355 per 100,000 women-years in women younger than age 50. Rates of benign surgical biopsies in the incident screening round in women aged 40 to 49 were 49 per 100,000 women-years compared to 21 per 100,000 women-years among women older than age 50. One out of 2.5 surgical biopsies was benign in the 40- to 49-year-old age group compared to 1 in 1.7 benign biopsies for women older than age 50. The authors estimate that 41% of the follow-up costs of false positive exams in the first screening round resulted from examining women aged 40 to 49. Interval malignancy rates are also reported, and a significantly larger number of women aged 40 to 49 were diagnosed with interval cancer when compared to women older than age 50. However, these interval cancers were shown to have better survival than breast cancer that occurred in the control population.

7) The Swedish Two-County Trial ^172–241^

The Swedish Two-County Study began in 1977 and involved cluster randomization of women aged 40 to 74 from two counties: Ostergotland (E-County) and Kopparberg (W-County). ^214^ The screening group was comprised of 77,080 women; the usual care group involved 55,985 women. Screening consisted of one-view mammography at an average interval of every 24 months among women aged 40 to 49 and every 33 months among women aged 50 to 74. The major outcome evaluated was death from breast cancer. Deaths were classified after full review of clinical and pathologic records, but the review originally was not blind. Mortality rates as initially reported were determined for all breast cancer diagnosed in both arms up to and including the first screen of the controls and a contemporaneous final screen of the study group (evaluation method). Analysis was intention to treat. In 1985, after a mortality reduction of 31% among women invited to screening was reported, the usual care group was invited for screening (approximately 7 to 8 years after randomization). Overall compliance with the first invitation to screening was 89%; for the second screening it was 83%. After the second round of screening, invitations to women aged 70 to74 were discontinued due to poor response rates. 13% of control women received mammography during the study. Specificity of mammography during the first round of this study was 95.3% for further evaluation and 99% for biopsy; in the second round, specificity for further evaluation was 97.4% and for biopsy 99.8%. Corresponding positive predictive values are: 10% for further evaluation and 55% for biopsy in the first round, and 12% for further evaluation and 67% for biopsy in the second round. Predictive values continued to improve with the third round.

From the time of randomization, cumulative mortality curves for the entire cohort began to diverge at approximately 1 year. In the first report, ^214^ the relative risk of mortality was 0.69 (95% CI, 0.51–0.92) among all ages, but mortality benefit seemed confined to women aged 50 to 74 (RR, 0.61; 95% CI, 0.44–0.84). After 20 years of follow-up, the mortality reduction persists at 32% (RR, 0.68; 95% CI, 0.59–0.80), with most benefit shown among women aged 50 to 69 (RR, 0.48–0.76) and varying by decade and county. Results among women aged 40 to 49 varied by county. In W-County, a mortality benefit began to emerge at 7 years with a relative risk of 0.76 (95% CI, 0.42–1.40) after 20 years of follow-up. Among women in E-County, no mortality reduction occurred, with a relative risk of 1.06 (95% CI, 0.65–1.76). Lack of benefit in E-County was attributed to high breast cancer fatality rates among women invited to screening but not attending screening. ^238^ Compliance with screening varied by age. Among women from both counties older than age 70, over half the breast cancer deaths occurred among women who never attended screening. For women aged 60 to 69, 38% of breast cancer deaths occurred among non-attenders. However, among women aged 40 to 49, over half of breast cancer deaths occurred among women with interval cancers. The relative risk of breast cancer mortality was also reduced among women aged 70 to 74 (RR, 0.79), although not statistically significant. A report from 1989 calculates that 1 breast cancer death was prevented per 4,000 woman-years, 1,460 mammograms, 13.5 biopsies, and 7.4 breast cancers detected. In the Two-County Study, after the first screening round, 50% of biopsies were malignant; after the second round, 75% of biopsies were malignant.

An important finding from this study relates to interval cancers. Among women older than age 50, relatively few interval cancers were observed in the 2 years after screening. ^217^ However, this rate rises significantly in the third year after screening. Specifically, in the first 12 months after screening there were 13% interval cancers, 29% in the second 12 months and 45% in year 2. ^217^ These data suggest that screening women older than age 50 every 2 years is adequate. Tumor modeling studies in this population have suggested that a screening interval of less than 24 months would be required to detect the more rapidly-growing tumors seen among women aged 40 to 49. Indeed, among women aged 40 to 49, the rate of interval cancers is 40% in the first year following screening and nearly 70% in the second year. ^217^ In the Two-County Study 50% of breast cancer deaths in women aged 40 to 49 were from interval cancers. For women older than age 50, much of breast cancer mortality comes from noncompliance with screening. In contrast, for women younger than age 50, much of the breast cancer mortality observed in this study occurred due to the emergence of interval cancers. ^217^ Modeling studies indicate that annually screening women aged 40 to 49 would decrease breast cancer mortality by 36%. ^235^ In the 2002 Swedish overview, ^159^ using the follow-up evaluation method, the findings from Ostergotland (E-County) were reported after approximately 17 years of follow-up. This report showed no screening benefit among women aged 40 to 49 (RR, 1.05), with an overall age-adjusted relative risk of 0.89 (95% CI 0.72–1.09) among women aged 40 to 74 using the evaluation method of analysis.

8) Gothenburg ^242–245^

The Gothenburg trial began in December 1982 and involved all women (51,611) in the city of Gothenburg, Sweden, aged 39 to 59. However, results initially were reported only for women aged 39 to 49 at randomization. Intervention women (n=11,724) were cluster (18%) or individually (82%) randomized to invitation to screening with two- or one-view mammography (30%) every 18 months over 7 years (5 rounds of screening). Women with prior breast cancer were excluded from the study. Films were single-read in the first 3 rounds and double-read thereafter. A moving grid was used in all screens except the first. The control group of 14,217 women continued to receive their usual care until after the fifth screen when they also were invited for screening. There was no evidence of misallocation in the randomization process. All breast malignancies diagnosed up to and including the fifth screen of the study group, and the first screen of the control group at approximately year 7, were followed for breast cancer mortality. Cases of invasive breast cancer and ductal carcinoma in situ were included, but cases of lobular carcinoma in situ were not.

Compliance within the study group was 85% for round 1, 78% for round 2, 79% for round 3, 77% for round 4, and 75% for round 5. Compliance for the control group was 66%. Sensitivity was estimated in the study at 87% for mammography and the mean sojourn time for breast cancer in this age group was estimated at 2.21 years. Thirty-five percent of all biopsies resulting from first screens led to a diagnosis of breast cancer and this rate improved with subsequent rounds. In the second screen, 40% of biopsies resulted in breast cancer diagnosis, and 56% of third, 84% of fourth, and 69% of biopsies resulting from the fifth breast cancer screening round resulted in a malignant diagnosis. When the control group was screened after the fifth screening of the study group, 70% of women undergoing biopsy were diagnosed with malignant disease.

During the screening period, 144 breast cancers were diagnosed in the study group and 195 in the control group including those at the first control screen. Mortality was evaluated using the evaluation method. A significant mortality reduction was shown after 11 years of follow-up with a relative risk of 0.55 (P = .035). Mortality differences in the 39- to 49-year-old age group diverged 6 to 8 years following randomization and the gap continued to widen with longer follow-up. All-cause mortality was similar between the control and study groups. The incidence of breast cancer in the study group was higher until the first screen of the control group, where the incidence became slightly higher in the control group, although not significantly. Deaths from interval breast cancer accounted for 55% of deaths in the study group and 33% of these deaths occurred in non-attenders.

The proportional incidence of interval cancers was low within the first 12 months of screening, but increased significantly between 12 and 18 months of screening. The investigators have estimated that approximately 72% (13 of 18) of breast cancer deaths in the study group and 63% (25 of 40) in the control group resulted from breast cancer that was diagnosed before age 50.

In this study, an unusual finding was not finding an increased number of breast cancers diagnosed at the prevalence screen compared to the incidence screens. The authors attribute this to lack of a grid for reading mammograms, a lower incidence of breast cancer in younger women, shorter mean sojourn time in younger women, and lower sensitivity of mammography. They also hypothesize that the low prevalence in the first screen might be due to screening the study group had received prior to enrollment as part of their usual care. In fact, 28% of women in the study group and 19% of the controls had had prior mammograms. An accompanying editorial was extremely critical of this study, ^245^ particularly the lack of description of the randomization process, as well as appropriate analysis of cluster randomization. The authors criticize the study investigators for not adequately describing the populations screened. They also suggested that the rate of breast cancer was higher in the control group because the groups were not similar. However, the study investigators suggest that this had been shown in their analysis to be due partially to lead time as well as nonstatistically significant. When adjustment for lead time was made, the difference in incidence rates was fully accounted for.

In the 2002 Swedish update, ^159^ information was reported on all women aged 39 to 59 in this study. After 13 years of observation (median trial time 6.7 years), 62 breast cancer deaths had occurred in the intervention group and 113 in the control group for an overall relative risk of 0.76 (95% , 0.56–1.04) using the evaluation method of follow-up. Among women aged 40 to 49 after the same average length of follow-up, the relative risk was 0.58 (95% CI, 0.35–0.96).

9) USSR/WHO trial in Leningrad/St Petersburg ^246–250^

A preliminary 10-year follow-up was published in 1999 in Russian that provided data on 122,471 women between the ages of 40 and 64 (57,712 received BSE and 64,759 were in the control group). Twenty-eight clinics were involved in providing participants. In 1985 when this study began, neither BSE nor mammography was being used as a screening modality. The intervention group was given personal BSE training in small groups of 5 to 20 women by nurses and physicians. Reinforcement was given using posters, broadcasts, and calendars. The control group had no intervention. Women were excluded if they had a history of breast cancer or other cancers. At the annual exam, BSE technique was evaluated by evaluating the frequency of performing eight BSE techniques: breast examination, 3 to 4 fingers with palpation, thumb not used, use of finger pads, concentric and radial movements, thorough exam, and palpation of the axial area.

After the fourth year, women were given positive reinforcement of the benefits of BSE. The demographics of the 2 groups were similar in age and education. There were a larger percentage of married women in the BSE group (68.4% vs 56.7%). In the first year of the study, 82% of the women performed the BSE at least 5 times per year. Eight years after the initial instruction, 76.4% of the women were still performing the BSE at least 5 times per year. The monthly BSE rate decreased from 52.3% to 32.2% over 8 years and reached a low of 17.9% in the fourth year. Women in the BSE group had more physician visits (4,340 vs 2,438; P<0.05) and had more breast biopsies performed (1,138 vs. 797; P<0.05) than the control group. Of the 122,471 women studied, the expected number of breast cancer cases was 1,060. Over the 10 years, 939 cases were found; 493 in the BSE group and 446 in the control group. There were 243 deaths; 157 in the BSE group and 164 in the control group. Further, the number/percentage of node negative breast cancers were similar among the 2 groups; 237 (48%) in the BSE group and 207 (46.4%) in the control group. Distant metastases were found in 3% of the BSE cases and 3.2% of the control cases. Using the Kaplan-Meier method, a 10% non-significant 9-year survival was found in the BSE group (65%) over the control group (55%); P>0.05. This study continued until 2001.

10) Shanghai ^251^

Between October 1989 and October 1991, 267,040 current and retired female textile workers in the Shanghai Textile Industry Bureau (STIB) were entered into the study. The women were randomly assigned to either the BSE instruction group (133,375) or the control group (133,665), which received education on lower back pain. Mammography was not available for routine screening. Most of the women received medical care at their respective factory's clinic. If further care was needed, they were usually referred to 1 of 3 hospitals. All women answered a baseline questionnaire assessing risk factors for breast cancer. Inclusion criteria included being a female, current or retired textile employee, born between 1925 and 1958 (ages 31–64), and a permanent resident of Shanghai. Exclusion criteria included leaving the textile company (6.4%), history of breast cancer (0.5%), and not completing a baseline questionnaire (2%).

Demographically, the 2 groups were very similar in regards to age, age of menarche, age of first birth, history of abortion, having 1 live birth, menopausal status, history of oophorectomy, prior breast lump, and having a sister with breast cancer. The BSE instruction group received training in the initial BSE class, which included proper technique, 2 reinforcement sessions, regular observed BSE by medical personnel, handouts, and posters. The initial session was given to the women in groups of 10. A demonstration of the proper technique was performed on silicone breast models, which included inspection and palpation while standing and lying down. In the first year, compliance was evaluated in current workers at months 1, 3, 6, 9, and 12. Retired workers were evaluated at months 6 and 12. After the first year, all women were evaluated every 6 months until July 1995. At 1 year, all the women in the BSE group saw a reinforcement video. A second video was shown between 1993 and 1995. The control group received 1 reinforcement video session at the end of one year on lower back pain. An active surveillance program to detect cancer included evaluation of all asymptomatic lumps by a medical worker who could then refer the patient to a surgeon, usually at 1 of the 3 referral hospitals. The medical workers recorded all breast lumps, how they were identified, and the interval between last exam and lump detection and diagnosis. A hospital tumor and death registry and a Shanghai cancer registry were also used to detect breast cancers that might be missed by the study's follow-up procedures.

The primary end point was breast cancer death. The BSE group has an 83.6% compliance for the all 3 sessions (baseline and 2 reinforcement classes) and 96.1% for 2 sessions. The control group has a compliance rate of 94.1% after 2 sessions. Expected breast cancer cases totaled 605, and 653 were actually detected, which indicates few, if any, cases were missed. Pathologists in China and Seattle confirmed all cases. The BSE group had 331 cases of breast cancer and 1,457 false positive tests. The control group has 322 cases and 623 false positive tests. Deaths due to breast cancer were equally divided between the two groups; 25 in each. The overall 5-year breast cancer mortality was similar in both cohorts and there was no difference in cumulative death rate due to breast cancer per 100,000 women-years, with 30.9 in the instructional group and 32.7 in the control group. This study is ongoing.

## References Appendix 2

1 Final reports of National Cancer Institute ad hoc working groups on mammography screening for breast cancer and a summary report of their joint findings and recommendations DHEW Publication No. (NIH) 11 1400. Washington, DC: US Department of Health, Education and Welfare; 1977.
2 Aron J L, Prorok P C. An analysis of the mortality effect in a breast cancer screening study. International Journal of Epidemiology. 1986;15(1):36-43. [pmid: 3957541].
3 Chu K C, Smart C R, Tarone R E. Analysis of breast cancer mortality and stage distribution by age for the Health Insurance Plan clinical trial. Journal of the National Cancer Institute. 1988;80:1125-1132. [pmid: 3411625].
4 Chu K C, Connor R J. Analysis of the temporal patterns of benefits in the Health Insurance Plan of Greater New York trial by stage and age [published erratum appears in Am J Epidemiol 1994 Aug 1;140(3):302]. American Journal of Epidemiology. 1991;133:1039-1049. [pmid: 2035504].
5 Connor R J, Prorok P C, Weed D L. The case-control design and the assessment of the efficacy of cancer screening. Journal of Clinical Epidemiology. 1991;44(11):1215-1221. [pmid: 1941016].
6 Dodd G D. Introduction to “Evaluation of periodic breast cancer screening with mammography: methodology and early observations” by Shapiro, Strax and Venet [editorial]. CA: A Cancer Journal for Clinicians. 1990;42(2):109.
7 Fink R, Shapiro S, Lewison J. The reluctant participant in a breast screening program. Public Health Reports. 1968;83(6):479-490. [pmid: 4968124]. [pmcid: 1891076].
8 Fink R, Shapiro S, Roester R. Impact of efforts to increase participation in repetitive screenings for early breast cancer detection. American Journal of Public Health. 1972;62(3):328-336. [pmid: 5011163]. [pmcid: 1530069].
9 Fink R, Shapiro S. Significance of increased efforts to gain participation in screening for breast cancer. American Journal of Preventive Medicine. 1990;6(1):34-41. [pmid: 2187496].
10 Friedman D R, Dubin N. Case-control evaluation of breast cancer screening efficacy. American Journal of Epidemiology. 1991;133(10):974-984. [pmid: 2035508].
11 Habbema J D, van Oortmarssen G, van Putten D J. An analysis of survival differences between clinically and screen-detected cancer patients. Statistics in Medicine. 1983;2(2):279-285. [pmid: 6648143].
12 Habbema J D, van Oortmarssen G J, van Putten D J, Lubbe J T, van der Maas P J. Age-specific reduction in breast cancer mortality by screening: an analysis of the results of the Health Insurance Plan of Greater New York study. Journal of the National Cancer Institute. 1986;77(2):317-320. [pmid: 3461193].
13 Shapiro S, Strax P, Venet L. Evaluation of periodic breast cancer screening with mammography. Methodology and early observations. JAMA. 1966;195(9 Feb. 28):731-738. [pmid: 5951878].
14 Shapiro S, Strax P, Venet L, Fink R. The search for risk factors in breast cancer. American Journal of Public Health & the Nations Health. 1968;58:820-835.
15 Shapiro S, Strax P, Venet L. Periodic breast cancer screening in reduced mortality from breast cancer. JAMA. 1971;215(11):1777-1785. [pmid: 5107709].
16 Shapiro S, Strax P, Venet L, Venet W. Changes in 5-year breast cancer mortality in a breast cancer screening program. Paper presented at: National Cancer Conference, 1972.
17 Shapiro S. Evaluation of two contrasting types of screening programs. Preventive Medicine. 1973;2(2):266-277. [pmid: 4579345].
18 Shapiro S, Goldberg JD, B. HG. Lead time in breast cancer detection and implications for periodicity of screening. Amerjepidem. 1974;100:357–366.
19 Shapiro S. Evidence on screening for breast cancer from a randomized trial. Conference on Breast Cancer: A Report to the Profession. 1976: 19–36.
20 Shapiro S. Evidence on screening for breast cancer from a randomized trial. Cancer-(Philadelphia). 1977;39:2772-2782.
21 Shapiro S, Venet W, Strax P, Venet L, Roeser R. Prospects for eliminating racial differences in breast cancer survival rates. American Journal of Public Health. 1982;72:1142-1145. [pmid: 7114338]. [pmcid: 1650189].
22 Shapiro S, Venet W, Strax P, Venet L, Roeser R. Ten- to fourteen-year effect of screening on breast cancer mortality. Journal of the National Cancer Institute. 1982;69:349-355. [pmid: 6955542].
23 Shapiro S, Venet W, Strax P, Venet L, Roeser R. Selection, follow-up, and analysis in the Health Insurance Plan Study: a randomized trial with breast cancer screening. National Cancer Institute Monographs. 1985;67:65-74.
24 Shapiro S, Venet W, Strax P, Venet L. Current results of the breast cancer screening randomized trial: The health insurance plan (HIP) of greater New York study. In: Day NE, Miller AB, eds. Screening for breast cancer. Toronto: Hans Huber; 1988:3–15.
25 Shapiro S, Venet W, Strax P, Venet L. Periodic screening for breast cancer: the Health Insurance Plan project and its sequelae, 1963-1986. Baltimore and London: The Johns Hopkins University Press; 1988.
26 Shapiro S. The status of breast cancer screening: a quarter of a century of research. World-J-Surg. 1989;13:9-18. [pmid: 2658359].
27 Shapiro S. Determining the efficacy of breast cancer screening. Cancer. 1989;63(10):1873-1880. [pmid: 2649218].
28 Shapiro S, Strax P, Venet L. Evaluation of periodic breast cancer screening with mammography: methodology and early observations. CA: A Cancer Journal for Clinicians. 1990;40(2):111-125. [pmid: 2106369].
29 Shapiro S. A dissent from Dr. Schmidt's appraisal of evidence on breast cancer screening. Journal of Clinical Epidemiology. 1990;43(3):227-234. [pmid: 2107281].
30 Shapiro S. Screening: assessment of current studies. Cancer. 1994;74:231-238. [pmid: 8004592].
31 Shapiro S. Periodic screening for breast cancer: the HIP Randomized Controlled Trial. Health Insurance Plan. Journal of the National Cancer Institute. Monographs. 1997;22:27-30. [pmid: 9709271].
32 Smart C R. Highlights of the evidence of benefit for women aged 40–49 years from the 14-year follow-up of the Breast Cancer Detection Demonstration Project. Cancer. 1994;74(1 Suppl):296-300. [pmid: 8004600].
33 Strax P, Venet L, Shapiro S, Gross S. Mammography and clinical examination in mass screening for cancer of the breast. Cancer. 1967;20(12):2184-2188. [pmid: 6073895].
34 Strax P, Venet L, Shapiro S. Mass screening in mammary cancer. Cancer. 1969;23(4):875-878. [pmid: 5775978].
35 Strax P, Venet L, Shapiro S, Gross S, Venet W. Breast cancer found on repetitive examination in mass screening. Archives of Environmental Health. 1970;20(6):758-763. [pmid: 4315318].
36 Strax P, Venet L, Shapiro S. Value of mammography in reduction of mortality from breast cancer in mass screening. American Journal of Roentgenology, Radium Therapy & Nuclear Medicine. 1973;117(3):686-689.
37 Strax P. Physical methods in breast cancer diagnosis. Israel Journal of Medical Sciences. 1981;17(910):847-853. [pmid: 7309471].
38 Strax P. Advances in detection of early breast cancer. Cancer Detection and Prevention. 1983;6(45):409-414. [pmid: 6652635].
39 Strax P. Mass screening for control of breast cancer. Cancer. 1984;53(3 Suppl):665-670. [pmid: 6692270].
40 Strax P. The Health Insurance Plan of New York study: clinical aspects. Cancer. 1989;64(Suppl):2641-2644. [pmid: 2819673].
41 Thomas L B, Ackerman L V, McDivitt R W, Hanson T A S, Hankey B F, Prorok P C. Report of NCI ad hoc pathology working group to review the gross and microscopic findings of breast cancer cases in the HIP study. Journal of the National Cancer Institute. 1977;59(2):496-541.
42 Vachieri C. Breast cancer screening: evidence of benefit for women 40–49. Journal of the National Cancer Institute. 1988;80:1090-1092.
43 Walter S D, Stitt L W. Evaluating the survival of cancer cases detected by screening. Statistics in Medicine. 1987;6:885-900. [pmid: 3438615].
44 Shapiro S. Is meta-analysis a valid approach to the evaluation of small effects in observational studies?. J Clin Epidemiol. 1997;50(3):223-229. [pmid: 9120519].
45 Bailar J C 3rd, MacMahon B. Randomization in the Canadian National Breast Screening Study: a review for evidence of subversion. Can Med Assoc J. 1997;156(2):193-199. [pmid: 9012720]. [pmcid: 1226907].
46 Baines C J. Impediments to recruitment in the Canadian Breast Screening Study: response and resolution. Control Clin Trials. 1984;5(2):129-140. [pmid: 6744885].
47 Baines C J. The Canadian National Breast Screening Stucdy: current status. Developmental Oncology. 1987;51:25-27.
48 Baines C J. The Canadian National Breast Screening Study: responses to controversy. Womens Health Issues. 1992;2(4):206-211. [pmid: 1486284].
49 Baines C J. The Canadian National Breast Screening Study: a perspective on criticisms. Ann Intern Med. 1994;120:326-334. [pmid: 8291826].
50 Baines C J. A different view on what is known about breast screening and the Canadian National Breast Screening Study. Cancer. 1994;74(4):1207-1211. [pmid: 8055439].
51 Baines CJ. Screening mammography in women 40 to 49 years of age: no. Important Adv Oncol. 1995:243–251.
52 Baines C J. The Canadian National Breast Screening Study. Why? What next? And so what?. [Review] [42 refs]. Cancer. 1995;76(10 Suppl):2107-2112. [pmid: 8635008].
53 Baines C J. Reflections on breast self-examination. Journal of the National Cancer Institute. 1997;89(5):339-340. [pmid: 9060953].
54 Baines C J. NBSS: changes were made, suspicious changes were not. [letter; comment]. Can Med Assoc J. 1997;157(3):248-250. [pmid: 9269191]. [pmcid: 1227817].
55 Baines C J. Screening for breast cancer: how useful are clinical breast examinations?. Journal of the National Cancer Institute. 2000;92(12):958-959. [pmid: 10861299].
56 Baines C J, Christen A, SImard A, Wall C, Dean D, Duncan L. The National Breast Screening Study: pre-recruitment sources of awareness in participants. Canadian Joural of Public Health. 1989;80(3):221-225.
57 Baines C J, Dayan R. A tangled web: factors likely to affect the efficacy of screening mammography [commentary]. J Natl Cancer Inst. 1999;91(10):833-838. [pmid: 10340902].
58 Baines C J, McFarlane D V, Miller A B. Sensitivity and specificity of first screen mammography in 15 NBSS centres. Can Assoc Radiol J. 1988;39:273-276. [pmid: 3060219].
59 Baines C J, McFarlane D V, Miller A B. The role of the reference radiologist. Estimates of inter-observer agreement and potential delay in cancer detection in the national breast screening study. Invest Radiol. 1990;25(9):971-976. [pmid: 2211054].
60 Baines C J, McFarlane D V, Wall C. Audit procedures in the National Breast Screening Study: mammography interpretation. Can Assoc Radiol J. 1986;37(4):256-260. [pmid: 2950109].
61 Baines CJ, Miller AB. Mammography versus clinical examination of the breasts. J Natl Cancer Inst Monogr. 1997(22):125–129.
62 Baines C J, Miller A B, Bassett A A. Physical examination. Its role as a single screening modality in the Canadian National Breast Screening Study. Cancer. 1989;63(9):1816-1822. [pmid: 2702588].
63 Baines C J, Miller A B, Kopans D B, et al. Canadian National Breast Screening Study: assessment of technical quality by external review. AJR Am J Roentgenol. 1990;155(4):743-747. discussion 748–749. [pmid: 2119103].
64 Baines C J, Miller A B, Wall C, et al. Sensitivity and specificity of first screen mammography in the Canadian National Breast Screening Study: a preliminary report from five centers. Radiology. 1986;160:295-298. [pmid: 3523590].
65 Baines C J, To T. Changes in breast self-examination behavior achieved by 89,835 participants in the Canadian National Breast Screening Study. Cancer. 1990;66(3):570-576. [pmid: 2194648].
66 Baines C J, To T, Wall C. Women's attitudes to screening after participation in the National Breast Breast Screening Study. A questionnaire survey. Cancer. 1990;65(7):1663-1669. [pmid: 2311075].
67 Baines C J, Vidmar M, McKeown-Eyssen G, Tibshirani R. Impact of menstrual phase on false-negative mammograms in the Canadian National Breast Screening Study. Cancer. 1997;80:720-724. [pmid: 9264355].
68 Baines C J, Wall C, Risch H A, Kuin J K, Fan I J. Changes in breast self-examination behavior in a cohort of 8214 women in the Canadian National Breast Screening Study. Cancer. 1986;57(6):1209-1216. [pmid: 3510711].
69 Basinski A S. The Canadian National Breast Screening Study: opportunity to rethink. Can Med Assoc J. 1992;147(10):1431-1434. [pmid: 1307231]. [pmcid: 1336539].
70 Boyd N F. The review of randomization in the Canadian National Breast Screening Study. Is the debate over? [editorial; comment]. Can Med Assoc J. 1997;156(2):207-209. [pmid: 9012723]. [pmcid: 1226910].
71 Boyd N F, Byng J W, Jong R A, et al. Quantitative classification of mammographic densities and breast cancer risk: results from the Canadian National Breast Screening Study. Journal of the National Cancer Institute. 1995;87(9):670-675. [pmid: 7752271].
72 Boyd N F, Jensen H M, Cooke G, Han H L. Relationship between mammographic and histological risk factors for breast cancer. Journal of the National Cancer Institute. 1992;87(9):1170-1179. [pmid: 1635085].
73 Boyd N F, Jensen H M, Cooke G, Han H L, Lockwood G A, Miller A B. Mammographic densities and the prevalence and incidence of histological types of benign breast disease. Reference Pathologists of the Canadian National Breast Screening Study. Eur J Cancer Prev. 2000;9(1):15-24. [pmid: 10777006].
74 Boyd N F, Jong R A, Yaffe M J, Tritchler D, Lockwood G, Zylak C J. A critical appraisal of the Canadian National Breast Cancer Screening Study [editorial]. Radiology. 1993;189:661-663. [pmid: 8234686].
75 Boyd N F, Lockwood G A, Martin L J, et al. Mammographic densities and risk of breast cancer among subjects with a family history of this disease. Journal of the National Cancer Institute. 1999;91(16):1404-1408. [pmid: 10451446].
76 Boyd N F, Wolfson C, Moskowitz M, et al. Observer variation in the interpretation of xeromammograms. Journal of the National Cancer Institute. 1982;68:357-363. [pmid: 7038244].
77 Bryant H. The review of randomization in the Canadian National Breast Screening Study. What does the verdict mean for clinicians? [editorial; comment]. Can Med Assoc J. 1997;156(2):213-215. [pmid: 9012724]. [pmcid: 1226911].
78 Burhenne L J, Burhenne H J. The Canadian National Breast Screening Study: a Canadian critique. AJR Am J Roentgenol. 1993;161:761-763. [pmid: 8372753].
79 Busetti M C, Miller A B, To T, Rohan T E. Risk factors for breast cancer mortality among the National Breast Screening Study of Canada participants. Cancer Detect Prev. 1996;20(2):122-129. [pmid: 8706037].
80 Byng J W, Yaffe M J, Lockwood G A, Little L E, Tritchler D L, Boyd N F. Automated analysis of mammographic densities and breast carcinoma risk. Cancer. 1997;80(1):66-74. [pmid: 9210710].
81 Cohen M M, Kaufert P A, MacWilliam L, Tate R B. Using an alternative data source to examine randomization in the Canadian National Breast Screening Study. J Clin Epidemiol. 1996;49(9):1039-1044. [pmid: 8780614].
82 Deschamps M, Band P R, Coldman A J, Hislop T G, Longley D J. Clinical determinants of mammographic dysplasia patterns. Cancer Detect Prev. 1996;20(6):610-619. [pmid: 8939347].
83 Goel V, Cohen M M, Kaufert P, MacWilliam L. Assessing the extent of contamination in the Canadian National Breast Screening Study. Am J Prev Med. 1998;15(3):206-211. [pmid: 9791638].
84 Goldman B. When considering attacks against the National Breast Screening Study, consider the sources. Can Med Assoc J. 1993;148(3):427-428. [pmid: 8439915]. [pmcid: 1490483].
85 Gray C. US resistance to Canadian Mammogram study not only about data. Can Med Assoc J. 1993;148(4):622-623. [pmid: 8431826]. [pmcid: 1490507].
86 Haiart D C, Henderson J. A comparison of interpretation of screening mammograms by a radiographer, a doctor and a radiologist: results and implications. Br J Clin Pract. 1991;45(1):43-45. [pmid: 1931542].
87 Harvey B J, Miller A B, Baines C J, Corey P N. Effect of breast self-examination techniques on the risk of death from breast cancer. Can Med Assoc J. 1997;157(9):1205-1212. [pmid: 9361639]. [pmcid: 1228347].
88 Holowaty P H, Miller A B, Baines C J, Risch H. Canadian National Breast Screening Study: first screen results as predictors of future breast cancer risk. Cancer Epidemiology, Biomarkers & Prevention. 1993;2:11-19.
89 Howe G, J. SG, B. SRMMA. Estimated benefits and risks of screening for breast cancer. Can-Med-Assoc-J. 1981;124:399–403.
90 Kopans DB. Screening mammography in women 40 to 49 years of age: yes. Important Adv Oncol. 1995:231–241.
91 Kopans D B. Canadian National Breast Screening Study [letter; comment]. Lancet. 1997;350(9080):810. [pmid: 9298019].
92 Kopans D B, Feig S A. The Canadian National Breast Screening Study: a critical review. AJR Am J Roentgenol. 1993;161:755-760. [pmid: 8372752].
93 Kopans D B, Halpern E, Hulka C A. Mammography screening for breast cancer. Reply to the commentaries. Cancer. 1994;74(4):1212-1216. [pmid: 8055440].
94 Kopans D B, Halpern E, Hulka C A. Statistical power in breast cancer screening trials and mortality reduction among women 40–49 years of age with particular emphasis on the National Breast Screening Study of Canada. Cancer. 1994;74(4):1196-1203. [pmid: 8055437].
95 Kotwall C A, Mahoney L J. Screening mammography: interpretation of the data. Surg Oncol. 1994;3(5):305-307. [pmid: 7889224].
96 Mettlin C J, Smart C R. The Canadian National Breast Screening Study. An appraisal and implications for early detection policy. Cancer. 1993;72(4 Suppl):1461-1465. [pmid: 8339239].
97 Miller A B. Mammography in mass screening [letter]. Eur J Cancer. 1980;16(5):737-739. [pmid: 7389799].
98 Miller AB. Routine mammography and the National Breast Screening Study. Can Med Assoc J. 1984;130(3):269–260, 273.
99 Miller AB. The Canadian national breast screening study. In: N.E. D, Miller AB, eds. Screening for breast cancer. Toronto: Hans Huber; 1988:51–58.
100 Miller A B. More on breast cancer screening. Cancer Forum. 1988;12:1-3.
101 Miller A B. Re: “Author of Canadian breast cancer study retracts warning” [letter]. Journal of the National Cancer Institute. 1992;84(17):1365-1371. [pmid: 1495109].
102 Miller A B. Canadian National Breast Screening Study: public health implications. Can J Public Health. 1993;84:14-16. [pmid: 8500048].
103 Miller A B. The costs and benefits of breast cancer screening. Am J Prev Med. 1993;9(3):175-180. [pmid: 8347369].
104 Miller A B. Canadian national breast screening study [correction]. Can Med Assoc J. 1993;148:718.
105 Miller A B. Re: May we agree to disagree, or how do we develop guidelines for breast cancer screening in women? [letter]. Journal of the National Cancer Institute. 1994;86(22):1729-1731. [pmid: 7966404].
106 Miller AB. The Canadian National Breast Cancer Screening Study: update on breast cancer mortality. NIH Consensus Development Conference on Breast Cancer Screening for Women Ages 40–49; 1997:51–53.
107 Miller A b. Canadian National Breast Screening Study: response [letter]. Can Med Assoc J. 1993;149(10):1374-1375. [pmid: 8221414]. [pmcid: 1485893].
108 Miller A B, Baines C J, Sickles E A. Canadian national breast screening study. AJR Am J Roentgenol. 1990;155:1133-1134. [pmid: 2120947].
109 Miller AB, Baines CJ, T. T, C. W. Screening mammography re-evaluated [letter]. Lancet. 2000;355(9205):747.
110 Miller AB, Baines CJ, To T. The Canadian national breast cancer screening study. In: Miller AB, Chamberlain J, Day NE, eds. Cancer Screening. Cambridge: Cambridge University Press; 1991:45–55.
111 Miller A B, Baines C J, To T, Wall C. Canadian National Breast Screening Study: 2. Breast cancer detection and death rates among women aged 50 to 59 years [published erratum appears in CMAJ 1993 Mar 1;148(5):718]. Can Med Assoc J. 1992;147:1477-1488. [pmid: 1423088]. [pmcid: 1336544].
112 Miller A B, Baines C J, To T, Wall C. Canadian National Breast Screening Study: 1. Breast cancer detection and death rates among women aged 40 to 49 years [published erratum appears in CMAJ 1993 Mar 1;148(5):718]. Can Med Assoc J. 1992;147:1459-1476. [pmid: 1423087]. [pmcid: 1336543].
113 Miller A B, Baines C J, Turnbull C. The role of the nurse-examiner in the National Breast Screening Study. Can J Public Health. 1991;82(3):162-167. [pmid: 1884309].
114 Miller A B, Baines C J, Wall C. Re: Canadian National Breast Screening Study-2: 13-year results of a randomized trial in women aged 50–59 years [letter; reply]. Journal of the National Cancer Institute. 2001;93(5):396-397. [pmid: 11238702].
115 Miller A B, Howe G R, Wall C. The National Study of Breast Cancer Screening Protocol for a Canadian Randomized Controlled trial of screening for breast cancer in women. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1981;4:227-258. [pmid: 6802546].
116 Miller A B, To T, Baines C J, Wall C. The Canadian National Breast Screening Study: update on breast cancer mortality. J Natl Cancer Inst Monogr. 1997;22:37-41. [pmid: 9709273].
117 Miller A B, To T, Baines C J, Wall C. The Canadian National Breast Cancer Screening Study-2: 13-year results of a randomized trial in women aged 50–59 years. J Natl Cancer Inst. 2000;92(18):1490-1499. [pmid: 10995804].
118 Miller A B, To T, Baines C J, Wall C. The Canadian National Breast Cancer Screening Study - I, breast cancer mortality after 11–16 years of follow-up in women age 40–49. Ann Intern Med. 2002;137:305-312. [pmid: 12204013].
119 Narod S A. On being the right size: a reappraisal of mammography trials in Canada and Sweden [letter]. Lancet. 1997;349(9068):1846. [pmid: 9269247].
120 Narod S A. Re: Canadian national breast screening study-2: 13-year results of a randomized trial in women aged 50–59 years [letter]. Journal of the National Cancer Institute. 2001;93(5):396-397. [pmid: 11238702].
121 Paci E, Alexander FE. Study design of randomized controlled clinical trials of breast cancer screening. J Natl Cancer Inst Monogr. 1997(22):21–25.
122 Simard A, Paquette L, Baillargeon J, Falardeau M. Perception of cancer detection and early treatment in a population participating in the National Breast Screening Study in Canada. Can J Public Health. 1989;80(3):226-227. [pmid: 2743248].
123 Tarone R. The excess of patients with advanced breast cancer in young women screened with mammography in the Canadian National Breast Screening Study. Cancer. 1995;75:997-1003. [pmid: 7842421].
124 Sickles E A, Kopans D B. Deficiencies in the analysis of breast cancer screening data [editorial; comment]. Journal of the National Cancer Institute. 1993;85(20):1621-1624. [pmid: 8179650].
125 Alexander F E, Roberts M M, Huggins A, Muir B B. Use of risk factors to allocate schedules for breast cancer screening. Journal of Epidemiology & Community Health. 1988;42(2):193-199. [pmid: 3221171]. [pmcid: 1052716].
126 Alexander F E. Estimation of sojourn time distributions and false negative rates in screening programmes which use two modalities. Stat-Med. 1989;8:743-755. [pmid: 2664960].
127 Alexander F, Roberts M M, Lutz W, Hepburn W. Randomisation by cluster and the problem of social class bias. Journal of Epidemiology and Community Health. 1989;43(1):29-36. [pmid: 2592888]. [pmcid: 1052787].
128 Alexander F E, Anderson T J, Donnan P, Prescott R J. Edinburgh trial of screening for breast cancer [letter]. Lancet. 1990;335(8695):969. [pmid: 1970036].
129 Alexander F E, Anderson T J, Brown H K, et al. The Edinburgh randomised trial of breast cancer screening: results after 10 years of follow-up. British Journal of Cancer. 1994;70(3):542-548. [pmid: 8080744].
130 Alexander F E. The Edinburgh Randomized Trial of Breast Cancer Screening. J Natl Cancer Inst Monogr. 1997;22:31-35. [pmid: 9709272].
131 Alexander F E, Anderson T J, Hubbard A L. Screening status in relation to biological and chronological characteristics of breast cancers: a cross sectional survey. Journal of Medical Screening. 1997;4(3):152-157. [pmid: 9368873].
132 Alexander F E, Brown H K, Prescott R J. Improved classification of socio-economic status expalins differences in all-cause mortality in the randomised trial of breast cancer screening. Journal of Epidemiology and Biostatistics. 1998;3(2):219-224.
133 Alexander F E, Anderson T J, Brown H K, et al. 14 years of follow-up from the Edinburgh randomised trial of breast-cancer screening. Lancet. 1999;353(9168):1903-1908. [pmid: 10371567].
134 Anderson T J, Lamb J, Alexander F, Lutz W, Chetty U, Forrest A P. Comparative pathology of prevalent and incident cancers detected by breast screening. Edinburgh Breast Screening Project. Lancet. 1986;1(8480):519-526. [pmid: 2869259].
135 Anderson T J, Lamb J, Donnan P, et al. Comparative pathology of breast cancer in a randomised trial of screening. British Journal of Cancer. 1991;64(1):108-113. [pmid: 1854609].
136 Anonymous 16-year mortality from breast cancer in the UK Trial of Early Detection of Breast Cancer. Lancet. 1999;353(9168):1909–1914.
137 Benjamin D J. The efficacy of surgical treatment of breast cancer. Medical Hypotheses. 1996;47(5):389-397. [pmid: 8951803].
138 Roberts M M, Alexander F E, Anderson T J, et al. The Edinburgh randomised trial of screening for breast cancer: Description of method. Br-J-Cancer. 1984;50:1-6. [pmid: 6743506].
139 Roberts M M, Alexander F E, Anderson T J, et al. Edinburgh trial of screening for breast cancer: mortality at seven years. Lancet. 1990;335(8684):241-246. [pmid: 1967717].
140 Black W C, Haggstrom D A, Welch H G. All-cause mortality in randomized trials of cancer screening. Journal of the National Cancer Institute. 2002;94(3):167-173. [pmid: 11830606].
141 Andersson I, Andren L, Hildell J, Linell F, Ljungqvist U, Pettersson H. Breast cancer screening with mammography: a population-based, randomized trial with mammography as the only screening mode. Radiology. 1979;132:273-276. [pmid: 461778].
142 Andersson I. Radiographic screening for breast carcinoma. I. Program and primary findings in 45–69 year old women. Acta-Radiol, Ser-Diagn. 1981;22:185-194.
143 Andersson I. Radiographic screening for breast carcinoma. II. Prognostic considerations on the basis of a short-term followup. Acta-Radiol, Ser-Diagn. 1981;22(3A):227-233.
144 Andersson I. Radiographic screening for breast carcinoma. III. Appearance of carcinoma and number of projections to be used. Acta-Radiol, Ser-Diagn. 1981;22:407-420.
145 Andersson I. Breast cancer screening in Malmo. Recent Results in Cancer Research. 1984;90:114-116. [pmid: 6366950].
146 Andersson I. Detection bias in mammographic screening for breast carcinoma. Recent Results in Cancer Research. 1984;90:164-165. [pmid: 6701373].
147 Andersson I, Janzon L, Sigfusson B F. Mammographic breast cancer screening--a randomized trial in Malmo, Sweden. Maturitas. 1985;7:21-29. [pmid: 2991708].
148 Andersson I, Sigfusson B F. Screening for breast cancer in Malmo: a randomized trial. Recent Results in Cancer Research. 1987;105:62-66. [pmid: 3296056].
149 Andersson I, Aspegren K, Janzon L, et al. Mammographic screening and mortality from breast cancer: the Malmo mammographic screening trial. BMJ. 1988;297:943-948. [pmid: 3142562]. [pmcid: 1834636].
150 Andersson I, Aspegren K, Janzon L, et al. Malmo mammographic screening trial. BMJ. 1989;298:49. [pmid: 2492860].
151 Andersson I, Nystrom L. Mammography screening [letter]. Journal of the National Cancer Institute. 1995;87(16):1263-1264. [pmid: 7563176].
152 Andersson I, Janzon L. Reduced breast cancer mortality in women under age 50: updated results from the Malmo Mammographic Screening Program. Journal of the National Cancer Institute. Monographs. 1997;22:63-67. [pmid: 9709278].
153 Berglund G, Nilsson P, Eriksson K F, et al. Long-term outcome of the Malmo preventive project: mortality and cardiovascular morbidity. Journal of Internal Medicine. 2000;247(1):19-29. [pmid: 10672127].
154 Gullberg B, Andersson I, Janzon L, Ranstam J. Screening mammography [letter]. Lancet. 1991;337(8735):244. [pmid: 1670878].
155 Ikeda D M, Andersson I, Wattsgard C, Janzon L, Linell F. Interval carcinomas in the Malmo Mammographic Screening Trial: radiographic appearance and prognostic considerations. AJR. American Journal of Roentgenology. 1992;159(2):287-294. [pmid: 1632342].
156 Janzon L, Andersson I. Malmo mammographic screening trial. Cancer screening: Cambridge University Press; 1991:37–44.
157 Ringberg A, Andersson I, Aspegren K, Linell F. Breast carcinoma in situ in 167 women--incidence, mode of presentation, therapy and follow-up. European Journal of Surgical Oncology. 1991;17(5):466-476. [pmid: 1657650].
158 Tabar L, Duffy S. Malmo mammographic screening trial. BMJ. 1989;298:48-49. [pmid: 2492859].
159 Nystrom L, Andersson I, Bjurstam N, Frisell J, Nordenskjold B, Rutqvist L E. Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. 2002;359:909-919. [pmid: 11918907].
160 Frisell J, Glas U, Hellstrom L, Somell A. Randomized mammographic screening for breast cancer in Stockholm. Design, first round results and comparisons. Breast Cancer Research & Treatment. 1986;8:45-54. [pmid: 3790749].
161 Frisell J, Eklund G, Hellstrom L, Somell A. Analysis of interval breast carcinomas in a randomized screening trial in Stockholm. Breast Cancer Research & Treatment. 1987;9:219-225. [pmid: 3663958].
162 Frisell J, Eklund G, Hellstrom L, Glas U, Somell A. The Stockholm breast cancer screening trial - 5-year results and stage at discovery. Breast Cancer Research and Treatment. 1989;13:79-87. [pmid: 2706329].
163 Frisell J, Eklund G, Nilsson R, Hellstrom L, Somell A. Additional value of fine-needle aspiration biopsy in a mammographic screening trial. British Journal of Surgery. 1989;76:840-843. [pmid: 2765842].
164 Frisell J, Eklund G, Hellstrom L, Lidbrink E, Rutqvist L E, Somell A. Randomized study of mammography screening--preliminary report on mortality in the Stockholm trial. Breast Cancer Research & Treatment. 1991;18:49-56. [pmid: 1854979].
165 Frisell J, von Rosen A, Wiege M, Nilsson B, Goldman S. Interval cancer and survival in a randomized breast cancer screening trial in Stockholm. Breast Cancer Research & Treatment. 1992;24:11-16. [pmid: 1463867].
166 Frisell J, Lidbrink E, Hellstrom L, Rutqvist L E. Followup after 11 years--update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Research & Treatment. 1997;45:263-270. [pmid: 9386870].
167 Frisell J, Lidbrink E. The Stockholm Mammographic Screening Trial: Risks and benefits in age group 40–49 years. Journal of the National Cancer Institute. Monographs. 1997;22:49-51. [pmid: 9709275].
168 Lidbrink E, Frisell J, Brandberg Y, Rosendahl I, Rutqvist L E. Nonattendance in the Stockholm mammography screening trial: relative mortality and reasons for nonattendance. Breast Cancer Research & Treatment. 1995;35:267-275. [pmid: 7579497].
169 Lidbrink E, Elfving J, Frisell J, Jonsson E. Neglected aspects of false positive findings of mammography in breast cancer screening: analysis of false positive cases from the Stockholm trial. BMJ. 1996;312(7026):273-276. [pmid: 8611781]. [pmcid: 2349888].
170 von Rosen A, Frisell J, Glas U, Hellstrom L, Nilsson R, SKoog L. Non-palpable invasive breast carcinomas from the Stockholm screening project. Acta Oncologica. 1989;28(1):23-27. [pmid: 2706131].
171 von Rosen A, Frisell J, Nilsson R, Wiege M, Auer G. Histopathological and cytochemical characteristics of interval breast carcinomas from the Stockholm Mammography Screening Project. Acta Oncologica. 1992;31(4):399-402. [pmid: 1321649].
172 Nystrom L, Rutqvist LE, Wall S, et al. Breast cancer screening with mammography: overview of Swedish randomised trials [published erratum appears in Lancet 1993 Nov 27;342(8883):1372]. Lancet. 1993;341:(8851):973–978.
173 Holmberg L, Baron J A, Byers T, et al. Alcohol intake and breast cancer risk: effect of exposure from 15 years of age. Cancer Epidemiology, Biomarkers and Prevention. 1995;4(8):843-847.
174 Holmberg L. Evaluation of breast cancer screening programs. Cancer. 1993;72(4 Suppl):1433-1436. [pmid: 8339235].
175 Holmberg L, Adami H O, Persson I, Lundstrom T, Tabar L. Demands on surgical inpatient services after mass mammographic screening. British Medical Journal. 1986;293:779-782. [pmid: 3094655]. [pmcid: 1341570].
176 Holmberg L H, Tabar L, Adami H O, Bergstrom R. Survival in breast cancer diagnosed between mammographic screening examinations. Lancet. 1986;2:27-30. [pmid: 2873324].
177 Hatschek T, Grontoft O, Carstensen J, Fagerberg G. Histopathological features and prognosis after fifteen years follow-up in a randomized population based trial of mammography screening [abstract]. Proc-Annu-Meet-Am-Soc-Clin-Oncol. 1995;14:Abs. A137.
178 Hatschek T, Grontoft O, Fagerberg G, et al. Cytometric and histopathologic features of tumors detected in a randomized mammography screening program: correlation and relative prognostic influence. Breast Cancer Research & Treatment. 1990;15:149-160. [pmid: 2196942].
179 Hatschek T, Carstensen J, Fagerberg G, Stal O, Grontoft O, Nordenskjold B. Influence of S-phase fraction on metastic pattern and post-recurrence survival in a randomized mammography screening trial. Breast Cancer Research and Treatment. 1989;14(3):321-327. [pmid: 2611405].
180 Forrest A P, Alexander F E. Re: Quantitative interpretation of age-specific mortality reductions from the Swedish breast cancer screening trials. Journal of the National Cancer Institute. 1996;88(1):52-55. [pmid: 8847728].
181 Hatschek T, Fagerberg G, Stal O, et al. Cytometric characterization and clinical course of breast cancer diagnosed in a population-based screening program. Cancer. 1989;64:1074-1081. [pmid: 2758384].
182 Field S, Michell M J, Wallis M G, Wilson A R. What should be done about interval breast cancers? [editorial]. BMJ. 1995;310(6974):224-226. [pmid: 7866124]. [pmcid: 2548620].
183 Fagerberg CJG, Tabar L. The results of periodic one-view mammography screening in a randomized, controlled trial in Sweden. In: Day NE, Miller AB, eds. Screening for breast cancer. Toronto: Hans Huber; 1988:33–38.
184 Fagerberg G. Experience from randomized controlled breast screening with mammography in Ostergotland county, Sweden: a preliminary report. Recent Results in Cancer Research. 1984;90:117. [pmid: 6366951].
185 Fagerberg G, Baldetorp L, Grontoft O, Lundstrom B, Manson J C, Nordenskjold B. Effects of repeated mammographic screening on breast cancer stage distribution. Results from a randomised study of 92 934 women in a Swedish county. Acta Radiologica - Oncology. 1985;24:465-473. [pmid: 3006435].
186 Ellman R. Breast cancer screening [editorial]. Journal of the Royal Society of Medicine. 1987;80:665-666. [pmid: 3694609]. [pmcid: 1291082].
187 Duffy S W, Chen H H, Tabar L, Fagerberg G, Paci E. Sojourn time, sensitivity and positive predictive value of mammography screening for breast cancer in women aged 40–49. International Journal of Epidemiology. 1996;25:1139-1145. [pmid: 9027517].
188 Duffy S W, Day N E, Tabar L, Chen H H, Smith T C. Markov models of breast tumor progression: some age-specific results. Journal of the National Cancer Institute. Monographs. 1997;22:93-97. [pmid: 9709283].
189 Duffy S W, Chen H H, Tabar L, Day N E. Estimation of mean sojourn time in breast cancer screening using a Markov chain model of both entry to and exit from the preclinical detectable phase. Statistics in Medicine. 1995;14:1531-1543. [pmid: 7481190].
190 Duffy S W, South M C, Day N E. Cluster randomization in large public health trials: the importance of antecedent data. Statistics in Medicine. 1992;11(3):307-316. [pmid: 1609172].
191 Duffy S W, Tabar L, Fagerberg G, et al. Breast screening, prognostic factors and survival - results from the Swedish two county study. British Journal of Cancer. 1991;64:1133-1138. [pmid: 1764377].
192 de Koning H, Boer R, Warmerdam P, Beemsterboer P M, van der Maas P. Re: Quantitative interpretation of age-specific mortality reductions from the Swedish breast cancer screening trials [letter]. Journal of the National Cancer Institute. 1996;88(1):52-55. [pmid: 8847728].
193 Duffy S, Tabar L, Krusemo UB, Day N. Randomization by cluster in the Swedish two-county trial: recent results from Kopparberg and implications for interpretation [abstract]. Paper presented at: Nordic Cancer Union, 1989; Stockholm.
194 de Koning H J, Boer R, Warmerdam P G, Beemsterboer P M, van der Maas P J. Quantitative interpretation of age-specific mortality reductions from the Swedish breast cancer-screening trials. Journal of the National Cancer Institute. 1995;87(16):1217-1223. [pmid: 7563167].
195 Day NE. Surrogate measures in the design of breast screening trials. In: Miller AB, Chamberlain J, Day NE, eds. Cancer Screening. Cambridge: Cambridge University Press; 1991:391–403.
196 Day N E, Williams D R, Khaw K T. Breast cancer screening programmes: the development of a monitoring and evaluation system. British Journal of Cancer. 1989;59(6):954-958. [pmid: 2736233].
197 Chen H H, Tabar L, Fagerberg G, Duffy S W. Effect of breast cancer screening after age 65. Journal of Medical Screening. 1995;2:10-14. [pmid: 7497137].
198 Bergkvist L, Tabar L, Bergstrom R, Adami H O. Epidemiologic determinants of the mammographic parenchymal pattern. A population-based study within a mammographic screening program. American Journal of Epidemiology. 1987;126(6):1075-1081. [pmid: 3687919].
199 Arnesson L G, Vitak B, Manson J C, Fagerberg G, Smeds S. Diagnostic outcome of repeated mammography screening. World Journal of Surgery. 1995;19(3):372-377. [pmid: 7638991].
200 Arnesson L G, Smeds S, Fagerberg G. Recurrence-free survival in patients with small breast cancers. An analysis of cancers 10 mm or less detected clinically and by screening. Eur. J. Surg. Acta Chir. 1994;160:271-276.
201 Arnesson L G, Smeds S, Hatschek T, Nordenskjold B, Fagerberg G. Hormone receptors, ploidy and proliferation rate in breast cancers up to 10 mm. European Journal of Surgery. 1992;18(3):235-240.
202 Arnesson L G, Smeds S, Fagerberg G, Grontoft O. Follow-up of two treatment modalities for ductal cancer in situ of the breast. British Journal of Surgery. 1989;76(7):672-675. [pmid: 2548651].
203 Arnesson L, Fagerberg G, Månson J, et al. Mammography screening: What is the diagnostic outcome in prevalent and repeated screening by an experienced team?. Annales Chirurgiae et Gynaecologiae. 1989;78:33-33.
204 Arnesson L G, Fagerberg G, Grontoft O, Lundstrom B. Surgical biopsy of non-palpable mammary lesions. Technique and results. Acta Chirurgica Scandinavica. 1986;152:97-101. [pmid: 3513472].
205 Anonymous. Summary of the discussion on breast cancer screening. In: Miller AB, Chamberlain J, Day NE, Hakama M, Prorok PC, eds. Cancer Screening. Cambridge: Cambridge University Press; 1991:78–80.
206 Andersson I, Fagerberg G, Lundgren B, Tabar L. Breast cancer screening in Sweden. The single modality approach. Radiologe. 1980;20:608-611. [pmid: 7208897].
207 Lindgren A. Autopsy and cause of death in randomized mammography studies. Quality Assurance in Health Care. 1993;5(4):303-307. [pmid: 8018887].
208 Lundstrom B, Fagerberg G. Clinical problems in relation to breast cancer screening with mammography. A preliminary report. Acta Chir Scand Supp. 1984;519:61-63.
209 Nixon R, Prevost T C, Duffy S W, Tabar L, Vitak B, Chen H H. Some random-effects models for the analysis of matched-cluster randomised trials: application to the Swedish two-county trial of breast-cancer screening. Journal of Epidemiology & Biostatistics. 2000;5(6):349-358. [pmid: 11234739].
210 Smart C R. Mammographic screening: efficacy and guidelines. Current Opinion in Radiology. 1992;4(5):108-117. [pmid: 1388042].
211 Tabar L, Gad A, Akerlund E, Fors B, Fagerberg G, Baldetorp L. Screening for breast cancer in Sweden. A randomised controlled trial. In: Logan WW, Muntz EP, eds. Reduced dose mammography. New York: Masson; 1979:417–414.
212 Tabar L, Gad A. Screening for breast cancer: the Swedish trial. Radiology. 1981;138:219-222. [pmid: 7005939].
213 Tabar L, Akerlund E, Gad A. Five-year experience with sinle-view mammography randomized controlled screening in Sweden. Recent Results in Cancer Research. 1984;90:105-113. [pmid: 6366948].
214 Tabar L, Fagerberg CJ, Gad A, et al. Reduction in mortality from breast cancer after mass screening with mammography. Randomised trial from the Breast Cancer Screening Working Group of the Swedish National Board of Health and Welfare. Lancet. 1985;1.
215 Tabar L, Gad A, Holmberg L, Ljungquist U. Significant reduction in advanced breast cancer. Results of the first seven years of mammography screening in Kopparberg, Sweden. Diagnostic Imaging in Clinical Medicine. 1985;54:158-164. [pmid: 3896614].
216 Tabar L, Gad A, Homberg L, Ljungquist U. Periodic screening with one-view mammography: the effect of mortality from breast cancer in a randomised, controlled trial [abstract]. Br-J-Radiol. 1986;59:640.
217 Tabar L, Faberberg G, Day N E, Holmberg L. What is the optimum interval between mammographic screening examinations? An analysis based on the latest results of the Swedish two- county breast cancer screening trial. British Journal of Cancer. 1987;55:547-551. [pmid: 3606947].
218 Tabar L. Screening for breast cancer: an overview. Recent Results in Cancer Research. 1987;105:58-61. [pmid: 3296055].
219 Tabar L, Duffy S W, Krusemo U B. Detection method, tumour size and node metastases in breast cancers diagnosed during a trial of breast cancer screening. European Journal of Cancer & Clinical Oncology. 1987;23:959-962. [pmid: 3311769].
220 Tabar L, Fagerberg CJG, Day NE. The results of periodic one-view mammographic screening in Sweden Part 2: Evaluation of results. In: Day NE, Miller AB, eds. Screening for breast cancer. Toronto: Hans Huber; 1988:39–44.
221 Tabar L, Fagerberg G, Duffy S W, Day N E. The Swedish two county trial of mammographic screening for breast cancer: recent results and calculation of benefit. Journal of Epidemiology & Community Health. 1989;43:107-114. [pmid: 2512366]. [pmcid: 1052811].
222 Tabar L. Control of breast cancer through screening mammography. Radiology. 1990:655–656.
223 Tabar L, Duffy S W, Day N E. Screening with mammography [letter]. International Journal of Technology Assessment in Health Care. 1990;6(3):498-500. [pmid: 2228462].
224 Tabar L, Fagerberg CJG, South MC, Day NE, Duffy SW. The Swedish Two-county Trial of mammographic screening for breast cancer:recent results on mortality and tumour characteristics. In: Miller AB, Chamberlain J, Day NE, eds. Cambridge: Cambridge University Press; 1991:23–36.
225 Tabar L, Fagerberg G, Duffy S W, Day N E, Gad A, Grontoft O. Update of the Swedish two-county program of mammographic screening for breast cancer. Radiologic Clinics of North America. 1992;30:187-210. [pmid: 1732926].
226 Tabar L, Fagerberg G, Day N E, Duffy S W. The Swedish Two-county Trial of mammographic screening for breast cancer:recent results on mortality and tumour characteristics. Pathol Biol Paris. 1992;39(9):846. [pmid: 1538900].
227 Tabar L, Fagerberg G, Duffy S W, Kitchin R M. Breast cancer treatment and natural history: new insights from results of screening. Lancet. 1992;339(8790):412-414. [pmid: 1346670].
228 Tabar L, Duffy S W, Burhenne L W. New Swedish breast cancer detection results for women aged 40–49. Cancer. 1993;72:1437-1448. [pmid: 8339236].
229 Tabar L, Fagerberg G, Chen H H, et al. Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 1995;75:2507-2517. [pmid: 7736395].
230 Tabar L, Fagerberg G, Chen H H, Duffy S W, Gad A. Screening for breast cancer in women aged under 50: mode of detection, incidence, fatality, and histology. Journal of Medical Screening. 1995;2:94-98. [pmid: 7497163].
231 Tabar L, Duffy S W, Chen H H. Re: Quantitative interpretation of age-specific mortality reductions from the Swedish Breast Cancer-Screening Trials. Journal of the National Cancer Institute. 1996;88(1):52-55. [pmid: 8847728].
232 Tabar L, Fagerberg G, Chen H H, Duffy S W. Tumour developoment, histology and grade of breast cancers: prognosis and progression. International Journal of Cancer. 1996;66(4):413-419.
233 Tabar L, Chen H H, Fagerberg G, Duffy S W, Smith T C. Recent results from the Swedish Two-County Trial: the effects of age, histologic type, and mode of detection on the efficacy of breast cancer screening. Journal of the National Cancer Institute. Monographs. 1997;22:43-47. [pmid: 9709274].
234 Tabar L, Duffy S W. Criticisms of Swedish mammography trials were wrong [letter]. BMJ. 1999;319(7221):1367. [pmid: 10567156].
235 Tabar L, Duffy S W, Vitak B, Chen H H, Prevost T C. The natural history of breast carcinoma: what have we learned from screening?. Cancer. 1999;86(3):449-462. [pmid: 10430253].
236 Tabar L, Vitak B, Chen H H, Prevost T C, Duffy S W. Update of the Swedish Two-County Trial of breast cancer screening: histologic grade-specific and age-specific results. Swiss Surgery. 1999;5(5):199-204. [pmid: 10546517].
237 Tabar L, Chen H H, Duffy S W, Krusemo U B. Primary and adjuvant therapy, prognostic factors and survival in 1053 breast cancers diagnosed in a trial of mammography screening. Japanese Journal of Clinical Oncology. 1999;29:608-616. [pmid: 10721943].
238 Tabar L, Vitak B, Chen H H, et al. The Swedish Two-County Trial twenty years later. Updated mortality results and new insights from long-term follow-up. Radiologic Clinics of North America. 2000;38(4):625-651. [pmid: 10943268].
239 Tabar L, Vitak B, Chen H H T, Yen M F, Duffy S W, Smith R A. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2001;91(9):1724-1731. [pmid: 11335897].
240 Vitak B. Invasive interval cancers in the Ostergotland Mammographic Screening Programme: radiological analysis. European Radiology. 1998;8:639-646. [pmid: 9569340].
241 Vitak B, Olsen K E, Manson J C, Arnesson L G, Stal O. Tumour characteristics and survival in patients with invasive interval breast cancer classified according to mammographic findings at the latest screening: a comparison of true interval and missed interval cancers. European Radiology. 1999;9:460-469. [pmid: 10087117].
242 Bjurstam N, Bjorneld L, Duffy S W, et al. The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39–49 years at randomization. Cancer. 1997;80(11):2091-2099. [pmid: 9392331].
243 Bjurstam N, Bjorneld L, Duffy S W, et al. The Gothenburg Breast Cancer Screening Trial: preliminary results on breast cancer mortality for women aged 39–49 [letter]. J Natl Cancer Inst Monogr. 1997;22:53-55. [pmid: 9709276].
244 Bjurstam N, Bjorneld L, Duffy S W, Prevost T C. Author reply. Cancer. 1998;83(1):188-190.
245 Miller A B, Baines C J, To T. The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39–49 years at randomization [letter; comment]. Cancer. 1998;83(1):186-190. [pmid: 9655310].
246 Semiglazov V F, Moiseenko V M. Breast self-examination for the early detection of breast cancer: a USSR/WHO controlled trial in Leningrad. Bull World Health Organ. 1987;65(3):391-396. [pmid: 3311442].
247 Semiglazov V F, Moiseyenko V M, Bavli J L, et al. The role of breast self-examination in early breast cancer detection (results of the 5-years USSR/WHO randomized study in Leningrad). Eur J Epidemiol. 1992;8(4):498-502. [pmid: 1397215].
248 Semiglazov V F, Sagaidak V N, Moiseyenko V M, Mikhailov E A. Study of the role of breast self-examination in the reduction of mortality from breast cancer. The Russian Federation/World Health Organization Study. Eur J Cancer. 1993;29A(14):2039-2046. [pmid: 8280499].
249 Semiglazov V F, Moiseenko V M, Protsenko S A, et al. [Preliminary results of the Russia (St.Petersburg)/WHO program for the evaluation of the effectiveness of breast self-examination]. Vopr Onkol. 1996;42(4):49-55. [pmid: 8928459].
250 Semiglazov V F, Moiseenko V M, Manikhas A G, et al. [Interim results of a prospective randomized study of self-examination for early detection of breast cancer (Russia/St.Petersburg/WHO)] The role of breast self-examination in early breast cancer detection (results of the 5-years USSR/WHO randomized study in Leningrad). Vopr Onkol. 1999;45(3):265-271. [pmid: 10443229].
251 Thomas H V, Reeves G K, Key T J. Endogenous estrogen and postmenopausal breast cancer: a quantitative review. Cancer Causes Control. 1997;8(6):922-928. [pmid: 9427435].