# References

1 U.S. Preventive Services Task Force. (2005). Screening for genital herpes: recommendation statement. Am Fam Physician.
2 Whitley RJ, Kimberlin DW, Roizman B. (1998). Herpes simplex viruses. Clin Infect Dis.
3 Patel R, Rompalo A. (2012). Genital herpes infections. Zenilman J, Shahmahnesh M, editors. Sexually Transmitted Infections: Diagnosis, Management and Treatment.
4 Corey L. (1994). The current trend in genital herpes. Progress in prevention. Sex Transm Dis.
5 Workowski KA. (2015). Centers for disease control and prevention sexually transmitted diseases treatment guidelines. Clin Infect Dis.
6 Bradley H, Markowitz LE, Gibson T, et al. (2014). Seroprevalence of herpes simplex virus types 1 and 2--United States, 1999–2010. J Infect Dis.
7 Patel R, Rompalo A. (2009). Genital herpes infections. Zenilman JSM, editor. Sexually Transmitted Infections: Diagnosis, Management, and Treatment.
8 Benedetti JK, Zeh J, Corey L. (1999). Clinical reactivation of genital herpes simplex virus infection decreases in frequency over time. Ann Intern Med.
9 Engelberg R, Carrell D, Krantz E, et al. (2003). Natural history of genital herpes simplex virus type 1 infection. Sex Transm Dis.
10 Fleming DT, McQuillan GM, Johnson RE, et al. (1997). Herpes simplex virus type 2 in the United States, 1976 to 1994. N Engl J Med.
11 Wald A, Zeh J, Selke S, et al. (2000). Reactivation of genital herpes simplex virus type 2 infection in asymptomatic seropositive persons. N Engl J Med.
12 Langenberg AG, Corey L, Ashley RL, et al. (1999). A prospective study of new infections with herpes simplex virus type 1 and type 2. Chiron HSV Vaccine Study Group. N Engl J Med.
13 Sacks SL. (2004). Famciclovir suppression of asymptomatic and symptomatic recurrent anogenital herpes simplex virus shedding in women: a randomized, double-blind, double-dummy, placebo-controlled, parallel-group, single-center trial. J Infect Dis.
14 Watts DH, Brown ZA, Money D, et al. (2003). A double-blind, randomized, placebo-controlled trial of acyclovir in late pregnancy for the reduction of herpes simplex virus shedding and cesarean delivery. Am J Obstet Gynecol.
15 Sheffield JS, Hollier LM, Hill JB, et al. (2003). Acyclovir prophylaxis to prevent herpes simplex virus recurrence at delivery: a systematic review. Obstet Gynecol.
16 Brown ZA, Wald A, Morrow RA, et al. (2003). Effect of serologic status and cesarean delivery on transmission rates of herpes simplex virus from mother to infant. J Am Med Assoc.
17 Brown ZA. (2000). HSV-2 specific serology should be offered routinely to antenatal patients. Rev Med Virol.
18 (2000). ACOG practice bulletin. Management of herpes in pregnancy. Number 8 October 1999. Clinical management guidelines for obstetrician-gynecologists. Int J Gynaecol Obstet.
19 Centers for Disease Control and Prevention. (2010). STD Treatment Guidelines, 2010: Diseases Characterized by Genital, Anal, or Perianal Ulcers.
20 Oster AM, Sternberg M, Nebenzahl S, et al. (2014). Prevalence of HIV, sexually transmitted infections, and viral hepatitis by Urbanicity, among men who have sex with men, injection drug users, and heterosexuals in the United States. Sex Transm Dis.
21 Xu F, Markowitz LE, Gottlieb SL, et al. (2007). Seroprevalence of herpes simplex virus types 1 and 2 in pregnant women in the United States. Am J Obstet Gynecol.
22 Xu F, Lee FK, Morrow RA, et al. (2007). Seroprevalence of herpes simplex virus type 1 in children in the United States. J Pediatr.
23 Xu F, Sternberg MR, Kottiri BJ, et al. (2006). Trends in herpes simplex virus type 1 and type 2 seroprevalence in the United States. JAMA.
24 Bernstein DI, Bellamy AR, Hook EW, et al. (2013). Epidemiology, clinical presentation, and antibody response to primary infection with herpes simplex virus type 1 and type 2 in young women. Clin Infect Dis.
25 Jin F, Prestage GP, Mao L, et al. (2006). Transmission of herpes simplex virus types 1 and 2 in a prospective cohort of HIV-negative gay men: the health in men study. J Infect Dis.
26 Roberts CM, Pfister JR, Spear SJ. (2003). Increasing proportion of herpes simplex virus type 1 as a cause of genital herpes infection in college students. Sex Transm Dis.
27 Wald A. (2006). Genital HSV-1 infections. Sex Transm Infect.
28 Ribes JA, Steele AD, Seabolt JP, et al. (2001). Six-year study of the incidence of herpes in genital and nongenital cultures in a central Kentucky medical center patient population. J Clin Microbiol.
29 Samra Z, Scherf E, Dan M. (2003). Herpes simplex virus type 1 is the prevailing cause of genital herpes in the Tel Aviv area, Israel. Sex Transm Dis.
30 Ross JD, Smith IW, Elton RA. (1993). The epidemiology of herpes simplex types 1 and 2 infection of the genital tract in Edinburgh 1978–1991. Genitourin Med.
31 Corey L, Adams HG, Brown ZA, et al. (1983). Genital herpes simplex virus infections: clinical manifestations, course, and complications. Ann Intern Med.
32 Kimberlin DW, Rouse DJ. (2004). Clinical practice. Genital herpes. N Engl J Med.
33 Weiss HA, Buve A, Robinson NJ, et al. (2001). The epidemiology of HSV-2 infection and its association with HIV infection in four urban African populations. AIDS.
34 Auvert B, Buve A, Ferry B, et al. (2001). Ecological and individual level analysis of risk factors for HIV infection in four urban populations in sub-Saharan Africa with different levels of HIV infection. AIDS.
35 Freeman EE, Weiss HA, Glynn JR, et al. (2006). Herpes simplex virus 2 infection increases HIV acquisition in men and women: systematic review and meta-analysis of longitudinal studies. AIDS.
36 Wald A, Link K. (2002). Risk of human immunodeficiency virus infection in herpes simplex type 2 seropositive persons: a meta-analysis. J Infect Dis.
37 Corey L, Wald A, Celum CL, et al. (2004). The effects of herpes simplex virus-2 on HIV-1 acquisition and transmission: a review of two overlapping epidemics. J Acquir Immune Defic Syndr.
38 Celum C, Wald A, Lingappa JR, et al. (2010). Acyclovir and transmission of HIV-1 from persons infected with HIV-1 and HSV-2. N Engl J Med.
39 Celum C, Wald A, Hughes J, et al. (2008). Effect of aciclovir on HIV-1 acquisition in herpes simplex virus 2 seropositive women and men who have sex with men: a randomised, double-blind, placebo-controlled trial. Lancet.
40 Benedetti J, Corey L, Ashley R. (1994). Recurrence rates in genital herpes after symptomatic first-episode infection. Ann Intern Med.
41 Ross K, Johnston C, Wald A. (2011). Herpes simplex virus type 2 serological testing and psychosocial harm: a systematic review. Sex Transm Infect.
42 Flagg EW, Weinstock H. (2011). Incidence of neonatal herpes simplex virus infections in the United States, 2006. Pediatrics.
43 Roberts SW. (2009). Herpes simplex virus: incidence of neonatal herpes simplex virus, maternal screening, management during pregnancy, and HIV. Curr Opin Obstet Gynecol.
44 Mahnert N, Roberts SW, Laibl VR, et al. (2007). The incidence of neonatal herpes infection. Am J Obstet Gynecol.
45 Handel S, Klingler EJ, Washburn K, et al. (2011). Population-based surveillance for neonatal herpes in New York City, April 2006–September 2010. Sex Transm Dis.
46 Hollier LM, Wendel GD. (2008). Third trimester antiviral prophylaxis for preventing maternal genital herpes simplex virus (HSV) recurrences and neonatal infection. Cochrane Database Syst Rev.
47 James SH, Kimberlin DW. (2015). Neonatal herpes simplex virus infection. Infect Dis Clin North Am.
48 LeGoff J, Pere H, Belec L. (2014). Diagnosis of genital herpes simplex virus infection in the clinical laboratory. Virol J.
49 Wald A. (2013). Knowledge is power: a case for wider herpes simplex virus serologic testing. JAMA Pediatr.
50 Gupta R, Warren T, Wald A. (2007). Genital herpes. Lancet.
51 Money D, Steben M, et al. (2009). SOGC clinical practice guidelines: Genital herpes: gynaecological aspects. Number 207, April 2008. Int J Gynaecol Obstet.
52 Clinical Effectiveness Group (British Association for Sexual Health and HIV). (2006). Sexually Transmitted Infections: UK National Screening and Testing Guidelines.
53 American Academy of Family Physicians. (2016). Summary of Recommendations for Clinical Preventive Services.
54 Centers for Disease Control and Prevention. (2015). 2015 Sexually Transmitted Diseases Treatment Guidelines.
55 ACOG Committee on Practice Bulletins. (2007). ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists. No. 82 June 2007. Management of herpes in pregnancy. Obstet Gynecol.
56 National Collaborating Centre for Women’s and Children’s Health (UK). (2011). Cesarean Section.
57 Glass N, Nelson HD, Huffman L. (2005). Screening for genital herpes simplex: Brief update for the U.S. Preventive Services Task Force.
58 U.S. Food and Drug Administration. (2014). Search Registration and Listing.
59 (2011). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
60 LeFevre ML. (2014). Behavioral counseling interventions to prevent sexually transmitted infections: U.S. PreventiveServices Task Force recommendation statement. Ann Intern Med.
61 Moyer VA. (2013). Screening for HIV: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med.
62 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
63 West SL, Gartlehner G, Mansfield AJ, et al. (2010). Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Paper.
64 StataCorp. (2015). Stata Statistical Software: Release 14.0.
65 Mark HD, Nanda JP, Roberts J, et al. (2007). Performance of focus ELISA tests for HSV-1 and HSV-2 antibodies among university students with no history of genital herpes. Sex Transm Dis.
66 Ashley-Morrow R, Nollkamper J, Robinson NJ, et al. (2004). Performance of focus ELISA tests for herpes simplex virus type 1 (HSV-1) and HSV-2 antibodies among women in ten diverse geographical locations. Clin Microbiol Infect.
67 Mujugira A, Morrow RA, Celum C, et al. (2011). Performance of the Focus HerpeSelect-2 enzyme immunoassay for the detection of herpes simplex virus type 2 antibodies in seven African countries. Sex Transm Infect.
68 Smith JS, Bailey RC, Westreich DJ, et al. (2009). Herpes simplex virus type 2 antibody detection performance in Kisumu, Kenya, using the HerpeSelect ELISA, Kalon ELISA, Western blot and inhibition testing. Sex Transm Infect.
69 Golden MR, Ashley-Morrow R, Swenson P, et al. (2005). Herpes simplex virus type 2 (HSV-2) Western blot confirmatory testing among men testing positive for HSV-2 using the focus enzyme-linked immunosorbent assay in a sexually transmitted disease clinic. Sex Transm Dis.
70 Morrow RA, Friedrich D, Meier A, et al. (2005). Use of “biokit HSV-2 Rapid Assay” to improve the positive predictive value of Focus HerpeSelect HSV-2 ELISA. BMC Infect Dis.
71 Hogrefe W, Su X, Song J, et al. (2002). Detection of herpes simplex virus type 2-specific immunoglobulin G antibodies in African sera by using recombinant gG2, Western blotting, and gG2 inhibition. J Clin Microbiol.
72 van Dyck E, Buve A, Weiss HA, et al. (2004). Performance of commercially available enzyme immunoassays for detection of antibodies against herpes simplex virus type 2 in African populations. J Clin Microbiol.
73 Lingappa J, Nakku-Joloba E, Magaret A, et al. (2010). Sensitivity and specificity of herpes simplex virus-2 serological assays among HIV-infected and uninfected urban Ugandans. Int J STD AIDS.
74 Ng’ayo MO, Friedrich D, Holmes KK, et al. (2010). Performance of HSV-2 type specific serological tests in men in Kenya. J Virol Methods.
75 Delany-Moretlwe S, Jentsch U, Weiss H, et al. (2010). Comparison of focus HerpesSelect and Kalon HSV-2 gG2 ELISA serological assays to detect herpes simplex virus type 2 antibodies in a South African population. Sex Transm Infect.
76 Corey L, Wald A, Patel R, et al. (2004). Once-daily valacyclovir to reduce the risk of transmission of genital herpes. N Engl J Med.
77 Mark H, Nanda JP, Joffe A, et al. (2008). Serologic screening for herpes simplex virus among university students: a pilot study. J Am Coll Health.
78 Melville J, Sniffen S, Crosby R, et al. (2003). Psychosocial impact of serological diagnosis of herpes simplex virus type 2: a qualitative assessment. Sex Transm Infect.
79 Rosenthal SL, Zimet GD, Leichliter JS, et al. (2006). The psychosocial impact of serological diagnosis of asymptomatic herpes simplex virus type 2 infection. Sex Transm Infect.
80 Wild D, Patrick D, Johnson E, et al. (1995). Measuring health-related quality of life in persons with genital herpes. Qual Life Res.
81 Sperling RS, Fife KH, Warren TJ, et al. (2008). The effect of daily valacyclovir suppression on herpes simplex virus type 2 viral shedding in HSV-2 seropositive subjects without a history of genital herpes. Sex Transm Dis.
82 Leone P, Warren T, Hamed K, et al. (2007). Famciclovir reduces viral mucosal shedding in HSV-seropositive persons. Sex Transm Dis.
83 Kim HN, Wald A, Harris J, et al. (2008). Does frequency of genital herpes recurrences predict risk of transmission? Further analysis of the valacyclovir transmission study. Sex Transm Dis.
84 Mujugira A, Magaret AS, Celum C, et al. (2013). Daily acyclovir to decrease herpes simplex virus type 2 (HSV-2) transmission from HSV-2/HIV-1 coinfected persons: a randomized controlled trial. J Infect Dis.
85 Provenzale A, Evans K, Russell J, et al. (2011). Psychosocial impact of a positive HSV-2 diagnosis on adults with unrecognized HSV-2 infection. Public Health Nurs.
86 Wilkinson D, Barton S, Chard S, et al. (2000). The psychological consequences in patient undergoing a POCKit HSV-2 test. Int J STD AIDS.
87 Miyai T, Turner KR, Kent CK, et al. (2004). The psychosocial impact of testing individuals with no history of genital herpes for herpes simplex virus type 2. Sex Transm Dis.
88 Richards J, Scholes D, Caka S, et al. (2007). HSV-2 serologic testing in an HMO population: uptake and psychosocial sequelae. Sex Transm Dis.
89 UW Medicine, Department of Laborary Medicine. (2015). HSV Western Blot Serology.
90 Le Cleach L, Trinquart L, Do G, et al. (2014). Oral antiviral therapy for prevention of genital herpes outbreaks in immunocompetent and nonpregnant patients. Cochrane Database Syst Rev.
91 Johnston C, Gottlieb SL, Wald A. (2016). Status of vaccine research and development of vaccines for herpes simplex virus. Vaccine.
92 Langenberg A, Benedetti J, Jenkins J, et al. (1989). Development of clinically recognizable genital lesions among women previously identified as having “asymptomatic” herpes simplex virus type 2 infection. Ann Intern Med.
93 Frenkel LM, Garratty EM, Jie Ping S, et al. (1993). Clinical reactivation of herpes simplex virus type 2 infection in seropositive pregnant women with no history of genital herpes. Ann Intern Med.
94 Tronstein E, Johnston C, Huang ML, et al. (2011). Genital shedding of herpes simplex virus among symptomatic and asymptomatic persons with HSV-2 infection. JAMA.
95 Summerton J, Riedesel M, Laeyendecker O, et al. (2007). Effect of sexually transmitted disease (STD) coinfections on performance of three commercially available immunosorbent assays used for detection of herpes simplex virus type 2-specific antibody in men attending Baltimore, Maryland, STD clinics. Clin Vaccine Immunol.
96 Gamiel JL, Tobian AA, Laeyendecker OB, et al. (2008). Improved performance of enzyme-linked immunosorbent assays and the effect of human immunodeficiency virus coinfection on the serologic detection of herpes simplex virus type 2 in Rakai, Uganda. Clin Vaccine Immunol.
97 Ashley RL, Wu L, Pickering JW, et al. (1998). Premarket evaluation of a commercial glycoprotein G-based enzyme immunoassay for herpes simplex virus type-specific antibodies. J Clin Microbiol.
98 Smith A, Denham I, Keogh L, et al. (2000). Psychosocial impact of type-specific herpes simplex serological testing on asymptomatic sexual health clinic attendees. Int J STD AIDS.
99 Edlow A, Kaimal A, Lee H, et al. (2012). Screening for herpes simplex virus in pregnancy does not impact quality of life. Reprod Sci.