# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: David Meyers, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Rhoda A. Morrow, PhD, University of Washington, David Kimberlin, MD, University of Alabama at Birmingham, Jeffrey Peipert, MD, MPH, MHA, Washington University, and one anonymous content expert; federal partner reviewers from the Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Institute of Allergy and Infectious Diseases, Office of the Surgeon General, and the National Center for HIV, Hepatitis, STD, and TB Prevention (Centers for Disease Control and Prevention); Evelyn Whitlock, MD, MPH, former Kaiser Permanente Research Affiliates EPC Director; and RTI International–University of North Carolina EPC Staff: Meera Viswanathan, PhD, Director, Rachel Weber and Carol Woodell, Project Managers, Christiane Voisin, MSLS, Librarian, Sharon Barrell, Editor, and Loraine Monroe, Publications Specialist.