# 4 Discussion

## Summary of Evidence

Table 6 provides a summary of findings in this evidence review. This table is organized by KQ, then by population or screening test, and provides a summary of outcomes along with our assessments of consistency, precision, quality, and applicability.

Table 6 Summary of Evidence

KQ | Population | No. of Studies (Total N) Study Designs | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence for KQ | Applicability
1 | - | No studies identified | - | - | - | - | - | - | -
2 | Adults without current symptoms of genital herpes | HerpeSelect, cutpoint 1.1: 10 (6,537) HerpeSelect, cutpoint 2.2 to 3.5: 7 (5,516) Biokit HSV-2: 4 (1,512) Cross-sectional | HerpeSelect, cutpoint 1.1: Sens: 99% (95% CI, 97 to 100) Spec: 81% (95% CI, 68 to 90) HerpeSelect cutpoint 2.2 to 3.5: Sens: 95% (95% CI, 91 to 97) Spec: 89% (95% CI, 82 to 93) Biokit HSV-2: Sens: 84% (95% CI, 73 to 91) Spec: 95% (95% CI, 93 to 97) | Herpeselect (any cutpoint): consistent/imprecise Biokit HSV-2: consistent/imprecise | Yes^*^ | Fair | Most studies excluded equivocal test results from calculations of sens/spec (or did not describe the handling of missing data); sampling strategy was often not adequately described | Moderate | Populations from African countries that have a high prevalence of HSV-2 infection (>50%); applicability to asymptomatic populations receiving care in U.S. primary care settings is limited
3 | Asymptomatic adults with HSV-2 infection | 2 (57) Qualitative study; cohort study | Qualitative study: New HSV-2 diagnosis is associated with: 1) short-term, emotional responses (e.g., distress, sadness); 2) short-term, psychological responses (e.g., fear of telling sex partners); and 3) perceived ongoing responses (e.g., feeling sexually undesirable) Cohort study: Individual items frequently reported as interfering in daily life on the herpes HRQOL questionnaire: “It is difficult to forget have herpes” (63%); “I worry about giving herpes to someone” (56%); “I worry about people finding out I have herpes” (48%); and others. | Consistent/imprecise | Not detected | Fair | Studies are uncontrolled (no concurrent control group of people who were not screened); due to study design and outcome measures, we cannot estimate a magnitude of effect or assess precision | Low | Asymptomatic persons with no known history of genital herpes
4 | Asymptomatic adults with HSV-2 infection | 2 (129) Crossover RCTs | Days with any subclinical genital HSV-2 viral shedding detected over 6–8 weeks:; - Valacyclovir 1 g daily vs. placebo: 1.5% vs. 5.1%, respectively; p<0.001; - Famciclovir 250 mg twice daily vs. placebo: 5.7% vs. 5.0%, respectively; RR, 0.8 (95% CI, 0.41 to 1.56); p=0.52 | Inconsistent/imprecise | Not detected | Fair | Studies assessed different medications over a short duration; sample sizes were small and overall attrition was >20% in both trials | Insufficient | Asymptomatic adults with HSV-2 infection diagnosed (or confirmed by) Western blot.
5 | Asymptomatic adults with HSV-2 infection | 2 (129) Crossover RCTs | Incidence of self-reported genital herpes symptoms at 6–8 weeks:; - Valacyclovir 1 g daily vs. placebo: 12% vs. 23%, respectively; p=0.033; - Famciclovir vs. placebo: 17.5% vs. 17.2%; respectively, (p-value NR) | Inconsistent/imprecise | Not detected | Fair | Incidence was self-reported; outcomes were measured over a relatively short duration; samples sizes were small and overall attrition was >20% in both trials | Insufficient | Asymptomatic adults with HSV-2 infection diagnosed (or confirmed by) Western blot.
5 | Serodiscordant couples | 2 (2421) RCTs | Incidence of HSV-2 seroconversion:; - Valacyclovir vs. placebo at 32 weeks: benefit in favor of valacyclovir (HR, 0.52 [95% CI:, 0.27–0.99]; p=0.04); - Acyclovir vs. placebo at 78 weeks: no difference between groups (HR, 1.35 [95% CI, 0.83–2.20]; p=0.220) | Inconsistent/imprecise | Not detected | Fair | Two studies assessed different medications over different durations in populations that were heterogeneous | Insufficient | Asymptomatic adults with known, ongoing exposure to genital herpes from a partner.
6 | Asymptomatic adults with HSV-2 infection | 1 (62) RCT | Incidence of self-reported adverse events were similar between groups (headache, nausea) | Unknown/Imprecise | Not detected | Fair | Unclear if adverse events were prespecified | Insufficient | Generally healthy asymptomatic nonpregnant adults.

* We found evidence for only two FDA-approved serologic tests for HSV-2; we did not identify studies assessing the accuracy of other FDA-approved tests (compared to the Western blot).

Abbreviations: CI=confidence interval; HSV=herpes simplex virus; KQ=key question; N=number; NA=not applicable; RCT= randomized, controlled trial; Sens=sensitivity; Spec=specificity.

### Evidence for Benefit and Harms of Screening for HSV-2 Infection

We did not identify any eligible studies directly assessing the benefits or harms of serologic screening for HSV-2 compared with no screening. Therefore, we reviewed literature that might establish an indirect chain of evidence from multiple questions that link screening to health outcomes (KQs 2–7).

We found evidence from two uncontrolled observational studies that detection of unexpected HSV-2 by screening is associated with potential psychosocial harms, including anxiety, worry, and distress from a HSV-2 diagnosis. Our conclusions about the potential harms of screening differ slightly from those of other reviews focused on the harms of HSV-2 serologic testing.^41, 85^ This may reflect differences in scope or eligibility criteria (or both). For example, we excluded studies enrolling persons who were seeking care for genital symptoms or concerns about recent exposure to someone with genital herpes.^86, 87^ We also excluded studies that enrolled persons with prior symptoms of HSV-2. When an assessment of current and prior symptom status was not reported, we contacted authors to confirm whether (and how) prior symptoms were assessed. We also excluded other studies from our evidence review that were included in prior reviews due to methodological shortcomings (i.e., poor quality), such as high attrition (and no methods to address missing data) and high risk of selection bias.^77, 88^

Other potential harms of serologic screening include false-positive test results that lead to psychosocial distress and costs of confirmatory testing. Currently, there is no widely available gold standard to confirm a positive HSV-2 test. Western blot testing is available through the University of Washington Clinical Virology Laboratory at a cost of about $207.^89^ Use of the Biokit HSV-2 has been advocated as a confirmatory test for positive HSV-2 results detected via HerpeSelect. Some commercially available HSV-2 serologic tests are “paired”—that is, they report both HSV-1 and HSV-2 results. Positive results for HSV-1 may cause confusion given that the test cannot indicate the site of infection.

### Accuracy of Serologic Screening Tests for HSV-2 Infection

Our pooled estimates of sensitivity and specificity for the commercially available HerpeSelect test found a sensitivity of 99 percent (95% CI, 97 to 100; 7,129 participants) and a specificity of 83 percent (95% CI, 68 to 90; 6,537 participants) using the manufacturer’s cutpoint (1.1) compared with the Western blot. Estimates for specificity varied and were imprecise, without a clear explanation for the observed heterogeneity. Potential explanations for false-positive serologic test results include cross-reactivity with HSV-1 (or other viruses), recent seroconversion, geographic variability in HSV-2 strain variants, and laboratory error. Of the six studies that described HSV-1 prevalence among enrolled participants, four studies had a HSV-1 prevalence of 93 percent or greater and found specificity estimates ranging from 52 to 89 percent.^66, 71, 74, 75^ Specificity estimates were higher at 93 and 94 percent in two studies with a lower HSV-1 prevalence (1% and 64%).^65, 70^

At higher cutpoints (2.2 to 3.5), estimates of sensitivity and specificity from eight studies in Africa were still imprecise. Our pooled estimates of sensitivity was 95 percent (95% CI, 91 to 97; 5,516 participants) and specificity was 89 percent (95% CI, 82 to 93; 5,516 participants). Four of these studies assessed the accuracy of the Biokit HSV-2 serologic test; our pooled estimates of sensitivity was 84 percent (95% CI, 73 to 91; 1,512 participants) and specificity was 95 percent (95% CI, 92 to 97; 1,512 participants).

These estimates of the accuracy of serologic tests are generally applicable to populations with a higher prevalence of HSV-2 infection than general primary care populations in the United States. Eight studies assessing the accuracy of HerpeSelect enrolled a population with HSV-2 prevalence greater than 40 percent based on Western blot (range, 41% to 70%); one enrolled a population with a prevalence of 28 percent;^73^ and one enrolled a population with a prevalence of 9 percent.^65^ Use of HerpeSelect in a population with lower prevalence, similar to that of U.S. adults, would greatly increase the number of false-positive tests, even if specificity were unchanged. For example, in a population of 100,000 with a prevalence of asymptomatic HSV-2 of 50 percent (similar to the prevalence in included studies) with a test sensitivity of 99 percent and specificity of 81 percent, there would be 49,500 true-positive test results and 9,500 false-positive test results (PPV, 84%).

If the prevalence instead was 16 percent (similar to the seroprevalence in the general U.S. adult population among persons with unknown symptom status), the number of true-positives would decrease to 15,840 and the number of false-positives would increase to 15,960 (PPV, 50%). True-positives would decrease further and false-positives would increase further if the prevalence was less than 16 percent. The true prevalence of asymptomatic HSV-2 infection in the United Sates is unknown. Prevalence estimates rely on serologic test results and are not confirmed with the Western blot. Although the overall seroprevalence of HSV-2 was 16 percent in the most recent NHANES survey, 3.8 percent of participants reported having been diagnosed with genital herpes and data was not collected regarding whether participants had prior symptoms consistent with herpes.^6^ Of those who were HSV-2 seropositive, 14 percent reported having been diagnosed with genital herpes.^6^ It is unclear what proportion of participants with no prior diagnosis of genital herpes who were identified as being HSV-2 seropositive have a true infection that is asymptomatic (or unrecognized) versus a false-positive serologic test result.

If sensitivity were unchanged, screening a lower-prevalence population would reduce the number of false-negative tests, although the NPV would change little. It is possible, however, that the sensitivity of the screening tests could be lower in a lower-prevalence population due to such factors as lower antibody levels, thus increasing the number of false-negative tests per 1,000 persons tested. The direction of these changes in prevalence would be similar regardless of which cutpoint is used.

### Benefits and Harms of Preventive Interventions for Asymptomatic Persons Who Are HSV-2 Seropositive or for Serodiscordant Couples

We found limited evidence evaluating preventive interventions for asymptomatic adults who screen positive for HSV-2. No studies enrolled pregnant women or adolescents, and no eligible studies assessed behavioral counseling interventions.

Two RCTs (with a total of 129 participants) assessed the benefit of preventive antiviral medications for reducing HSV-2 viral shedding and symptomatic occurrences among adults seropositive for HSV-2 who reported no prior symptoms consistent with genital herpes. Evidence from these two trials does not allow an accurate estimate of the benefit of preventive antiviral medications for improving health outcomes. The two trials differed in several ways. They assessed different medications (valacyclovir and acyclovir), recruited from different sources, and used different tests to establish HSV-2 infection. Both assessed outcomes over a short time (6 to 8 weeks) and relied on self-report to ascertain symptom occurrence. This duration is likely inadequate to evaluate whether antiviral medications reduce the incidence of symptoms among populations who have been asymptomatic. Results were inconsistent and imprecise; one trial found benefit for valacyclovir compared with placebo for reducing viral shedding and symptom occurrences^81^ and the other found no statistically significant differences between groups.^82^

Similarly, the two trials assessing preventive antiviral medications for reducing HSV-2 transmission between serodiscordant partners were heterogeneous and found inconsistent results. One enrolled immunocompetent couples from primarily industrialized countries,^76^ while the other enrolled couples who were serodiscordant for both HIV and HSV-2 from sub-Saharan Africa.^84^ The studies assessed different medications (valacyclovir and acyclovir) and over different durations (8 months and a median of 18 months). One trial found benefit for valacyclovir compared with placebo for reducing symptomatic HSV-2 infection and HSV-2 seroconversion in the susceptible partner; however, the magnitude of benefit is modest and results are imprecise.

One trial assessed harms of medications; adverse events were similar between groups randomized to valacyclovir and placebo.^81^ Although few studies eligible for our review assessed harms of antiviral medications, other reviews have concluded that there are few harms in nonpregnant adults.^90^

## Limitations of the Review

We required studies to compare FDA-approved, currently available serologic screening tests with Western blot. We did not include preventive interventions that are not FDA-approved and currently unavailable in the United States, such as studies of topical tenofovir gel or HSV-2 vaccines. We did not evaluate other comparisons, such as a serologic test compared with a viral PCR swab or culture to diagnose genital herpes. We focused on studies comparing a serologic test with the Western blot and did not include studies that assessed the concordance between two commercially available serologic tests (i.e., without comparing them to a gold standard).

For benefits, we did not evaluate every possible outcome. For example, we did not evaluate whether interventions for asymptomatic HSV-2 infection in persons with HIV prevents transmission of HIV.

We also limited our assessment to studies enrolling persons who had no current or prior symptoms. For persons with frequent symptomatic recurrences of genital herpes (>4 episodes per year), antiviral medications have been shown to reduce the frequency of recurrences; however, the magnitude of effect is somewhat uncertain and the quality of evidence is low. A Cochrane review published in 2014 evaluated the efficacy of antiviral medications (acyclovir, famciclovir, and valacyclovir) to suppress genital herpes outbreaks in nonpregnant adults.^90^ Twenty-two trials were included; the risk of bias was considered high for half of the studies and unclear for the other half. The authors concluded that there was low-quality evidence that the risk of having at least one clinical recurrence was reduced with acyclovir (9 parallel-group trials; n=2,049; RR, 0.48 [95% CI, 0.39 to 0.58]), valacyclovir (4 trials; n=1,788; RR, 0.41 [95% CI, 0.24 to 0.69]), or famciclovir (2 trials; n=732; pooled RR, 0.57 [95% CI, 0.50 to 0.64]).^90^ It is unclear whether these results would apply to persons who have less frequent recurrences (or who are asymptomatic).

## Future Research Needs

RCTs enrolling persons with no (or unrecognized) genital herpes symptoms that directly compare screening with no screening and assess health outcomes (i.e., trials that address KQ 1, the overarching question) over at least 12 months are required to improve the evidence base for serologic screening for HSV-2. Studies assessing the accuracy of HSV-2 serologic tests that enroll asymptomatic persons from primary care settings in the United States would clarify the accuracy of these tests when used in the general population (related to KQ 2). Such studies should aim to include a representative asymptomatic community population, to avoid spectrum bias, and compare all results with the Western blot. Future studies of serologic test accuracy should clearly describe the handling of indeterminate (or equivocal) test results.

To better understand the frequency and severity of the harms of screening, longitudinal studies with sensitive measures of psychosocial distress attributable to screening or to positive screening results are needed. These studies should evaluate pre- and posttest counseling approaches and should include such outcomes as disruption of relationships.

Future studies that assess the benefit of behavioral counseling interventions specifically focused on genital herpes (compared with no intervention) among asymptomatic populations that screen positive for HSV-2 would help clarify whether nonmedication interventions are effective for improving health outcomes. Finally, RCTs assessing the effectiveness of antiviral medications for reducing viral shedding and improving health outcomes among persons with asymptomatic HSV-2 infection should enroll screen-detected populations and measure outcomes over a longer duration.

The net benefit of serologic screening for HSV-2 could be affected by development of an effective vaccine. Previous clinical trials of HSV vaccines have not shown efficacy; however, work in this area is ongoing^91^ and may prove to be an effective prevention strategy.

## Conclusion

Serologic screening for HSV-2 infection is associated with psychological harms and false-positive test results, particularly in populations that have a low prevalence of HSV-2. Evidence on the benefit of preventive antiviral medications for reducing viral shedding or improving health outcomes (e.g., reducing symptom occurrences) in asymptomatic adults who screen positive for HSV-2 is uncertain. We found no evidence evaluating preventive interventions in pregnant women or adolescents.