# 3 Results

## Literature Search

We identified 3,213 unique titles and abstracts and assessed 289 full-text articles for eligibility (Figure 2). We excluded 271 articles for various reasons detailed in Appendix C and included 17 published studies of good or fair quality. Of the included studies, 11 were studies of HSV-2 serologic test accuracy (KQ 2), two assessed harms of screening for asymptomatic HSV-2 infection (KQ 3), and four were RCTs focused on the benefits of oral antiviral medications (KQs 4 and 5), one of which also reported on harms (KQ 6). We identified no eligible studies for KQ 1 (direct evidence of screening). Details of quality assessments of included studies and studies excluded because of poor quality are provided in Appendix D.

Figure 2 Summary of Evidence Search and Selection

The figure is a flow chart that summarizes the search and selection of articles. There were 3,213 references identified through database searches, after duplicates were removed. In addition, 77 references were identified through other sources. The titles and abstracts of 3,290 references were screened for potential inclusion. Of these, 289 were deemed appropriate for full-text review to determine eligibility. After full-text review, 271 were excluded: 37 for not original research, 63 for ineligible population, 18 for ineligible screening test, 31 for ineligible intervention, 36 for ineligible comparator, 50 for ineligible outcome, 21 for ineligible study design, 4 for ineligible language/non-English, and 11 for poor quality. Nineteen articles representing 17 studies are included in the systematic review: 0 studies were included for Key Question 1, 11 studies were included for Key Question 2 (10 studies were included in the quantitative analyses), 2 studies were included for Key Question 3, 2 studies were included for Key Question 4, 4 studies were included for Key Question 5, and 1 study was included for Key Question 6.

## Results

### KQ 1 Direct Evidence That Serologic Screening for Genital HSV-2 Infection Improves Health Outcomes

We found no eligible studies that addressed this question.

### KQ 2 Accuracy of Serologic Screening Tests for Detecting HSV-2 Infection

We included 11 good- or fair-quality studies assessing the accuracy of one or more type-specific HSV-2 serologic tests compared with the Western blot (Table 2).^65–75^ All 11 studies enrolled adults and none enrolled pregnant women; two studies enrolled participants as young as age 15 years, but neither described the proportion of participants who were younger than age 18 years (or reported outcomes separately).^66, 72, 76^ Four of the 11 included studies described the age of participants; the mean or median age ranged from 25 to 35 years.^65, 67, 69, 75^ Two studies enrolled only women^66, 75^ and one enrolled only men;^74^ of the other eight studies, one enrolled a minority of women (33%),^67^ one enrolled a majority of women (64%),^77^ and six did not describe the sex of participants. Most studies did not report on race/ethnicity; two studies conducted in the United States enrolled 23 to 31 percent nonwhite participants.^69, 77^ Most studies (k=8) enrolled a population with a HSV-2 prevalence greater than 40 percent based on Western blot (range, 41% to 70%).

Table 2 Characteristics of Included Studies Assessing the Accuracy of Serologic Screening Tests for HSV-2 (Key Question 2)

Author, Year Study Design Quality | Eligible Serologic Test(s) | Population (Analytic Sample Size) | Recruitment Setting; Country | Age, Mean (SD) | % Female | % Nonwhite | % With Comorbid STI | % HSV-1 Positive (Test^*^)
Ashley-Morrow, 2004^66^ Cross-sectional Fair | HerpeSelect | Women age ≥15 years participating in a HSV seroprevalence study (675) | Study participants Multinational^†^ | NR | 100 | NR | NR | 93–99 (WB)
Delany-Moretlwe, 2009^75^ Cross-sectional Fair | HerpeSelect | Adult women with unknown HSV-2 serostatus (98) | Family planning clinics South Africa | 26 (range, 18–46 years) | 100 | NR | HIV-1: 52 | NR
Golden, 2005^69^ Cross-sectional Fair | HerpeSelect | Men who had been tested for HSV at an STI clinic between 2001 and 2002 (61) | 2 county STI clinics United States | Median: 35 (range, 18–73 years) | 0 | 23 | 1 | 56 (WB)
Hogrefe, 2002^71^ Cross-sectional Fair | HerpeSelect | Adults, varied by location: Kenya: Women enrolled in a vitamin A study; Uganda: a) serologic samples from participants in a HIV seroprevalence study, b) samples from HIV-negative women; South Africa and Namibia: samples from healthy, primarily middle-income persons initially collected for HIV screening (776) | Varied by location; primarily study participants Multiple African countries^‡^ | NR | NR | NR | NR | 89–100 (WB)
Lingappa, 2010^73^ Cross-sectional Good | HerpeSelect Biokit HSV-2 | Adults participating in a study of genital herpes seroprevalence and incidence (467) | Study participants Uganda | NR | NR | NR | HIV-1: 12 | NR
Mark, 2007^65^; Mark, 2008^77^ Cohort study Good | HerpeSelect | Urban university students with no history of genital herpes or genital sores who reported being sexually active within the past 6 months (89) | Recruited by flyers, announcement, and online/newspaper ads at 1 university United States | 25 (4.4) | 64 | 31% | NR | 9 (HerpeSelect) 3 (WB)
Morrow, 2005^70^ Cross-sectional Fair | HerpeSelect Biokit HSV-2 | Two populations enrolled:; 1. Adult MSM screened for enrollment in a clinical trial assessing acyclovir to reduce HIV transmission; 2. Consecutive serologic samples submitted for HSV WB testing (782) | Study participants and serologic samples sent to the University of Washington Virology Laboratory during a 4-week period United States | NR | 0 | NR | NR | 64 (WB)
Mujugira, 2011^67^ Cross-sectional Good | HerpeSelect | HIV-negative adult men and women participating in the Partners in Prevention HSV/HIV Transmission Study^§^ (3290) | Study participants Multiple African Countries^¶^ | Median: 34 | 33 | NR | NR | NR
Ng’ayo, 2010^74^ Cross-sectional Fair | HerpeSelect Biokit HSV-2 | Adult men who worked in the fishing industry who reported being sexually active in the previous 2 weeks (233) | Community (beaches along Lake Victoria) Kenya | NR (age ≥18 years eligible) | 0 | NR | NR | NR
Smith, 2009^68^ Cross-sectional Fair | HerpeSelect | Adult men who were HIV-negative participating in a trial to determine the effectiveness of circumcision in reducing HIV incidence (99) | Study participants (recruited from STI clinics, workplaces, and community organizations) Kenya | NR | 0 | NR | NR | NR
Van Dyck, 2004^72^ Cross-sectional Fair | HerpeSelect Biokit HSV-2 | Adults who were enrolled in a study on factors determining the spread of HIV (330) | Study participants Multiple African countries^**^ | NR (age ≥15–49 years eligible) | NR | NR | NR | NR

* Test used to determine HSV-1 seropositivity.

† Argentina, Costa Rica, Korea, Mexico, Nigeria, Thailand, and Vietnam.

‡ Kenya, Uganda, South Africa, and Namibia.

§ This is a randomized trial of acyclovir (for HSV-2 suppressive therapy) to reduce HIV-1 transmission.

¶ Kenya, Rwanda, Tanzania, Uganda, Botswana, South Africa, and Zambia.

** Kenya, Zambia, Benin, and Cameroon.

Abbreviations: HIV=human immunodeficiency virus; HSV=herpes simplex virus; MSM=men who have sex with men; N=number; NR=not reported; SD=standard deviation; STI=sexually transmitted infection; WB=Western blot.

Two of the 11 included studies described whether enrolled participants had current or prior symptoms consistent with genital herpes.^69, 77^ One enrolled U.S. college students with no current or previous symptoms consistent with genital herpes^77^ and the other study enrolled men seeking care at U.S. STI clinics, 35 percent of whom had symptoms of an STI (17% were later diagnosed with genital herpes).^69^ In all other studies, the proportion of participants who had current or past symptoms consistent with genital herpes was not described. Few studies described the prevalence of other current or past STIs; two studies reported on the prevalence of HIV (12%^73^ and 52%^75^) and one study reported on the percentage of participants with various STIs (35% had symptoms of an STI).^69^ Five studies reported on the seroprevalence of HSV-1; in four studies, it ranged from 56 to 99 percent,^66, 69–71^ and in one U.S. study enrolling university students, it was very low (3.4% based on Western blot).^77^

Most studies enrolled participants from one or more African countries; three were conducted in the United States^65, 69, 70^ and one enrolled participants from multiple countries (Argentina, Costa Rica, Korea, Mexico, Nigeria, Thailand, and Vietnam).^66^ Study participants were selected from heterogeneous sources. Most studies assessed the accuracy of a serologic test in populations that were enrolled (or screened for enrollment) in other studies focused on STIs, such as studies of HSV seroprevalence^66, 73^ and the seroprevalence or prevention of HIV.^67, 68, 71, 72^ Other studies enrolled participants from clinical settings (one from an STI clinic^69^ and one from family planning clinics^75^) or from community settings (one enrolled male fishermen employed along the beaches of Lake Victoria^74^ and one enrolled students from a U.S. university via flyers, online posts, and newspaper advertisements^77^).

Sample sizes ranged from 61 to 3,290. All 11 studies compared the Focus HerpeSelect HSV-2 ELISA with the Western blot. All studies used a test cutpoint value of 1.1 to define a positive test result (manufacturer’s current cutpoint). Seven studies also assessed higher test cutpoints to boost specificity (ranging from 2.1 to 3.5).^66–68, 71, 73–75^ Four studies also assessed the accuracy of the Biokit HSV-2 Rapid Test (Biokit USA, Lexington, MA).^70, 72–74^

#### HerpeSelect

##### Manufacturer’s Recommended Cutpoint

Ten studies (n=6,537 participants analyzed) provided sufficient data to estimate sensitivity and specificity of HerpeSelect using a cutpoint of 1.1.^65–68, 70–75^ The pooled estimates of sensitivity and specificity were 99 percent (95% CI, 97 to 100) and 81 percent (95% CI, 68 to 90), respectively; the positive and negative likelihood ratios were 6 (95% CI, 3 to 10) and 0.01 (95% CI, 0.004 to 0.04), respectively (Table 3). Appendix E Figure 1 shows the HSROC with 95 percent confidence ellipse using pairs of sensitivity and specificity. Results of individual studies are summarized in Appendix E Table 1.

Table 3 Accuracy of Serologic Screening Tests for HSV-2 Compared With Western Blot^*^

Test (Cutpoint) | Studies, n | Sensitivity, % (95% CI) | Specificity, % (95% CI) | Positive Likelihood Ratio (95% CI) | Negative Likelihood Ratio (95% CI)
HerpeSelect (1.1) | 10 (6,537) | 99 (97 to 100) | 81 (68 to 90) | 5 (3 to 10) | 0.01 (0.003 to 0.04)
HerpeSelect (2.2 to 3.5) | 7 (5,516) | 95 (91 to 97) | 89 (82 to 93) | 8 (5 to 13) | 0.06 (0.036 to 0.099)
Biokit HSV-2 | 4 (1,512) | 84 (73 to 91) | 95 (93 to 97) | 17 (11 to 29) | 0.16 (0.92 to 0.30)

* Values summarize pooled estimates of sensitivity and specificity based on hierarchical summary receiver-operator curve and bivariate analyses.

Estimates for specificity were highly variable, ranging from 41 to 97.5 percent. Specificity ranged from 41 to 70 percent in four studies,^68, 73–75^ from 80 to 89 percent in three studies,^66, 67, 71^ and from 93 to 97.5 percent in three studies.^65, 70, 72^ Of the three studies reporting a higher specificity (93% to 97.5%), two were conducted in the United States, which has a lower prevalence of HSV-2 than the other study population settings.^65, 70^

Studies handled equivocal (or indeterminate) test results in various ways, which may contribute to heterogeneity in estimates of test accuracy (Appendix E Table 1). Of the 10 studies reporting sensitivity or specificity, five excluded equivocal Western blot results,^66, 67, 70, 73, 74^ six excluded indeterminate HerpeSelect results,^65, 66, 68, 70, 71, 74^ and three excluded both equivocal Western blot and HerpeSelect results.^66, 70, 74^ Two studies did not describe the handling of equivocal test results.^72, 75^

Five studies reported a positive predictive value (PPV) using the manufacturer’s cutpoint; estimates ranged from 37.5 to 86.0.^65, 66, 69, 70, 74^ The lowest PPV was reported in a study enrolling U.S. university students (n=89) with no current or prior symptoms consistent with genital herpes (PPV, 37.5 [95% CI, 10.2 to 74.1]).^65^ Estimates from the other four studies ranged from 77.4 to 86.0; of these, two enrolled populations outside the United States (one was conducted in Kenya^74^ and the other included participants from Argentina, Nigeria, Thailand, Vietnam, and other countries^66^) and two enrolled populations in the United States who had either sought testing specifically for HSV^69, 70^ or were considered to have a higher risk of infection for other reasons (men who have sex with men screened for enrollment in a HIV prevention trial).^70^ Four studies reported negative predictive values (NPVs); estimates ranged from 96.5 to 100.^65, 66, 70, 74^

##### Higher Cutpoints

Seven studies (n=5,516 participants analyzed) also assessed higher cutpoints for positivity than those recommended by the manufacturer (ranging from 2.2 to 3.5); all were conducted in Africa.^66–68, 71, 73–75^ In general, estimates of specificity were higher at cutpoints greater than 2.2 but still imprecise (Table 3). The joint estimates of sensitivity and specificity were 95 percent (95% CI, 91 to 97) and 89 percent (95% CI, 82 to 93), respectively; the positive and negative likelihood ratios were 8 (95% CI, 5 to 13) and 0.06 (95% CI, 0.036 to 0.099), respectively (Table 3). Appendix E Figure 2 shows the HSROC with 95 percent confidence ellipse using pairs of sensitivity and specificity. Results of individual studies are summarized in Appendix E Table 1; as noted above, studies often excluded indeterminate test results from analyses.

Three studies reported PPV using cutpoints higher than those recommended by the manufacturer; estimates ranged from 86 to 98.^66, 69, 74^ Two studies reported NPV using cutpoints higher than those recommended by the manufacturer; estimates ranged from 96 to 98 (Appendix E Table 1).^66, 74^

#### Biokit HSV-2 Rapid Test

Four fair-quality studies (n=1,512 participants analyzed) reported on the sensitivity and specificity of the Biokit HSV-2 Rapid Test; one was conducted in the United States,^70^ two were conducted in African countries (Uganda^73^ and Kenya^74^), and one was multinational.^72^ The joint estimates of sensitivity and specificity were 84 percent (95% CI, 73 to 91) and 95 percent (95% CI, 93 to 97), respectively (Table 3). The positive and negative likelihood ratios were 17 (95% CI, 10 to 29) and 0.17 (95% CI, 0.09 to 0.30). Appendix E Figure 3 shows the HSROC with 95 percent confidence ellipse using pairs of sensitivity and specificity. Results of individual studies are summarized in Appendix E Table 2.

Two studies reported PPVs of 92 and 95 and NPVs of 62 and 98, respectively.^70, 74^

### KQ 3 Harms of Screening for Asymptomatic HSV-2

Characteristics and outcomes of the two included fair-quality studies are shown in Appendix E Table 3. The two studies enrolled different populations and measured different outcomes.^78, 79^ One was included in the 2005 review for the USPSTF^78^ and one was published after that review. Both studies were conducted in the United States and assessed the effect of a positive HSV-2 serologic test on psychosocial outcomes among persons who reported no prior history of genital herpes.

One study was a qualitative assessment of the psychosocial effects of receiving a diagnosis of HSV-2 based on serological testing.^78^ Investigators recruited 24 participants who reported no prior history of genital herpes and were found to be seropositive for HSV-2 (by Western blot). The mean age of participants was 35 years and 58 percent were women. Participants were recruited from clinical settings (STI, maternal and infant care, family medicine, and research clinics) over a 10-month period; they completed an in-depth interview on their experience of receiving a HSV-2 diagnosis. The qualitative analysis identified three categories of themes: 1) short-term, emotional responses that included surprise, denial, confusion, distress, sadness, disappointment, and relief to know; 2) short-term, psychological responses that included fear of telling sex partners, anger at the source partner, guilt about acquiring or transmitting, and concern about transmitting to a child; and 3) perceived ongoing responses that included fear of telling future partners, concern about transmitting to a sex partner, feeling sexually undesirable, feeling socially stigmatized, feeling like “damaged goods,” sex avoidance because of social responsibility, fear of transmitting to newborn child, and relationship concerns relating to the diagnosis. The authors concluded that participants exhibited strong emotional and psychological responses to their serological diagnoses of HSV-2, while observing that some of these responses were time-limited.^78^

The second study enrolled persons ages 14 to 30 years from an urban university setting and various clinical settings, including STI, primary care, and adolescent clinics.^79^ Of the 1,190 enrolled, 820 (68%) had serologic testing (type of test not described) and 149 (18%) were HSV-2 positive. Of those who screened positive for HSV-2, 93 (62%) participants returned for their initial test results and 33 returned for the 3-month followup. At 3 months, participants completed the herpes Health-Related Quality of Life (HRQOL) questionnaire, which addresses issues such as feelings of shame associated with herpes and feeling like herpes is “making life difficult.”^80^ Participants responded to each item using a 4-point scale that ranged from “very” to “not at all”; the total score was calculated by summing across items—a higher score indicated a better HRQOL and fewer problems with herpes. For individual item analysis, answers of “very” or “quite” were considered to be indicative of endorsing the experience.^79^ A number of individual HRQOL items were endorsed frequently as “very” or “quite,” including the following: “it is difficult to forget that I have herpes” (63%); “I worry about giving herpes to someone” (56%); “I worry about people finding out I have herpes” (48%); “I feel insecure about personal (intimate) relationships because of herpes” (30%); “I get depressed about having herpes” (30%); “I feel angry about having herpes” (30%); and “I worry that people will reject me if they know I have herpes” (30%).^79^ Items endorsed less frequently on the HRQOL scale are shown in Appendix E Table 3.

### KQ 4 Effectiveness of Oral Antiviral Medications for Reducing Genital HSV-2 Viral Shedding

We included two fair-quality RCTs that reported on viral shedding outcomes.^81, 82^ Both were crossover RCTs comparing daily preventive antiviral medication with placebo over 6 to 8 weeks in asymptomatic adults who screened positive for HSV-2 (Tables 4 and 5). One study did not describe how current or prior symptoms of genital herpes were ascertained;^82^ the other study reported that participants had undergone HSV serologic testing as part of their clinical care but had no current or prior symptoms that could be consistent with genital herpes (by self-report).^81^ We identified no eligible studies enrolling pregnant women or adolescents.

Table 4 Characteristics of Included Studies Assessing Antiviral Medications in Nonpregnant Adults (Key Questions 4 and 5)

Author, Year Study Design Quality | Group 1 (N) Group 2 (N) | Duration, weeks | Population | Recruitment Setting; Country | HSV-2 Test | Mean Age (SD) | % Female | % Nonwhite | % HSV-1 Positive
Sperling, 2008^81^ RCT (crossover) Fair | Total (63) Valacyclovir 1g daily first (36) Placebo first (37) | 8 active; 8 placebo | Adults age ≥18 years who are seropositive for HSV-2 with no active lesions or symptoms consistent with genital herpes and no history of recurrent or undiagnosed symptoms consistent with genital herpes | 13 clinical settings^*^ (STI clinics, primary care clinics, and gynecology practices) United States | HerpeSelect^†^ | 37 (NR) | 75 | 35 | 56–57
Leone, 2007^82^ RCT (crossover) Fair | Total (66) Famciclovir 250 mg twice daily first (NR) Placebo first (NR) | 6 active; 6 placebo | Adults age ≥18 years who are seropositive for HSV-2 with no history of symptomatic genital herpes | 7 centers (not otherwise specified) United States | Western blot | Median (range): 38 (18–68) | 64 | 35 | 55
Corey, 2004^76^ Kim, 2008^83^ RCT (parallel) Fair | Total (1484 couples) Valacyclovir 500 mg once daily (743 couples) Placebo (741 couples) | 32 | Adults age ≥18 years; HSV-2 serodiscordant heterosexual couples | 96 study sites (not otherwise specified) United States, Canada, Europe, Latin America, Australia | Western blot | Median (range): 34–34 (18–76) | 33 | 10–11 | 70
Mujugira^84^ RCT (parallel) Fair | Total (937 couples) Acyclovir 400 mg twice daily (458 couples) Placebo (453 couples) | 96 | HSV-2 serodiscordant heterosexual couples enrolled into the Partners in Prevention HSV/HIV Transmission study^38^; couples were also serodiscordant for HIV (HSV-2 infected partners were also infected with HIV) | 14 study sites (not specified) Kenya, Rwanda, Tanzania, Uganda, Botswana, South Africa, Zambia | HerpeSelect^‡^ | Median: 31 (IQR, 27–38) | 12 | NR | ≥99

* Participants had either undergone specific HSV serologic testing as part of their clinical care or in response to local advertisements offering free HSV serologic testing.

† Samples with an index value of 1.1 to 3.5 were confirmed with HSV-2 IgG inhibition assay to eliminate false-positive test results.

‡ Samples with an index value of ≥3.5 were considered positive to improve test specificity, and confirmed by Western blot.

Abbreviations: HSV=herpes simplex virus; IQR=interquartile range; N=number; NR=not reported; RCT=randomized, controlled trial; SD=standard deviation.

Table 5 Results of Included Studies Assessing Preventive Interventions (Key Questions 4 and 5)

Author, Year Study Design | Group 1 (N) Group 2 (N) | Duration, weeks | Viral Shedding Outcome Measure Results | Symptomatic Episode Outcome Measure Results | HSV-2 Transmission Outcome Measure Results
Sperling, 2008^81^ RCT (crossover) | Total (63) Valacyclovir 1 g daily first (36) Placebo first (37) | 8 active; 8 placebo | Subjects with no shedding, N (%) G1: 47 (84) G2: 30 (54) p<0.001 % of days with any subclinical viral shedding, mean (SD) G1^*^: 1.5 (5.3) G2: 5.1 (9) p<0.001^†^ | Subjects reporting no signs or symptoms of genital herpes, N (%): G1: 49 (88) G2: 43 (77) p=0.033 | NR
Leone, 2007^82^ RCT (crossover) | Total (66) Famciclovir 250 mg twice daily first (NR) Placebo first (NR) | 6 active; 6 placebo | Subjects with any shedding, N (%) G1: 27 (42.9) G2: 29 (50.0) P=NR Reduction in subclinical shedding risk, G1 vs. G2: RR, 0.80 (95% CI, 0.41 to 1.56); p=0.52 | Subjects reporting genital lesions, N (%): G1: 11 (17.5) G2: 10 (17.2) p=NR | NR
Corey, 2004^76^ Kim, 2008^83^ RCT (parallel) | Total (1484 couples) Valacyclovir 500 mg once daily (743 couples) Placebo (741 couples) | 32 | NR | NR | HSV-2 seroconversion, N (%) G1: 14 (1.9) G2: 27 (3.6) HR, 0.52 (95% CI, 0.27 to 0.99); p=0.04 Incidence of symptomatic genital herpes, N (%) G1: 4 (0.5) G2: 16 (2.2) HR, 0.25 (95% CI, 0.08 to 0.75); p=0.008
Mujugira^84^ RCT (parallel) | Total (937 couples) Acyclovir 400 mg twice daily (458 couples) Placebo (453 couples) | 288 | NR | NR | HSV-2 seroconversion (N) G1: 40 G2: 28 HSV-2 incidence HR, 1.35 (95% CI, 0.83 to 2.20); p=0.220

* Persons with at least one swab during each crossover period.

† Nonparametric crossover analysis methods in the ITTC population (ITTC= intention to treat crossover, all subjects who had at least one dose of medication and one PCR result in each treatment period).

Abbreviations: NR=not reported; RCT=randomized, controlled trial; CI=confidence interval; HSV-2=herpes virus simplex type 2; N=number; HR=hazard ratio.

One RCT (n=63) assessed valacyclovir 1 g daily^81^ and the other (n=66) assessed famciclovir 250 mg twice daily.^82^ Both enrolled populations who were predominantly female (≥ 64%) and had a minority of nonwhite participants (35%). The mean age of participants was 37 years (range, 20 to 62 years) in one trial,^81^ and the other trial enrolled participants with a median age of 38 years (range, 18 to 68 years).^82^ Both were conducted at multiple centers in the United States. One recruited participants from various clinical settings (primary care clinics, gynecology practices, and STI clinics);^81^ the other trial did not describe how participants were identified.^82^ One RCT determined infection with HSV-2 via Western blot.^82^ The other RCT used the commercially available HerpeSelect ELISA to determine HSV-2 infection; positive samples with an index value between 1.1 and 3.5 were confirmed with a HSV-2 immunoglobulin G inhibition assay.^81^ Approximately half of participants in both trials also tested positive for HSV-1 infection (determined by the same methods as HSV-2 infection); only one trial described the number of participants with a clinical history of oral herpes (17%).^82^

One RCT reported a statistically significant reduction in viral shedding outcomes and the other did not. In the RCT comparing valacyclovir 1 g daily with placebo, participants were educated on performing self-administered swabs of the anogenital area, which they completed once daily during the 60-day treatment period. Valacyclovir treatment significantly reduced the number of days with subclinical HSV-2 shedding (1.5%) compared with placebo (5.1%; p<0.001) and also resulted in a greater proportion of subjects who experienced no days with shedding (84% vs. 54%, respectively; p=0.001).^81^ The RCT comparing famciclovir with placebo also collected daily swabs during the 60-day treatment period. Participants randomized to famciclovir or placebo had a similar risk of subclinical viral shedding; PCR samples were positive on 5.0 and 5.7 percent of days, respectively (relative risk [RR], 0.8 [95% CI, 0.41 to 1.56]; p=0.52).^82^

Key quality limitations across both trials included attrition (23% to 29% of participants) and unclear handling of missing data. In addition, the validity and reliability of daily self-swab to ascertain viral shedding is unclear, which contributes to potential measurement bias.

### KQ 5 Effectiveness of Preventive Medications and Counseling Interventions for Improving Health Outcomes

We included four fair-quality RCTs evaluating antiviral medications (Table 4).^76, 81–83^ Two focused on preventing transmission and enrolled adult heterosexual couples who were serologically discordant for HSV-2 infection (i.e., one partner had known genital herpes and the other partner had no prior diagnosis and was seronegative for HSV-2)^76, 83^ and two enrolled asymptomatic adults with no prior history of genital herpes who were seropositive for HSV-2 infection.^81, 82^ We describe the characteristics and results of trials among adults with asymptomatic HSV-2 infection and serodiscordant couples separately below. We identified no eligible studies that enrolled pregnant women or adolescents and no eligible studies that evaluated a behavioral counseling intervention.

#### Asymptomatic Adults With HSV-2 Infection

Two crossover RCTs compared daily suppressive antiviral medication with placebo over 6 to 8 weeks (Tables 4 and 5); both also reported on viral shedding outcomes, and study characteristics were described previously in the KQ 4 discussion. Both RCTs reported on the incidence of genital herpes symptoms; neither evaluated transmission of HSV-2 infection to a sexual partner.

In the RCT comparing valacyclovir 1 g daily with placebo, participants were educated on the signs and symptoms of genital herpes and instructed to return to the clinic any time they suspected an outbreak of genital herpes. At 2 months, fewer participants in the valacyclovir group reported signs and symptoms of genital herpes than in the placebo group (12% vs. 23%, respectively); the authors report that the treatment effect was significant (p=0.033, controlling for the crossover effect); however, the arithmetic mean of the difference between groups was not significant (11% [95% CI, −0.6 to 22]).^81^ In the RCT comparing famciclovir 250 mg twice daily with placebo, the percentage of persons reporting genital lesions in the famciclovir and placebo groups was similar at 6 weeks (17.5% and 17.2%, respectively; p-value not reported).^82^

Key quality limitations across both trials included attrition (23% to 25% of participants), unclear handling of missing data, and risk of measurement bias. Symptoms were ascertained by self-report (not using a validated questionnaire) over a relatively short duration (6 to 8 weeks). One study enrolled subjects who had HSV serologic testing as part of their clinical care (including some who were enrolled from STI clinics);^81^ results may not be applicable to persons who screen positive (but who are not seeking testing for HSV infection).

#### Serodiscordant Couples

Two RCTs compared the benefit of daily suppressive antiviral medication with placebo for preventing the transmission of HSV-2 between heterosexual couples who are serodiscordant for HSV-2 infection; one RCT measured outcomes at 8 months^76, 83^ and the other at 12 to 24 months (Tables 4 and 5).^84^ One study enrolled immunocompetent subjects,^76, 83^ while the other RCT was a substudy of HIV-1-serodiscordant couples in which the HIV-1-negative partner was also susceptible to HSV-2.^84^ One RCT (n=1,484 couples) assessed valacyclovir 500 mg daily^76, 83^ and the other (n=937 couples) assessed acyclovir 400 mg daily; in both studies, antiviral medication was provided to the infected partner.^84^ In both studies, the HSV-2-infected partners were predominantly female (≥67%). One study reported that participants were 89 to 91 percent Caucasian^76, 83^ and the other did not describe race/ethnicity.^84^ The median age of participants was 34 to 35 years in one trial^76, 83^ and 31 years in the other trial.^84^ Both studies were conducted in multiple countries; one enrolled from 96 study sites in the United States, Canada, Europe, Latin America, and Australia,^76, 83^ and one was conducted in seven sub-Saharan African countries.^84^

One RCT determined infection with HSV-2 using the HerpeSelect HSV-2 ELISA; positive samples with an index value less than 3.5 were confirmed with the Western blot.^84^ The other RCT enrolled couples if the source partner had recurrent genital herpes with fewer than 10 episodes per year and the susceptible partner had a negative HSV-2 Western blot.^76, 83^ Approximately 51 to 54 percent of participants in one trial tested positive for HSV-1 infection (determined by Western blot),^76, 83^ and the other trial reported that 93 percent or more of participants were infected with HSV-1;^84^ neither described the number of participants with a clinical history of oral herpes. Both RCTs reported on the transmission of HSV-2 infection to a sexual partner.

In the RCT comparing valacyclovir with placebo, fewer HSV-2-susceptible partners in the valacyclovir group had symptomatic HSV-2 infection than partners randomized to placebo over 8 months (0.5% vs. 2.2%, respectively; hazard ratio, 0.25 [95% CI, 0.08 to 0.75]); similarly, fewer HSV-2-suceptible partners in the valacyclovir group had seroconversion to HSV-2 than those in the placebo group (1.9% vs. 3.6%, respectively; p=0.04; hazard ratio, 0.52 [95% CI, 0.27 to 0.99]).^76, 83^ In contrast, the RCT of HIV-1-serodiscordant couples conducted in sub-Saharan African countries that compared acyclovir with placebo did not find a reduction in transmission. For participants who tested negative for HSV-2 at enrollment and positive at study exit, samples collected at intervening quarterly visits were used to identify the time of HSV-2 seroconversion. At followup (median, 18 months), the number of susceptible partners with seroconversion was not statistically different between the acyclovir group (40) and placebo group (28), which indicated seroincidence of 5.9 and 4.3 cases per 100 person-years, respectively (hazard ratio, 1.35 [95% CI, 0.83 to 2.20]; p=0.22).^84^

Key limitations across both trials included high attrition; 22 percent of couples withdrew from one trial,^76, 83^ and the overall attrition was 66 percent in the other trial (partially accounted for by imputing missing data).^84^

### KQ 6 Harms of Preventive Medications and Behavioral Counseling Interventions

We included one fair-quality RCT enrolling asymptomatic adults with no known history of genital herpes who screened positive for HSV-2 infection.^81^ This trial was also included in KQs 4 and 5; study characteristics are described in detail in KQ 4 and shown in Table 4. We identified no studies enrolling pregnant women and no trials assessing the benefits or harms of behavioral counseling interventions for asymptomatic adults who screen positive for HSV-2. Rates of reported adverse events were similar among groups randomized to valacyclovir and placebo, including dizziness, headache, and nausea (Appendix E Table 4).^81^

### KQ 7 Association Between Subclinical Viral Shedding and Health Outcomes

We had insufficient evidence to establish the benefit of preventive medications for reducing genital HSV-2 subclinical viral shedding and therefore did not address this KQ.