# 2 Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope, Key Questions (KQs), and analytic framework (Figure 1) that guided our literature search and review.

Figure 1 Analytic Framework and Key Questions

* Studies that screen using an HSV-2 serologic test alone or a “paired” (HSV-1 and HSV-2) serologic test will be included if they meet other eligibility criteria; however, only the accuracy of test characteristics related to HSV-2 serological tests will be evaluated.

** KQ 7 will only be addressed if there is insufficient literature for KQs 1 and 5 but sufficient literature for KQ 4.

Abbreviations: KQ=key question; HSV=herpes simplex virus.

Key Questions to Be Systematically Reviewed

1a Does serologic screening for herpes simplex virus type 2 (HSV-2) or combined testing for herpes simplex virus type 1 (HSV-1) and 2 in asymptomatic nonpregnant adults and adolescents reduce future symptomatic episodes and transmission of genital herpes?
1b Does serologic screening for HSV-2 or combined testing for HSV-1 and HSV-2 in pregnant women reduce neonatal HSV infection and symptomatic episodes of genital herpes at delivery?
2 What is the accuracy of serologic screening for HSV-2 in asymptomatic adults, adolescents, and pregnant women?
3a What are the harms of serologic screening for HSV-2 or combined testing for HSV-1 and HSV-2 in asymptomatic nonpregnant adolescents and adults?
3b What are the harms of serologic screening for HSV-2 or combined testing for HSV-1 and HSV-2 in asymptomatic pregnant women?
4 How effective are oral antiviral medications in reducing genital HSV-2 viral shedding in asymptomatic adolescents, adults, and pregnant women?
5a How effective are preventive medications and behavioral counseling interventions in reducing future symptomatic episodes and transmission of genital herpes in asymptomatic nonpregnant adults and adolescents?
5b How effective are preventive medications and behavioral counseling interventions in reducing neonatal HSV infection and symptomatic episodes of genital herpes at delivery in pregnant women?
6a What are the harms of preventive medications and behavioral counseling interventions for reducing future symptomatic episodes and transmission of genital herpes in asymptomatic nonpregnant adults and adolescents?
6b What are the harms of preventive medications and behavioral counseling interventions for reducing neonatal HSV infection and symptomatic episodes of genital herpes at delivery in asymptomatic pregnant women?
7 What is the evidence supporting an association between subclinical genital HSV-2 viral shedding and health outcomes in asymptomatic adults, adolescents, and pregnant women who are seropositive for HSV-2?

Contextual Questions

Contextual questions will not be systematically reviewed and are not shown in the Analytic Framework.

1. What proportion of asymptomatic adults, adolescents, and pregnant women who are identified as being seropositive for HSV-2, HSV-1, or both will have a recognized symptomatic episode of genital herpes?
2. Among asymptomatic adults, adolescents, and pregnant women who are identified as being seropositive for one virus subtype (HSV-1 or HSV-2), what proportion of recognized symptomatic episodes is due to a new (incident) HSV infection with a different subtype (i.e., nonprimary infection) versus a recurrent infection?
3. What is the estimated incidence rate of neonatal HSV infection in the United States?
4. What proportion of neonatal HSV infections in the United States is attributed to HSV-1 and HSV-2?
5. Are externally validated, reliable risk stratification tools available that distinguish persons who are more or less likely to have genital herpes?
6. What populations are at higher risk for genital herpes infection?

This figure depicts the Key Questions (KQs) within the context of the populations, interventions, comparisons, outcomes, and settings framework that will guide the evidence review. The population of interest is asymptomatic sexually active adults, adolescents, and pregnant women with no clinical history of genital herpes. An arrow from HSV serologic screening leads to “HSV status,” illustrating KQ 2: what is the accuracy of serologic screening for HSV-2? After HSV status comes “preventive medications and behavioral counseling,” which leads to the intermediate outcome of genital HSV-2 viral shedding, illustrating KQ 4: how effective are oral antiviral medications in reducing genital HSV-2 viral shedding? The health outcomes are genital herpes symptoms, transmission of genital herpes, and neonatal HSV infection. The dotted line illustrates KQ 7: what is the evidence supporting an association between subclinical genital HSV-2 viral shedding and health outcomes? KQs 1 and 5 are illustrated by two additional solid lines connecting “HSV serologic screening” and “preventive medications and behavioral counseling,” respectively, to the health outcomes box. These lines explore whether serologic screening (KQ 1) and preventive medications/behavioral counseling (KQ 5) reduce genital herpes symptoms and transmission of genital herpes (KQs 1a and 5a, respectively) and neonatal HSV infection (KQs 1b and 5b, respectively). Finally, two curved vertical arrows extend downward from “HSV serologic screening” and “preventive medications and behavioral counseling” to two ovals, each containing the word “harms,” illustrating KQ 3 and KQ 6, respectively.

In addition to our KQs, we also looked for evidence related to six Contextual Questions (CQs) focused on the prevalence, incidence, and natural history of genital herpes in the United States. These CQs were not a part of our systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and EMBASE for English-language articles published through March 31, 2016. We conducted ongoing surveillance after March 2016 through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and related USPSTF recommendation. The last surveillance was conducted on October 31, 2016. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. Appendix B1 describes the complete search strategies. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization’s International Clinical Trials Registry Platform. We retrieved all articles described in the 2005 review for the USPSTF^57^ and evaluated them using our eligibility criteria. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We reviewed all literature suggested by peer reviewers or public comment respondents and incorporated eligible studies into the final review. To minimize publication bias, we requested published or unpublished data on test accuracy (e.g., sensitivity, specificity) from studies comparing an available HSV-2 serologic test with the Western blot. We sent requests for data to all manufacturers currently listed in the FDA Approved Device Registration and Listing Database^58^ as being involved with the production or distribution of HSV-2 enzyme-linked immunoabsorbent assays (ELISA). We reviewed all information received from test manufacturers and incorporated eligible studies into the final review.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs (Appendix B2).^59^ We included English-language studies of immunocompetent adults or adolescents age 13 years or older, including pregnant women. For all KQs, studies of persons who did not have symptoms or a clinical history of genital herpes were eligible, as were studies of asymptomatic partners of persons with known genital herpes (i.e., serodiscordant couples). For KQ 1 (direct evidence that screening improves health outcomes), we included only randomized, controlled trials (RCTs) comparing groups that were screened with groups that were not screened.

For KQ 2 (screening test accuracy), we searched for studies that assessed the accuracy of FDA-approved serologic tests for HSV-2 (e.g., sensitivity, specificity) compared with the Western blot. The Western blot has been used as a gold standard in studies assessing commercially available serologic tests in the United States. Eligible populations could be either symptomatic or asymptomatic (or a combination of both). We excluded studies using tests that were not serologic (e.g., viral culture), not type-specific, and not commercially available or FDA-approved. We included studies assessing “paired” tests (i.e., those reporting HSV-1 and HSV-2) but we did not assess the accuracy of HSV-1. Good-quality, recent (within 5 years) systematic reviews were eligible, as well as trials or observational studies published since the most recent review for the USPSTF.

For KQ 3 (harms of screening), we included studies assessing the harms of screening in populations that are clearly asymptomatic (i.e., no current symptoms) and with no prior diagnosis of genital herpes, with or without a comparison group; eligible harms outcomes included labeling, anxiety, stigma, and others (Appendix B). Good-quality, recent (within 5 years) systematic reviews were eligible, as well as trials and observational studies published since the most recent review for the USPSTF.

Studies assessing benefits or harms of preventive medications for HSV-2 (KQs 4–6) and RCTs comparing FDA-approved oral antiviral medications for the suppression of recurrent genital HSV (acyclovir, famciclovir, or valacyclovir) with placebo were eligible. RCTs of behavioral counseling interventions (e.g., education or counseling; partner notification; barrier protection, such as condom use; or combinations of these components) were also eligible for KQs 5 and 6. For studies assessing the harms of antiviral medications in pregnant women (KQ 6b), multi-institution antiviral medication pregnancy exposure registries were eligible. Eligible outcomes included reduced rates of symptomatic episodes of genital herpes and genital herpes transmission (including measures of HSV-2 seroconversion). For KQ 5b (effectiveness of interventions in pregnant women), eligible outcomes included rates of neonatal HSV infection and reduced rates of symptomatic genital herpes at delivery. For KQ 4 (effects of antiviral medication on subclinical HSV-2 shedding), we included any outcome measure of subclinical HSV-2 shedding (e.g., percentage of days with any shedding detected); however, we did not include measures of viral shedding during symptomatic occurrences. Eligible harms outcomes for intervention studies (KQ 6) included medication-related adverse events and harms of behavioral counseling interventions (e.g., psychosocial harms). We did not include outcomes such as the transmission or acquisition of HIV. Other effective strategies of preventing HIV transmission exist,^60, 61^ and HIV prevention does not appear to be a strong rationale supporting screening for asymptomatic HSV-2 infection in U.S. primary care settings.

Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full text of abstracts marked for potential inclusion by either reviewer. Two experienced team members resolved any disagreements.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second investigator checked all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3).^62^ Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member. We included only studies rated as having good or fair quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular and narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of studies following established guidance.^63^ We qualitatively assessed the populations, serologic tests, interventions, comparators, outcomes, and study designs, looking for similarities and differences.

For KQ 2 (the only KQ with a sufficient number of studies addressing similar questions to conduct quantitative syntheses), we constructed 2 × 2 tables and calculated sensitivity and specificity and the corresponding 95 percent confidence intervals (CIs). When studies did not report sufficient data to populate a 2 × 2 table (e.g., number of true-positive and false-positive serologic test results), we calculated values based on the data provided (when possible). For each type of serologic test, we calculated pooled sensitivities and specificities using a hierarchical summary receiver-operator curve (HSROC) analysis when at least three similar studies were available. HSROC analysis simultaneously compares sensitivity and specificity (accounting for their correlation) for all studies comparing a particular serologic test with the Western blot. We conducted separate models for each type of serologic test and also conducted separate analyses for HerpeSelect^®^ (Focus Diagnostics, Cypress, CA) using the manufacturer-recommended cutpoint for test positivity (1.1) and for higher cutpoints reported in the literature. We used the metandi program in Stata version 14^64^ (StataCorp, College Station, TX) to conduct all quantitative analyses.

For each KQ, we assessed the consistency of results among studies (similar magnitude and direction of effect); precision of certainty surrounding an effect estimate; reporting bias; overall quality and limitations of the group of included studies; and applicability.

## Expert Review and Public Comment

The draft report was reviewed by content experts, USPSTF members, and AHRQ Medical Officers and was revised based on comments. The draft report was also posted for public comment, and revisions were made based on comments received.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.