# 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2005 recommendation on serologic screening for genital herpes simplex virus (HSV) infection. In 2005, the USPSTF recommended against routine serological screening for HSV in asymptomatic adolescents and adults (D recommendation) and asymptomatic pregnant women at any time during pregnancy to prevent neonatal HSV infection (D recommendation).^1^ The purpose of this report is to evaluate the evidence on benefits and harms of serologic screening for asymptomatic HSV infection and to review the performance characteristics of HSV serologic tests.

## Condition Definition

Genital herpes is a viral sexually transmitted infection (STI) caused by one of two HSV subtypes (HSV-1 or HSV-2). The term “genital herpes” is most often used to describe a range of signs and symptoms of HSV infection in the area innervated by the sacral nerve ganglion, typically genital or perianal lesions.^2, 3^ Table 1 describes the categories of genital HSV infection and the common clinical manifestations for each category. We use the term “asymptomatic” to refer to populations in whom serum antibody is present but there is no history of symptomatic occurrence.

Table 1 Clinical Categories of Genital HSV Infection^92^

Category | Definition | Clinical Manifestations
Primary genital HSV infection | Newly acquired genital HSV infection (either HSV-1 or HSV-2); no serum antibody is present when symptoms appear | Painful genital ulcers or vesicular lesions, potentially associated with dysuria, fever, tender local inguinal lymphadenopathy, and headache; can be subclinical or entirely asymptomatic
Nonprimary genital HSV infection | Newly acquired genital infection with HSV-2 (or HSV-1) in an individual previously seropositive to the other subtype. Type-specific antibody to one subtype is initially present while antibody to the new infection may take weeks or months to appear | In general, manifestations tend to be milder than those of primary infection (e.g., fewer lesions and less systemic symptoms); can be subclinical or entirely asymptomatic
Recurrent genital HSV infection | Reactivation of genital HSV in which the HSV type recovered from a lesion is the same type as antibodies in the serum; can be the first clinical episode in people with prior asymptomatic (or unrecognized) genital HSV infection | Ulcerative or vesicular lesions sometimes associated with a prodrome of local itching, tingling, or pain; usually milder and shorter in duration than primary infection; can be subclinical or entirely asymptomatic
Asymptomatic genital HSV infection | Genital HSV infection in which serum antibody is present, but there is no known history of clinical outbreaks | None or potentially mild or unrecognized symptoms previously attributed to another cause

Abbreviation: HSV=herpes simplex virus.

## Etiology and Natural History

Genital HSV acquisition occurs predominantly through sexual activity—genital-to-genital or orogenital contact—and viral latency is established in the sacral ganglia followed by viral reactivation and recurrent local disease.^3, 4^ HSV-2 accounts for the majority of prevalent cases of genital herpes and is more likely to cause frequent symptomatic recurrences and more severe symptoms than HSV-1 infection.^2, 5, 6^ HSV-1 is most commonly associated with orofacial herpes symptoms (e.g., “cold sores”) and usually acquired during childhood. The incubation period for genital HSV of either viral type ranges from 1 to 12 days, and is often followed by an occurrence of symptoms (primary infection).^2, 3^ Many persons will experience marked signs and symptoms during primary infection, including bilateral lesions along with regional lymphadenopathy, headache, fever, malaise, and other symptoms. Primary infection may also be mild or entirely asymptomatic.^7^

Recurrences may be symptomatic or asymptomatic (i.e., subclinical viral shedding only) and are common following symptomatic primary infection. An estimated 70 to 90 percent of patients with clinical first episodes of genital HSV-2 will experience recurrences in the first year and many will have multiple symptomatic episodes per year (the average number is 4 but some patients may have 10 or more).^3, 8^ Recurrences are more common with HSV-2 than HSV-1.^7, 9^ Over time, the average number of symptomatic recurrences per year declines.^7, 8^ Recurrences (as well as primary infection) can be associated with “nonclassical” signs and symptoms that may be misdiagnosed or confused with other conditions (e.g., yeast infections, fissures, urinary tract infections, irritation related to sexual intercourse).^7, 10–12^ In addition, episodic subclinical viral shedding (i.e., viral shedding in the absence of genital lesions) at skin and mucosal sites occurs in both men and women, leading to the potential for transmission in the absence of symptoms.^11, 13^

In women who have a prior history of symptomatic genital herpes, nearly 75 percent will have at least one recurrence during pregnancy, and about 14 percent will have prodromal symptoms or clinical recurrence at delivery.^14, 15^ Most cases of neonatal HSV are transmitted from mother to fetus by direct contact with the virus in the genital tract during birth.^16^

### Risk Factors

Risk factors for genital HSV infection have primarily been described using studies of seroprevalence (e.g., the National Health and Nutrition Examination Survey [NHANES]); the independence of factors such as age, sex, and number of sexual partners is unclear. Risk factors for genital herpes are discussed in more detail in Appendix A.

Among pregnant women, factors associated with seroconversion (i.e., incident HSV-2 infection) include younger age, being unmarried, and the occurrence of other sexually transmitted diseases.^17^ Perinatal transmission requires that the virus be present in the genital tract of the mother at the time of delivery, either symptomatically or asymptomatically. The risk of vertical transmission is related to the presence of maternal antibodies to HSV and the route of delivery (higher risk with vaginal vs. cesarean delivery).^16, 18^ Women who acquire HSV near the time of delivery are at higher risk for vertical transmission compared with women who have antibodies to HSV-1, HSV-2, or both.^7, 16^ Additional risk factors for development of neonatal HSV among infants born to women with positive HSV cultures obtained at delivery include the use of fetal scalp electrodes, HSV isolated from the cervix (vs. from the vulva only), and premature delivery (<38 weeks).^16^

## Prevalence and Burden

Genital herpes is one of the most prevalent STIs in the United States. Data from the 2005–2010 NHANES estimated the seroprevalence of HSV-2 among persons ages 14 to 49 years at 15.5 percent.^19^ Estimated seroprevalence rates vary by age, sex, race/ethnicity, and geographic region. HSV-2 seroprevalence is estimated to be 1.4 percent among persons ages 14 to 19 years compared with 26.1 percent among adults ages 40 to 49 years.^19^ Women have a higher estimated seroprevalence than men (20.9% vs. 11.5%), which is attributed to anatomic factors predisposing women to be more susceptible to HSV-2 infection than men. Men who have sex with men have a HSV-2 seroprevalence similar to that of women (20.7% among men who have ever reported sex with another man, and 23.2% for those who reported it in the last 12 months).^20^ Non-Hispanic blacks have the highest estimated seroprevalence of HSV-2 infection at 39.2 percent, which is 3 times that of non-Hispanic whites (12.3%).^19^ NHANES data from 1988–2004 estimate that 35 percent of pregnant women were seropositive for HSV-2.^21, 22^

HSV-1 infection is common. The seroprevalence of genital herpes due to HSV-1 alone is uncertain because a positive serologic test for HSV-1 can signify oral infection only, genital infection only, or both. NHANES data from 2005–2010 estimate HSV-1 seroprevalence at 53.9 percent.^6^ Historically, HSV-1 is transmitted in childhood via oral secretions. However, studies in the United States and Europe have documented declining rates of HSV-1 acquisition during childhood. In the United States (based on NHANES data), the seroprevalence of HSV-1 among younger cohorts (ages 14 to 19 years) has greatly declined over the past few decades.^6^ Among subgroups of NHANES participants, a higher proportion of persons infected with HSV-1 (but not with HSV-2) reported having been diagnosed with genital herpes in 1999–2004 compared with 1988–1994 (1.8% vs. 0.4%, respectively; p<0.001).^23^

In addition, some data suggest that HSV-1 is a more common cause of incident genital herpes than HSV-2.^24–29^ For example, in the control arm of a herpes vaccine trial (N=3,438), women who were seronegative for HSV-1 and HSV-2 had a higher incidence of HSV-1 (2.5 cases per 100 person-years) compared with HSV-2 (1.1 cases per 100 person-years) infection over a 20-month period.^24^ Most infections (74% of HSV-1 and 63% of HSV-2) occurred without recognized signs or symptoms of herpes disease. Of the 54 participants presenting with symptomatic HSV, 33 had HSV-1 disease (5 oral, 24 genital, 4 both genital and oral) and 21 had HSV-2 disease (all genital).^12, 24, 30^

Genital HSV infection can lead to both acute and chronic morbidity. Table 1 outlines the clinical features of primary, nonprimary, and recurrent infection. Nonprimary first-episode infection is associated with fewer lesions and less systemic symptoms than primary infection, presumably because the presence of antibodies against one HSV type offer some protection against the other.^31, 32^Acute primary (or nonprimary) infection can be severe and associated with multiple, bilateral, ulcerating, pustular lesions that resolve after a mean duration of 19 days.^31^ Extragenital complications can also occur; in a study of 268 adults with primary first-episode genital herpes, extragenital complications included aseptic meningitis (8%), urinary bladder retention due to sacral autonomic nervous system dysfunction (2%), secondary yeast infections (11%), and distant skin lesions (20%).^31^

Genital HSV-2 infection is highly prevalent among HIV-infected patients. Epidemiologic studies suggest that incident and prevalent genital HSV-2 increases the risk of HIV acquisition;^33–36^ potentially due to disruption of the genital mucosal barrier or alteration of immunologic factors (or both). In addition, genital HSV-2 infection may contribute to the risk of HIV transmission by increasing HIV genital shedding (particularly at sites of genital ulcerations).^37^ Whether this association results from similar modes of acquisition or to biologic interactions between the two viruses has been a topic of debate. So far, clinical trials have not supported a role for HSV-2 suppressive therapy in preventing HIV acquisition among HSV-2 seropositive HIV-uninfected persons.^38, 39^

Approximately half of persons with symptomatic recurrences have prodromal symptoms before eruption of genital lesions (e.g., local mild tingling or shooting pains in the buttocks, legs and hips).^32, 40^ Because of the chronic nature of genital HSV, those with symptomatic infections often experience psychological distress following diagnosis. Common worries for patients include the potential for ongoing symptomatic episodes, the impact of herpes on sexual relationships, questions about transmission to sexual partners, and management of herpes in pregnancy.^41^

Genital HSV infection during pregnancy is of particular concern because of the risk of transmission to the infant during delivery. Vertical transmission typically occurs by direct contact with the virus in the genital tract during delivery. Estimated rates of neonatal infection with HSV range from 1 of every 3,200 to 10,000 live births in the United States.^16, 42–44^ One large multistate study found an overall incidence of 9.6 cases per 100,000 births in 2006;^42^ rates varied significantly by geographic region, race/ethnicity, and insurance status. Mothers with Medicaid had higher rates of neonatal infection during delivery than mothers with private insurance or managed health care (15.1 vs. 5.4 cases per 100,000 births).^42^ The most recent estimate is based on a clinical laboratory reporting system initiated in New York City in 2006.^45^ Between April 2006 and September 2010, 76 cases were detected, and the average incidence was estimated at 13.3 cases per 100,000 live births (or 1 case per 7,519 live births).^45^ Most reported cases were laboratory confirmed (91%); 41 percent (28 cases) were HSV-1 and 39 percent (27 cases) were HSV-2 (20% of cases were not typed).^45^

Vertical transmission of HSV can lead to significant fetal morbidity and mortality. Among newborns diagnosed with neonatal herpes, approximately 45 percent of cases involve infection of the skin, eye, and mucous membranes; 30 percent develop the encephalitic form of neonatal herpes (which presents with nonspecific signs and symptoms such as fever, lethargy and irritability, or poor feeding); and 25 percent develop disseminated disease.^46^ Many survivors of central nervous system neonatal herpes infection are left with long-term neurodevelopmental impairment.^47^ Approximately 30 percent of infants with disseminated disease and 4 percent with central nervous system disease will die from HSV infection.^32^

## Rationale for Screening

In theory, serologic screening to identify unrecognized HSV-2 infection followed by appropriate counseling or treatment could prevent transmission (to partners and neonates) and reduce future morbidity from symptomatic recurrences. Episodic or suppressive antiviral treatment for HSV-2 infection may be prescribed to reduce symptomatic episodes and shedding. In pregnant women, serologic screening to identify seronegative women followed by appropriate counseling could reduce neonatal HSV infection given that women who acquire HSV late in pregnancy (and who are seronegative at delivery) are at highest risk for vertical transmission.

Several U.S. Food and Drug Administration (FDA)-approved type-specific HSV serologic tests rely on glycoprotein G to distinguish between HSV-1 and HSV-2 antibodies; however, after exposure, it may take 6 weeks to 3 months for antibody response to occur.^48^ Since HSV-2 rarely causes infection outside the anogenital region, the presence of HSV-2 antibodies in serum can be interpreted as an indicator of genital herpes infection.^49^ For persons without symptoms (e.g., no genital lesions), the HSV Western blot is considered the gold standard for the diagnosis of herpes via serology. Although a Western blot test can be obtained by sending samples to the University of Washington Virology Laboratory, this test is not commercially available as a confirmatory test for persons who screen positive for HSV-2 on an FDA-approved commercially available serologic test. Genital HSV-1 infection cannot be diagnosed using serologic tests; HSV-1 is highly prevalent and these tests cannot determine the site of infection. For persons with genital lesions, viral culture and polymerase chain reaction (PCR)-based testing are the preferred tests to confirm a diagnosis of genital herpes.^50^ These tests are not recommended in persons without genital lesions given that subclinical viral shedding is intermittent.

## Summary of Guidelines From Other Groups

The Centers for Disease Control and Prevention (CDC), U.K. National Guidelines, American Academy of Family Physicians, Society of Obstetricians and Gynaecologists of Canada (SOGC), and the American Congress of Obstetricians and Gynecologists (ACOG) do not recommend routine serologic screening for genital herpes in asymptomatic adults or adolescents.^51–55^ The CDC guidelines note that type-specific HSV serologic screening for genital herpes may be helpful in the following situations: for patients who present with recurrent atypical genital symptoms and whose HSV cultures are negative, when a clinical diagnosis of genital herpes is made without laboratory confirmation, and for persons who have partners known to have genital herpes.^19, 54^ Finally, the CDC guidelines state that providers should consider serologic testing for genital herpes in persons presenting for a sexually transmitted disease evaluation (especially for those persons with multiple sex partners), persons with HIV infection, and men who have sex with men at increased risk for HIV acquisition.^19, 54^

For pregnant women, the American Academy of Family Physicians and ACOG recommend against routine serologic screening.^53, 55^ Both the CDC and SOGC recommend asking about a personal history of genital herpes.^51, 54^ The CDC, SOGC, and U.K. National Guidelines recommend conducting type-specific HSV serology for pregnant women who have had partners with known HSV to determine their risk of acquiring genital HSV in pregnancy.^51, 52, 54^ However, the CDC cautions that the effectiveness of antiviral therapy to decrease the risk for HSV transmission to pregnant women by infected partners has not been studied.^19, 54^ The CDC recommends advising pregnant women who are not known to have HSV 2 infection to abstain from intercourse with partners who are known or suspected to have genital herpes during the third trimester of pregnancy; similarly, women who are not known to have HSV 1 infection should be advised to abstain from receptive orolabial intercourse with partners who are known or suspected of orolabial herpes infection.^19, 54^

Recommendations for reducing neonatal HSV transmission focus on identifying active genital lesions or prodromal symptoms during the antenatal period. For women with active genital lesions (due to recurrent or primary infection) or prodromal symptoms that may indicate an impending outbreak, SOGC, ACOG, CDC, and the National Collaborating Centre for Women’s and Children’s Health all recommend cesarean delivery to reduce the risk of neonatal HSV infection.^51, 54–56^ ACOG, SOGC, and the CDC recommend that women with active recurrent genital herpes should be offered suppressive viral therapy at or beyond 36 weeks of gestation to decrease the risk of clinical lesions and viral shedding at the time of delivery (and therefore decrease the need for cesarean delivery).^51, 55^

Cesarean delivery is not recommended for women with a history of HSV infection but no active genital disease during labor.^55^

## Current Clinical Practice in the United States

We were not able to find data on actual screening practices for genital herpes in the United States. Most guidelines described above do not recommend routine serologic screening for genital herpes in asymptomatic populations.