# Appendix E Additional Tables of Results

Appendix E Table 1 Results of Included Studies Assessing the Accuracy of HerpeSelect for HSV-2 (Key Question 2)

Author, Year Country | N Eligible (N analyzed) | Equivocal Tests Excluded^*^ (Cutpoint^†^); N | Cutpoint: Sensitivity (95% CI) | Cutpoint: Specificity (95% CI) | Cutpoint: PPV (95% CI) | Cutpoint: NPV (95% CI)
Ashley-Morrow, 2004^66^ Multinational | NR (675) | WB=9^‡^ HS=11 | 1.1: 97.0 (NR) 3.5: 90.0 (NR) | 1.1: 89.0 (NR) 3.5: 96.0 (NR) | 1.1: 86.0 (NR) 3.5: 86.0 (NR) | 1.1:98.0 (NR) 3.5:98.0 (NR)
Delany-Moretlwe, 2009^75^ South Africa | 210 (98)^§^ | NR | 1.1: 98.0 (95.0 to 100.0) 3.5: 94.0 (89.0 to 100.0) | 1.1: 61.0 (48.0 to 74.0) 3.5: 87.0 (67.0 to 100) | NR | NR
Golden, 2005^69^ US | Unclear^¶^ (1.1=61) (1.5=55) (2.0=50) (2.5=47) (3.0=43) | WB (all)= 5 HS (1.1)=NR HS (1.5)= 9 HS (2.0)=18 HS (2.5)=26 HS (3.0)=30 | NR | NR | 1.1: 84.0 (NR) 1.5: 85.0 (NR) 2.0: 92.0 (NR) 2.5: 96.0 (NR) 3.0: 98.0 (NR) | NR
Hogrefe, 2002^70^ African countries | 785 (765) | HS =5 | 1.1: 99.6 (NR) 1.5: 98.0 (NR) 2.1: 95.9 (NR) 2.5: 93.7 (NR) 3.1: 90.5 (NR) | 1.1: 88.0 (NR) 1.5: 93.0 (NR) 2.1: 94.9 (NR) 2.5: 96.5 (NR) 3.1: 97.8 (NR) | NR | NR
Lingappa, 2010^73^ Uganda | 493 (467) | WB=25 | 1.1: 99.5 (98.5 to 100.1) 2.2: 96.4 (94.4 to 98.3) | 1.1: 70.2 (64.1 to 76.1) 2.2: 92.4 (87.0 to 96.9) | NR | NR
Mark, 2007^65^ US | 100 (89) | HS=3 | 1.1: 100.0 (30.9 to 100) | 1.1: 94.1 (86.3 to 97.8) | 1.1: 37.5 (10.2 to 74.1) | 1.1: 100 (94.3 to 100)
Morrow, 2005^70^ US | 1749 (782) | WB= 37 HS= 26 | 1.1: 99.2 (96.3 to 100.0) | 1.1: 93.2 (91.8 to 94.6) | 1.1: 80.5 (76.9 to 84.2) | 1.1: 99.7 (98.9 to 100)
Mujugira, 2011^67^ African countries | 3408 (3290) | WB=109 | 1.1: 98.3 (NR) 2.1: 93.9 (NR) 3.5: 82.9 (NR) | 1.1: 80.3 (NR) 2.1: 90.5 (NR) 3.5: 95.1 (NR) | NR | NR
Ng’ayo, 2010^74^ Kenya Gen 1^**^ | 250 (1.1:229) (3.5:154) | WB: 15 HS (1.1)=6 HS (3.5)=90 | 1.1: 98.6 (95.1 to 99.8) 3.5: 97.2 (92.8 to 99.3) | 1.1: 63.5 (52.9 to 73.0) 3.5:93.0 (83.3 to 97.1) | 1.1: 82.1 (NR) 3.5: 96.0 (NR) | 1.1=96.4 (NR) 3.5: 96.4 (NR)
Ng’ayo, 2010^74^ Kenya Gen 2^**^ | 250 (1.1:233) (3.5:179) | WB=15 HS (1.1)=6 HS (3.5)=64 | 1.1: 99.3 (96.2 to 99.8) 3.5: 99.2 (95.6 to 99.8) | 1.1: 52.3 (97.6 to 58.0) 3.5:94.9 (73.3 to 92.2) | 1.1: 77.4 (NR) 3.5: 94.0 (NR) | 1.1=97.8 (NR) 3.5: 97.8 (NR)
Smith, 2009^68^ Kenya | 120 (99) | HS=1 | 1.1:100 (86.0 to 100.0) 3.5:80.0 (59.0 to 93.0) | 1.1: 41.0 (30.0 to 53.0) 3.5: 80.0 (70.0 to 89.0) | NR | NR
Van Dyck, 2004^72^ African countries | 330 (NR) | NR | 1.1: 100 (NR) | 1.1: 97.5 (NR) | NR | NR

* This refers to the number of samples that were excluded from the sensitivity, specificity, PPV or NPV calculation because of an equivocal, indeterminate, or uninterpretable result. Other samples that were eligible may have been excluded for other reasons (e.g., insufficient serum sample).

† Cutpoint refers to the cutoff value at or above which the test is considered positive.

‡ Two of these were equivocal by Western blot and HerpeSelect.

§ Sensitivity and specificity for whole sample (210) were calculated using the results of 98 participants who had results compared with Western blot. Handling of equivocal tests is unclear.

¶ These numbers and estimates refer to the subgroup of participants who had no clinical evidence of genital herpes.^69^

** This study reported estimates separate for the first generation and second generation HerpeSelect.

Abbreviations: CI=confidence interval; HS=Focus HerpeSelect; HSV-2=herpes virus simplex type 2; N=number; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; WB=Western blot.

Appendix E Table 2 Characteristics and Results of Included Studies Assessing the Accuracy of Biokit Rapid HSV-2 (Key Question 2)

Author, Year Country | N eligible (N analyzed); Equivocal tests excluded (N) | Population; Country | Age, mean (SD) | % Female | % Nonwhite | % Comorbid STI | % HSV-1 | Results: Sens: (95% CI) Spec: (95% CI) | Results: PPV (95% CI) NPV (95% CI)
Lingappa, 2010^73^ Good | 493 (467) N excluded: 25 (WB) | Adults participating in a study of genital herpes seroprevalence and incidence; Uganda | NR | NR | NR | 12 (HIV=1) | NR | Sens: 86.4 (83.1 to 89.7) Spec: 97.0 (94.3 to 99.0) | NR
Morrow, 2005^70^ Fair | 1749 (782) N excluded: 63^*^ | Two populations enrolled:; 1. adult MSM screened for enrollment in a clinical trial assessing acyclovir to reduce HIV transmission and; 2. consecutive serologic samples submitted for HSV WB testing at the University of Washington Virology Laboratory; United States | NR | 0 | NR | NR | 64 (WB) | Sens: 90.5 (86.1 to 94.0) Spec: 98.4 (97.5 to 99.3) | PPV: 94.5 (90.5 to 97.3) NPV: 99.7 (98.9 to 100)
Ng’ayo, 2010^74^ Fair | 250 (233) N Excluded: 15 (WB); 3 (Biokit) | Adult men who worked in the fishing industry who reported being sexually active in the previous 2 weeks; Kenya | NR (all ≥18 y) | 0 | NR | NR | NR | Sens: 66.0 (57.9 to 73.2) Spec: 90.9 (83.2 to 95.4) | PPV: 92.2 (NR) NPV: 62.3 (NR)
Van Dyck, 2004^72^ Fair | 330 (NR) | Adults who were enrolled in a study on factors determining the spread of HIV; Kenya, Zambia, Benin, Cameroon | NR (all 15–49 y) | NR | NR | NR | NR | Sens: 83.0 (NR) Spec: 95.0 (NR) | NR

* This study also assessed the accuracy of HerpeSelect. Samples that were equivocal on HerpeSelect (n=26) or Western blot (n=37) were not tested with Biokit Rapid HSV-2.

Abbreviations: CI=confidence interval; HIV=human immunodeficiency virus; HSV=herpes simplex virus; N=number; SD=standard deviation; sens=sensitivity; spec=specificity; PPV=positive predictive value; STI=sexually transmitted infection; NPV=negative predictive value; NR=not reported; y = year.

Appendix E Table 3 Characteristics and Results of Included Studies Assessing Harms of Serologic Screening for Genital Herpes (Key Question 3)

Author, Year Study Design Quality | Population; Country | Age, mean (SD) | % Female | % Nonwhite | % Comorbid STI | Results
Melville, 2003^78^ Qualitative Fair | Patients at 4 clinics (STD, maternal and infant care, family medicine, virology research) with positive HSV-2 serology; age 14 or older, able to communicate in English, with HSV-2 infection determined by WB but no history of genital herpes United States (24) | 35 (range, 19 to 55) | 58 | 25 | NR | Short-term emotional responses: N (%)^*^; - Denial: 9 (38); - Confusion: 8 (33); - Distress: 6 (25); - Sadness: 4 (17); - Disappointment: 4 (17); - Self-blame: 3 (13); - Surprise: 12 (50.0); - Relief to know: 5 (20.8); - “Why me?”: 3 (12.5); Short-term psychosocial responses: N (%)^*^; - Fear of telling current partner: 11 (46); - Fear of telling past partner(s): 4 (17); - Anger at source partner: 6 (25); - Guilt about acquiring or transmitting: 5 (21); - Concern about transmitting to child: 4 (17); - Decreased libido: 3 (12.5); Perceived ongoing responses: N (%)^*^; - Feeling socially stigmatized: 8 (33); - Feeling like “damaged goods”: 8 (33); - Fear of telling future partner(s): 12 (50); - Feeling sexually undesirable: 10 (42); - Relationship problems after diagnosis: 8 (33); - Increased commitment to current partner: 3 (13); - Relieved to discover both have HSV-2: 3 (13); - Reluctance toward future relationships: 3 (13); - Acceptance: 14 (59); - Concern about transmitting to partner: 11 (46); - Sex avoidance due to social responsibility: 8 (33); - Concern of transmitting to newborn: 7 (29)
Rosenthal, 2006^79^ Cohort study Fair | Persons (ages 14–30 years) without a history of genital herpes recruited from various settings (urban university; STD, primary care, and adolescent clinics). Participants completed a questionnaire and were offered free HSV-2 antibody testing. (HSV-2 positive=33) | 24 (3.6) | 88 | 52 | NR; 46% of sample recruited from STI clinic | Genital herpes HRQOL^†^ at 3 months: Most endorsed items (% endorsed as “‘very” or “quite”):; - “It is difficult to forget that I have herpes” (63); - “I worry about giving herpes to someone” (56); - “I worry about people I know finding out I have herpes” (48); - “I feel insecure about personal (intimate) relationships because of herpes” (30); - “I get depressed about having herpes” (30); - “I feel angry about having herpes” (30); - “I worry that people will reject me if they know I have herpes” (30)

* These items were expressed by at least three individuals during focus groups. Items described as short-term relate to initial reactions. Those categorized as “perceived ongoing” were experienced by participants months after diagnosis.

† Genital herpes HRQOL is a 20-item measure that addresses issues such as feelings of shame associated with having genital herpes.^80^ In this study, participants responded to each item using a 4-point response ranging from “very” to “not at all.” “Very” and “quite” were considered to be indicative of endorsing the experience described in individual items.

Abbreviations: NR=not reported; HRQOL=health-related quality of life; HSV=herpes simplex virus; SD=standard deviation; STI=sexually transmitted infection.

Appendix E Table 4 Characteristics and Results of Included Studies Assessing Harms of Preventive Interventions (Key Question 6)

Author, Year Study Design Quality | G1 (N) G2 (N) | Duration (weeks) | Population | Recruitment Setting; Country | HSV-2 Test | Mean Age (SD) | % Female | % Nonwhite | % HSV-1 Positive | Results
Sperling, 2008^81^ RCT (crossover) Fair | Total (63) Valacyclovir 1 g daily first (36) Placebo first (37) | 8 active; 8 placebo | Adults seropositive for HSV-2 with no active lesions or symptoms consistent with genital herpes and no history of recurrent or undiagnosed symptoms consistent with genital herpes | 13 clinical settings (STI clinics, primary care clinics, and gynecology practices) United States | HerpeSelect | 37 (NR) | 75 | 35 | 56–57 | % of participants reporting adverse events: Dizziness G1: 6 G2: 2 Headache G1: 5 G2: 6 Nausea G1: 5 G2: 2 p-value NR

Abbreviations: G=Group; HSV=herpes simplex virus; N=number; NR=not reported; RCT=randomized, controlled trial; SD=standard deviation; STI=sexually transmitted infection.

Appendix E Figure 1 HerpeSelect Hierarchical Summary Receiver-Operator Curve, Manufacturer’s Recommended Cutpoint

This HSROC compares sensitivity and specificity for the 10 studies reporting on the accuracy of HerpeSelect at the manufacturer’s recommended cutpoint for a positive test (1.1).

Abbreviation: HROC=hierarchical summary receiver-operating curve.

This figure displays the results of a hierarchical summary receiver-operating curve (HSROC) analysis comparing sensitivity and specificity for the 10 studies reporting on the accuracy of HerpeSelect at the manufacturer’s cutpoint for a positive test (1.1). Sensitivity is shown on the Y-axis of the graph, starting with 0 and ranging to 1.0. Specificity is shown on the X-axis, starting with 1.0 and ranging to 0. Individual study estimates of sensitivity and specificity are depicted on the graph using closed circles. The pooled summary estimate of the 10 studies yielded a sensitivity of 0.99 with a 95% confidence interval of 0.97 to 1.00, and a pooled specificity estimate of 0.81 with a 95% confidence interval of 0.68 to 0.90. The HSROC curve is depicted starting in the lefthand corner of the graph and extending upward and rightward, passing directly through the pooled summary estimate of sensitivity and specificity noted above. A 95% prediction region is indicated on the graph by curved lines around the pooled summary estimate and its associated 95% confidence interval.

Appendix E Figure 2 HerpeSelect Hierarchical Summary Receiver-Operator Curve, Higher Cutpoints

This HSROC compares sensitivity and specificity for the 7 studies reporting on the accuracy of HerpeSelect at cutpoints between 2.1 and 3.5.

Abbreviation: HROC=hierarchical summary receiver-operating curve.

This figure displays the results of a hierarchical summary receiver-operating curve (HSROC) analysis comparing sensitivity and specificity for the 7 studies reporting on the accuracy of HerpeSelect at higher cutpoints for a positive test (2.1 to 3.5). Sensitivity is shown on the Y-axis of the graph, starting with 0 and ranging to 1.0. Specificity is shown on the X-axis, starting with 1.0 and ranging to 0. Individual study estimates of sensitivity and specificity are depicted on the graph using closed circles. The pooled estimate of the 7 studies yielded a sensitivity of 0.95 with a 95% confidence interval of 0.91 to 0.97, and a specificity estimate of 0.89 with a 95% confidence interval of 0.82 to 0.93. The HSROC curve is depicted starting at the lefthand corner of the graph and extending upward and rightward, passing directly through the pooled summary estimate of sensitivity and specificity noted above. A 95% prediction region is indicated on the graph by curved lines around the pooled summary estimate and its associated 95% confidence interval.

Appendix E Figure 3 Biokit HSV-2 Hierarchical Summary Receiver-Operator Curve

This HSROC compares sensitivity and specificity for the 4 studies reporting on the accuracy of Biokit HSV-2.

Abbreviation: HROC=hierarchical summary receiver-operating curve.

This figure displays the results of a hierarchical summary receiver-operating curve (HSROC) analysis comparing sensitivity and specificity for the 4 studies reporting on the accuracy of Biokit HSV-2. Sensitivity is shown on the Y-axis of the graph, starting with 0 and ranging to 1.0. Specificity is shown on the X-axis, starting with 1.0 and ranging to 0. Individual study estimates of sensitivity and specificity are depicted on the graph using closed circles. The pooled estimate of the 4 studies yielded a sensitivity estimate of 0.84 with a 95% confidence interval of 0.73 to 0.91, and a specificity estimate of 0.95 with a 95% confidence interval of 0.93 to 0.97. The HSROC curve is depicted starting at the lefthand corner of the graph and extending upward and rightward, passing directly through the pooled summary estimate of sensitivity and specificity noted above. A 95% prediction region is indicated on the graph by curved lines around the pooled summary estimate and its associated 95% confidence interval.